# SEARCH STRATEGY

Database: Ovid MEDLINE(R) <1950 to May Week 4 2010>

Search Strategy:

1. exp *Health Services Accessibility/ (34616)
2. limit 1 to (english language and humans and yr=”1990 -Current” and “all adult (19 plus years)” and english) (6577)
3. *Veterans/ (4309)
4. *United States Department of Veterans Affairs/ (1252)
5. *Hospitals, Veterans/ (2008)
6. or/3-5 (6992)
7. 2 and 6 (75)
8. access.mp. (114750)
9. 6 and 8 (287)
10. limit 10 to (english language and humans and yr=”1990 -Current” and “all adult (19 plus years)” and english) (182)
11. 7 or 10 (209)