# Dietary Data Brief No. 15 Phosphorus Intake of Americans

What We Eat In America, NHANES 2011-2012

Phosphorus is the second most abundant mineral in the body after calcium. The main role of phosphorus is formation of bones and teeth, but it is also needed for the growth, maintenance, and repair of cells and tissues. Phosphorus works in conjunction with the B vitamins to assist with kidney function, muscle contractions, maintaining a normal heartbeat, and nerve signaling (1). This report describes the dietary intake of phosphorus of the U.S. population as reported in What We Eat In America (WWEIA), NHANES 2011-2012.

Highlights

- The mean daily intake of phosphorus was 1393 mg.
- Adolescent and adult males had higher phosphorus intakes than their female counterparts.
- The diets of children 2-5 years had higher phosphorus density compared to those of children 6-11 years and adults up to 60 years.
- Phosphorus intake differed by race/ethnicity. Intakes were lower for blacks and Asians compared to whites and Hispanics.
- Dairy products were the largest contributor (20%) to daily intake of phosphorus, followed by breads and sweet bakery products at 10%.

## How much phosphorus is the U.S. population consuming?

The mean daily intake of phosphorus for individuals 2 years of age and older was 1393 mg. Phosphorus intake has remained relatively consistent for the last 10 years: mean daily phosphorus intake in 2001-2002 was 1315 mg (2). As shown in Figure 1, intake of males was higher than females for adolescents and adults. Most (96%) Americans obtain recommended amounts of phosphorus from their diets with the exception of adolescent females. At least one-third of adolescent females do not meet their recommendation for phosphorus (3).

Figure 1 Mean daily phosphorus intake by age and gender, 2011-2012

*Significantly different from females (p<0.001)

SOURCE: What We Eat in America, NHANES 2011-2012, day 1, individuals 2+ years

## Is phosphorus intake influenced by energy intake?

When mean daily phosphorus intake was adjusted by energy intake (mg per 1000 kcal), there were no differences between males and females within age groups (data not shown). However, as seen in Figure 2, when examined across age groups irrespective of gender, children 2-5 years of age had diets of greater phosphorus density compared to children aged 6-11 and adults up to 60 years old.

Figure 2 Phosphorus density (mg per 1000 kcal) by age, 2011-2012

^a^Significantly different from 2-5 age group (p<0.001)

^b^Significantly different from 60+ age group (p<0.001)

SOURCE: What We Eat in America, NHANES 2011-2012, day 1, individuals 2+ years

## Does phosphorus intake differ by race/ethnicity or income status?

There were differences in mean daily phosphorus intake when examined by race/ethnicity. Figure 3 illustrates blacks and Asians had lower mean daily phosphorus intakes compared to whites and Hispanics. However, intake did not differ by income level (data not shown).

Figure 3 Mean phosphorus intake of the U.S. population by race/ethnicity, 2011-2012

^a,b^ Race/ethnicity groups with different superscript letter significantly different from each other (p<0.001)

SOURCE: What We Eat in America, NHANES 2011-2012, day 1, individuals 2+ years

## What foods and beverages contribute to phosphorus intake of the U.S. population?

Table 1 shows the contribution of WWEIA Food Categories (4) to phosphorus intake of the population. Dairy products including milk, cheese, ice cream and yogurt provided the highest contribution to the day’s total intake of phosphorus (20%). Following dairy, bakery products contributed 10% of the day’s intake; these included bread, rolls, tortillas, and sweet bakery products. Other categories that each contributed 5% were vegetables, chicken, Mexican dishes, and pizza.

Table 1 Top contributing WWEIA Food Categories to phosphorus intake of the U.S. population, 2011-2012

WWEIA Food Category^*^ | Individuals reporting (%)^‡^ | Contribution to phosphorus intake (%)
Dairy Products
Milk and flavored milk | 46 | 11
Cheese, ice cream, yogurt | 49 | 9
Bakery Products
Breads, rolls, tortillas | 59 | 5
Sweet bakery products and quick breads | 49 | 5
Vegetables | 65 | 5
Chicken | 26 | 5
Mexican dishes (burritos, tacos, nachos) | 14 | 5
Pizza | 13 | 5

* WWEIA Food Categories not shown that provided 3 to <5% of phosphorus intake: eggs; beef; cured meats; plant-based protein foods; cereals; meat, poultry, and seafood mixed dishes; grain-based mixed dishes; and sandwiches.

‡ Percentage of individuals reporting foods in the category at least once on the reporting day.

SOURCE: What We Eat in America, NHANES 2011-2012, day 1, individuals 2+ years

## Definitions

Phosphorus density: Amount of phosphorus (mg) consumed per 1000 kcal of energy intake. This is a measure of the concentration of a nutrient in a daily dietary intake.

## Data source

Estimates in this report are based on one day of dietary intake data of 7933 individuals age 2 years and older collected in What We Eat in America (WWEIA), the dietary interview component of the National Health and Nutrition Examination Survey (NHANES) in 2011-2012. Sample weights were applied in all analyses to produce nationally representative estimates.

## References

1 Institute of Medicine (US) Standing Committee on the Scientific Evaluation of Dietary Reference Intakes. Dietary Reference Intakes for Calcium, Phosphorus, Magnesium, Vitamin D, and Fluoride. Washington (DC): National Academies Press (US); 1997.
2 U.S. Department of Agriculture, Agricultural Research Service. 2005. What We Eat in America, NHANES 2001-2002: Nutrient Intakes: Mean Amount Consumed per Individual, One Day. Available: http://www.ars.usda.gov/SP2UserFiles/Place/80400530/pdf/0102/Table_1_BIA.pdf
3 U.S. Department of Agriculture, Department of Health and Human Services. 2015. Scientific Report of the 2015 Dietary Guidelines Advisory Committee: Appendix E-2.1: Usual Intake Distributions, 2007-2010, by Age/Gender Groups. Available: https://health.gov/dietaryguidelines/2015-binder/meeting2/docs/refMaterials/Usual_Intake_072013.pdf
4 U.S. Department of Agriculture, Agricultural Research Service. 2015. What We Eat in America Food Categories 2011-2012. Available: www.ars.usda.gov/nea/bhnrc/fsrg