# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information concerning the chemical identity of elemental zinc and zinc compounds is listed in Table 4-1.

Zinc is a naturally occurring element found in the earth=s surface rocks. Because of its reactivity, zinc metal is not found as the free element in nature. There are approximately 55 mineralized forms of zinc. The most important zinc minerals in the world are sphalerite (ZnS), smithsonite (ZnCO_3_), and hemimorphite (Zn_4_Si_2_O_7_(OH_2_)H_2_O). Zinc appears in Group IIB of the periodic table and has two common oxidation states, Zn(0) and Zn(+2). Zinc forms a variety of different compounds, such as zinc chloride, zinc oxide, and zinc sulfate (Goodwin 1998; Ohnesorge and Wilhelm 1991; WHO 2001).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of elemental zinc and zinc compounds is located in Table 4-2.

Zinc is a lustrous, blue-white metal that burns in air with a bluish-green flame. It is stable in dry air, but upon exposure to moist air, it becomes covered with a film of zinc oxide or basic carbonate (e.g., 2ZnCO_3_·3Zn(OH)_2_) isolating the underlying metal and retarding further corrosion. Bonding in zinc compounds tends to be covalent, as in the sulfide and oxide (Goodwin 1998). In solution, four to six ligands can be coordinated with the zinc ion. Zinc has a strong tendency to react with acidic, alkaline, and inorganic compounds. Since zinc is amphoteric (i.e., capable of reacting chemically either as an acid or a base), it also forms zincates (e.g., [Zn(OH)_3_H_2_O]- and [Zn(OH)_4_]^2−^) (Goodwin 1998; Ohnesorge and Wilhelm 1991; WHO 2001).

In humans and animals, zinc is an essential nutrient that plays a role in membrane stability, in over 300 enzymes, and in the metabolism of proteins and nucleic acids (WHO 2001).

Table 4-1 Chemical Identity of Zinc and Selected Compounds^a^

Characteristic | Zinc | Zinc acetate | Zinc chloride | Zinc chromate | Zinc cyanide | Zinc hydroxide | Zinc oxide | Zinc phosphate | Zinc sulfate | Zinc sulfide
Synonyms | Zinc dust; zinc powder | Acetic acid, zinc salt; acetic acid, zinc(II) salt; dicarbomethoxyzinc; octan zinecnaty [Czech]; zinc diacetate; zinc(II) acetate | Butter of zinc; chlorure de zinc (French); zinc (Chlorure de) (French); zinc butter; zinc chloride (ZnCl_2_); zinc dichloride; zinco (cloruro di) (Italian); zinkchlorid (German); zinkchloride (Dutch) | Basic zinc chromate; chromic acid, zinc salt(1:1); chromic acid, zinc salt; chromium zinc oxide; zinc chrome yellow; zinc chromate; zinc chromate AM; zinc chromate C; zinc chromate O; zinc chromate Z; zinc chromate(VI) hydroxide; zinc chrome; zinc chrome (anti-corrosion); zinc chromium oxide; zinc hydroxychromate; zinc tetraoxychromate | Cyanure de zinc (French); zinc dicyanide | Zinc dihydroxide | Zinc monoxide; zincum oxydatum; zinci oxydum; zinci oxicum; cynku tlenek (Polish) | Zinc ortho-phosphate; neutral zinc phosphate; tribasic zinc phosphate; trizinc diphosphate; zinc acid phosphate; zinc phosphate (3:2) | Sulfate de zinc (French); sulfuric acid zinc salt; sulfuric acid, zinc salt (1:1); white copperas; white vitriol; zinc sulfate; zinc vitriol; zinci sulfas; zincum sulfuricum | Wurtzite (alpha)^b^; sphalerite (beta)^b^; zinc monosulfide; zinc blende; zinc sulphide
Registered trade name(s) | Asarco; L 15; Blue powder; CI 77945; CI pigment Metal 6; Emanay zinc dust; Granular zinc; JASAD; Merrillite; PASCO | No data | Tinning flux (DOT)^b^; AI3-0440; Zintrace | Pigment yellow 36; buttercup yellow; zinc tetraoxychromate 76A; zinc tetraoxychromate 780B; zinc yellow; ZTO; zincro ZTO | No data | No data | Actox 14; Actox 16; Actox 216; AI3-00277; Akro-Zinc Bar85^b^; Amalox; Amaloz; Azo 22; Azodox; Blanc de Zinc; Cadox XX 78; Caswell No 920; Chinese White; CI 77947; CI Pigment White 4; Electrox 2500; Emanay Zinc Oxide; Emar; Felling Zinc Oxide; Flores de Zinci; Flowers of Zinc; GIAP 10; Green Seal-8; Hubbuck’s White; Kadox 15; Kadox-25; Kadox 72; Outmine; Ozide; Ozlo; Permanent White; Philosopher’s Wool; Powder Base 900; Protox 166; Protox 168; Protox 169; Protox Type 166; Protox Type 167; Protox Type 168; Protox Type 169; Protox Type 267; Protox Type 268; Red Seal; Red seal-9; Snow White; Unichem ZO; Vandem VAC; Vandem VOC; Vandem VPC; C-Weiss 8 (German); White Seal-7; XX 78; XX 203; XX 601; Zinca 20; Zinc White; Zincoid; Zn 0701T; Calamine^b^; Zincite^b^ | Bonderite 181; Bonderite 40; Bonderite 880; C.I. Pigment White 32; Delaphos; Delaphos 2M; Fleck’s Extraordinary; Fleck’s Extraordinary cement; Granodine 16NC; Granodine 80; Heucophos ZP 10; LF Bowsei PW 2; Man-Gill 51339; Man-Gill 51355; Microphos 90; Phoshinox PZ 06; Pigment White 32; Sicor ZNP/M; ZPF; Sicor ZNP/S; Virchem 931; Weather coat 1000; ZP-DL; ZP-SB | Bonazen^b^; Medizinc; Bufopto Zinc sulfate; Op-thal-zin; Optraex; Solvenzink; Verazinc; zincate; Zincomed; Zinkosite; AI3-03967; Orazinc; Zinc-200; Zinklet; Neozin; Optised; Prefrin-Z; Visine-AC; Zincfrin; Zink-Gro | Albalith; Irtran Z; Irtran 2; CI Pigment White 7; Sachtolith; Sachtolith HD-S; Cleartran
Chemical formula | Zn | Zn(C_2_H_3_O_2_)_2_ | ZnCl_2_ | ZnCrO_4_ | Zn(CN)_2_ | Zn(OH)_2_ | ZnO | Zn_3_(PO_4_)_2_ | ZnSO_4_^c^ | ZnS
Chemical structure | Zn | [image] | Cl-Zn-Cl | [image] | [image] | HO—Zn—OH | Zn=O | [image] | [image] | Zn=S
Identification numbers:
CAS registry | 7440-66-6 | 557-34-6 (anhydrous); 5970-45-6 (dihydrate) | 7646-85-7 | 13530-65-9 | 557-21-1 | 20427-58-1 | 1314-13-2 | 7779-90-0 | 7733-02-0 | 1314-98-3
NIOSH RTECS | ZG8600000 | AK1500000 (anhydrous); ZG8750000 (dihydrate) | ZH1400000 | GB3290000 | ZH1575000 | ZH3853000 | ZH4810000 | TD0590000 | ZH5260000 | ZH5400000
EPA hazardous waste | No data | No data | No data | No data | P121; an acute hazardous waste when a discarded commercial chemical product or manufacturing chemical intermediate or an off-specification commercial chemical product or a manufacturing chemical intermediate. D003; a waste containing zinc cyanide may (or may not) be characterized a hazardous waste following testing for the reactivity characteristics as prescribed by RCRA regulations | No data | No data | No data | No data | D003
OHM/TADS | 7216955 | No data | 7216957 | No data | No data | No data | No data | No data | 7216958 | No data
DOT/UN/NA/IMCO shipping | Zinc, powder or dust, UN 1436; zinc, powder or dust, zinc ashes, IMO4.3; zinc ashes, UN 1435 | Zinc acetate, environmental hazardous substance, solid, NOS, UN 3077 | Zinc chloride, anhydrous, UN 2331; zinc chloride, solution, UN 1840; zinc chloride, anhydrous, solution, IMO 8.3 | No data | Zinc cyanide, UN 1713; Zinc cyanide, IMO 6.1 | No data | No data | No data | NA 9161 | UN 3077; Zinc sulfide, environmentally hazardous substance, solid, NO; UN 3082; zinc sulfide, environmentally hazardous substance, liquid, NOS
HSDB | 1344 | 1043 | 1050 | 6188 | 1051 | No data | 5024 | No data | 1063 | 5802
NCI | No data | No data | No data | 77955 | No data | No data | No data | No data | No data | No data

a Unless otherwise specified, all data from Chemfinder 2003; ChemID 2003; HSDB 2003; NIOSH 1990; and RTECS 2003

b HSDB 1990

c O’Neil et al. 2001

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RCRA = Resource Conservation and Recovery Act; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Zinc and Selected Compounds^a^

Property | Zinc | Zinc acetate | Zinc chloride | Zinc chromate | Zinc cyanide | Zinc hydroxide | Zinc oxide | Zinc phosphate | Zinc sulfate | Zinc sulfide (α) | Zinc sulfide (γ)
Molecular weight | 65.38 | 183.48 | 136.29 | 181.37 | 117.42 | 99.40 | 81.38 | 386.11 | 161.44 | 97.45 | 97.45
Color | Bluish-white, lustrous | White granules | White granules^b^ | Lemon-yellow | White^c^ | Colorless^c^ | White/yellowish-white | White^c^ | Colorless^i^ | Colorless^i^ | Colorless
Physical state | Solid metal | Solid | Solid | Solid | Powder^c^ | Solid^c^ | Solid | Powder^c^ | Solid | Solid | Solid
Melting point | 419.5 °C | 237 °C (decomposes) | 290 °C | No data | 800 °C (decomposes)^c^ | Decomposes at 125 °C^c^ | 1975 °C | 900 °C^c^ | 680 °C (decomposes) | 1,700±20 °C | No data
Boiling point | 908 °C | No applicable | 732 °C | No data | Not applicable | Not applicable | Sublimes | No data | No applicable | 1,185 °C at 1 atm | 1,185 °C at 1 atm
Density (g/cm) | 7.14 at 25 °C | 1.735 | 2.907 at 25 °C | 3.40 | 1.852^c^ | 3.053^c^ | 5.607 at 20 °C | 3.998 at 15 °C^c^ | 3.54 at 25 °C | 3.98 at 20 °C^i^; 4.087 at 25 °C | 4.102 at 25 °C
Odor | No data | Faint acetous odor^c^ | Odorless; fume has acrid odor^c^ | Odorless | No data | No data | Odorless | Odorless | Not determined | No data | No data
Odor threshold:
Water | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Solubility:
Water | Insoluble^d^ | 4.0×10^4^ mg/L at 25 °C; 6.7×10^4^ mg/L at 100 °C^c^ | 4.32×10^6^ mg/L at 25 °C; 6.14×10^6^ mg/L at 100 °C | Insoluble in cold water; sparingly soluble | Insoluble^c^; 50 mg/L at 20 °C^c^ | Almost insoluble^c^ | 1.6 mg/L at 29 °C^i^ | Insoluble^j^ | Soluble in cold and hot water^j^; 4.19×10^5^ mg/L at 0 °C; 9.1×10^5^ mg/L at 70 °C | 6.9 mg/L at 18 °C^i^ | 6.5 mg/L at 18 °C^i^
Other solvent(s) | Soluble in acetic acid and alkali | 33 mg/L in alcohol | 1 g/1.3 mL alcohol; 1 g/2 mL glyderol; 1 g/0.25 mL 2% hydrochloroacetic acid | Soluble in acids, liquid ammonia; insoluble in acetone | Soluble in dilute mineral acids | No data | Soluble in dilute acetic or mineral acids, ammonia, ammonium carbonate, fixed alkali hydroxide solution, and ammonium chloride^i^; insoluble in alcohol^i^ | Soluble in dilute mineral acids, ammonium hydroxide and alkali hydroxide solutions; insoluble in alcohol | Slightly soluble in alcohol; soluble in methanol and glycerol^i^; 1 g/2.5 mL glycerol | Very soluble in alcohol; soluble in dilute mineral acids; insoluble in acetic acid; insoluble in alkalis | Very soluble in alcohol; soluble in dilute mineral acids; insoluble in alkalis
Partition coefficients:
K_d_ (mL/g) | 0.1–8,000^e^; 40 (average)^f^; 39 in sandy loam soil; 12.2 in sandy soil^g^ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
K_ow_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
K_oc_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Vapor pressure | 1 mm Hg at 487 °C | Not data | Not data | No data | No data | No data | Not data | No data | No data | No data | No data
Henry’s law constant | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | No data | Not applicable | Not applicable | Not applicable
Autoignition temperature | No data | No data | Not flammable^h^ | No data | No data | No data | Not flammable^h^ | No data | Not flammable^h^ | No data | No data
Flashpoint | No data | No data | Not flammable^h^ | No data | No data | No data | Not flammable^h^ | No data | Not flammable^h^ | No data | No data
Flammability limits | No data | No data | Not flammable^h^ | No data | No data | No data | Not flammable^h^ | No data | Not flammable^h^ | No data | No data
Conversion factor | Not applicable | mg Zn(C_2_H_3_O_2_)_2_ × 0.36 = mg Zn | mg ZnSO_4_ × 0.40 = mg Zn | mg ZnCrO_4_ × 0.36 = mg Zn | mg Zn(CN)_2_ × 0.56 = mg Zn | mg Zn(OH)_2_ × 0.66 = mg Zn | mg ZnO × 0.80 = mg Zn | mg Zn_3_(PO_4_)_2_ × 0.51 = mg Zn | mg ZnSO_4_ × 0.40 = mg Zn | mg ZnS × 0.67 = mg Zn | mg ZnS × 0.67 = mg Zn
Explosive limits | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data

a Information obtained from O’Neil et al. (2001) except where noted.

b ACGIH 1991

c Lewis 1997

d HSDB 2003

e Baes and Sharp 1983

f Baes et al. 1984

g Gerritse et al. 1982

h Weiss 1986

i Weast 1988

j Goodwin 1998

Zn = zinc; Zn(C_2_H_3_O_2_)_2_ = zinc acetate; ZnCl_2_ = zinc chloride; ZnCrO_4_ = zinc chromate; Zn(CN)_2_ = zinc cyanide; Zn(OH)_2_ = zinc hydroxide; ZnO = zinc oxide; Zn_3_(PO_4_)_2_ = zinc phosphate; ZnS = zinc sulfide; ZnSO_4_ = zinc sulfate