# 1 PUBLIC HEALTH STATEMENT

This public health statement tells you about zinc and the effects of exposure to it. Zinc is an essential element needed by your body and is commonly found in nutritional supplements. However, taking too much zinc into the body can affect your health.

The Environmental Protection Agency (EPA) identifies the most serious hazardous waste sites in the nation. These sites are then placed on the National Priorities List (NPL) and are targeted for long-term federal clean-up activities. Zinc has been found in at least 985 of the 1,662 current or former NPL sites. Although the total number of NPL sites evaluated for zinc is not known, the possibility exists that the number of sites at which zinc is found may increase in the future as more sites are evaluated. This information is important because these sites may be sources of exposure and exposure to zinc may harm you.

When a substance is released either from a large area, such as an industrial plant, or from a container, such as a drum or bottle, it enters the environment. Such a release does not always lead to exposure. You can be exposed to a substance only when you come in contact with it. You may be exposed by breathing, eating, or drinking the substance, or by skin contact.

If you are exposed to zinc, many factors will determine whether you will be harmed. These factors include the dose (how much), the duration (how long), and how you come in contact with it. You must also consider any other chemicals you are exposed to and your age, sex, diet, family traits, lifestyle, and state of health.

## 1.1 WHAT IS ZINC?

Zinc is one of the most common elements in the Earth's crust. Zinc is found in the air, soil, and water and is present in all foods. In its pure elemental (or metallic) form, zinc is a bluish-white, shiny metal. Powdered zinc is explosive and may burst into flames if stored in damp places. Metallic zinc has many uses in industry. A common use for zinc is to coat steel and iron as well as other metals to prevent rust and corrosion; this process is called galvanization. Metallic zinc is also mixed with other metals to form alloys such as brass and bronze. A zinc and copper alloy is used to make pennies in the United States. Metallic zinc is also used to make dry cell batteries.

Zinc can also combine with other elements, such as chlorine, oxygen, and sulfur, to form zinc compounds. Zinc compounds that may be found at hazardous waste sites are zinc chloride, zinc oxide, zinc sulfate, and zinc sulfide. Most zinc ore found naturally in the environment is in the form of zinc sulfide. Zinc compounds are widely used in industry. Zinc sulfide and zinc oxide are used to make white paints, ceramics, and other products. Zinc oxide is also used in producing rubber. Zinc compounds, such as zinc acetate, zinc chloride, and zinc sulfate, are used in preserving wood and in manufacturing and dyeing fabrics. Zinc chloride is also the major ingredient in smoke from smoke bombs. Zinc compounds are used by the drug industry as ingredients in some common products, such as vitamin supplements, sun blocks, diaper rash ointments, deodorants, athlete's foot preparations, acne and poison ivy preparations, and antidandruff shampoos. Information can be found on the chemical and physical properties of zinc in Chapter 4 and on its occurrence and fate in the environment in Chapter 6.

## 1.2 WHAT HAPPENS TO ZINC WHEN IT ENTERS THE ENVIRONMENT?

Zinc enters the air, water, and soil as a result of both natural processes and human activities. Most zinc enters the environment as the result of mining, purifying of zinc, lead, and cadmium ores, steel production, coal burning, and burning of wastes. These activities can increase zinc levels in the atmosphere. Waste streams from zinc and other metal manufacturing and zinc chemical industries, domestic waste water, and run-off from soil containing zinc can discharge zinc into waterways. The level of zinc in soil increases mainly from disposal of zinc wastes from metal manufacturing industries and coal ash from electric utilities. Sludge and fertilizer also contribute to increased levels of zinc in the soil. In air, zinc is present mostly as fine dust particles. This dust eventually settles over land and water. Rain and snow aid in removing zinc from air. Most of the zinc in lakes or rivers settles on the bottom. However, a small amount may remain either dissolved in water or as fine suspended particles. The level of dissolved zinc in water may increase as the acidity of water increases. Fish can collect zinc in their bodies from the water they swim in and from the food they eat. Most of the zinc in soil is bound to the soil and does not dissolve in water. However, depending on the type of soil, some zinc may reach groundwater, and contamination of groundwater has occurred from hazardous waste sites. Zinc may be taken up by animals eating soil or drinking water containing zinc. Zinc is also a trace mineral nutrient and as such, small amounts of zinc are needed in all animals. For more information about what happens to zinc in the environment, see Chapter 6.

## 1.3 HOW MIGHT I BE EXPOSED TO ZINC?

Zinc is an essential element needed by your body in small amounts. We are exposed to zinc compounds in food. The average daily zinc intake through the diet in this country ranges from 5.2 to 16.2 milligrams (milligram=0.001 gram). Food may contain levels of zinc ranging from approximately 2 parts of zinc per million (2 ppm) parts of foods (e.g., leafy vegetables) to 29 ppm (meats, fish, poultry). Zinc is also present in most drinking water. Drinking water or other beverages may contain high levels of zinc if they are stored in metal containers or flow through pipes that have been coated with zinc to resist rust. If you take more than the recommended daily amount of supplements containing zinc, you may have higher levels of zinc exposure.

In general, levels of zinc in air are relatively low and fairly constant. Average levels of zinc in the air throughout the United States are less than 1 microgram of zinc per cubic meter (μg/m^3^) of air, but range from 0.1 to 1.7 μg/m^3^ in areas near cities. Air near industrial areas may have higher levels of zinc. The average zinc concentration for a 1-year period was 5 μg/m^3^ in one area near an industrial source.

In addition to background exposure that all of us experience, about 150,000 people also have a source of occupational exposure to zinc that might elevate their total exposure significantly above the average background exposure. Jobs where people are exposed to zinc include zinc mining, smelting, and welding; manufacture of brass, bronze, or other zinc-containing alloys; manufacture of galvanized metals; and manufacture of machine parts, rubber, paint, linoleum, oilcloths, batteries, some kinds of glass and ceramics, and dyes. People at construction jobs, automobile mechanics, and painters are also exposed to zinc. For more information on exposure to zinc, see Chapter 6.

## 1.4 HOW CAN ZINC ENTER AND LEAVE MY BODY?

Zinc can enter the body through the digestive tract when you eat food or drink water containing it. Zinc can also enter through your lungs if you inhale zinc dust or fumes from zinc-smelting or zinc-welding operations on your job. The amount of zinc that passes directly through the skin is relatively small. The most likely route of exposure near NPL waste sites is through drinking water containing a high amount of zinc. Zinc is stored throughout the body. Zinc increases in blood and bone most rapidly after exposure. Zinc may stay in the bone for many days after exposure. Normally, zinc leaves the body in urine and feces. More information on how zinc enters and leaves your body can be found in Chapter 3.

## 1.5 HOW CAN ZINC AFFECT MY HEALTH?

Scientists use many tests to protect the public from harmful effects of toxic chemicals and to find ways for treating persons who have been harmed.

One way to learn whether a chemical will harm people is to determine how the body absorbs, uses, and releases the chemical. For some chemicals, animal testing may be necessary. Animal testing may also help identify health effects such as cancer or birth defects. Without laboratory animals, scientists would lose a basic method for getting information needed to make wise decisions that protect public health. Scientists have the responsibility to treat research animals with care and compassion. Scientists must comply with strict animal care guidelines because laws today protect the welfare of research animals.

Inhaling large amounts of zinc (as zinc dust or fumes from smelting or welding) can cause a specific short-term disease called metal fume fever, which is generally reversible once exposure to zinc ceases. However, very little is known about the long-term effects of breathing zinc dust or fumes.

Taking too much zinc into the body through food, water, or dietary supplements can also affect health. The levels of zinc that produce adverse health effects are much higher than the Recommended Dietary Allowances (RDAs) for zinc of 11 mg/day for men and 8 mg/day for women. If large doses of zinc (10–15 times higher than the RDA) are taken by mouth even for a short time, stomach cramps, nausea, and vomiting may occur. Ingesting high levels of zinc for several months may cause anemia, damage the pancreas, and decrease levels of high-density lipoprotein (HDL) cholesterol.

Eating food containing very large amounts of zinc (1,000 times higher than the RDA) for several months caused many health effects in rats, mice, and ferrets, including anemia and injury to the pancreas and kidney. Rats that ate very large amounts of zinc became infertile. Rats that ate very large amounts of zinc after becoming pregnant had smaller babies. Putting low levels of certain zinc compounds, such as zinc acetate and zinc chloride, on the skin of rabbits, guinea pigs, and mice caused skin irritation. Skin irritation from exposure to these chemicals would probably occur in humans. EPA has determined that because of lack of information, zinc is not classifiable as to its human carcinogenicity.

Consuming too little zinc is at least as important a health problem as consuming too much zinc. Without enough zinc in the diet, people may experience loss of appetite, decreased sense of taste and smell, decreased immune function, slow wound healing, and skin sores. Too little zinc in the diet may also cause poorly developed sex organs and retarded growth in young men. If a pregnant woman does not get enough zinc, her babies may have birth defects.

More information on the health effects linked with exposure to higher-than-normal levels of zinc is presented in Chapter 3.

## 1.6 HOW CAN ZINC AFFECT CHILDREN?

This section discusses potential health effects in humans from exposures during the period from conception to maturity at 18 years of age.

Zinc is essential for proper growth and development of young children. Mothers who did not eat enough zinc during pregnancy had a higher frequency of birth defects and gave birth to smaller children (lower birth weight) than mothers whose zinc levels were sufficient. Very young children who did not receive enough zinc in the diet were smaller, both in length and in body weight, than children who ate enough zinc. Some foods, such as soy-based formulas, contain high levels of phytate, which can result in a decreased absorption of zinc in the diet. Too much of these foods may result in effects similar to those that occur when children receive too little zinc in the diet.

Little is known about whether children who eat too much zinc will react differently from adults who have ingested large amounts of zinc. A child who accidentally drank a large amount of a caustic zinc solution was found to have damage to his mouth and stomach, and later to his pancreas, but similar effects have been seen in adults who accidentally drank the same solution.

## 1.7 HOW CAN FAMILIES REDUCE THE RISK OF EXPOSURE TO ZINC

If your doctor finds that you have been exposed to substantial amounts of zinc, ask whether your children might also have been exposed. Your doctor might need to ask your state health department to investigate.

Children living near waste sites containing zinc are likely to be exposed to higher environmental levels of zinc through breathing, drinking contaminated drinking water, touching soil, and eating contaminated soil. It is unlikely that a child would ingest enough zinc from eating soil to cause harmful effects. However, parents should supervise to see that children avoid eating soil and wash their hands frequently, especially before eating. Parents should consult their family physicians about whether (and how) hand-to-mouth behaviors in their children might be discouraged. A more complete discussion can be found in Section 3.11 of the profile.

Children and adults require a certain amount of zinc in the diet in order to remain healthy. However, overuse of some medicines or vitamin supplements containing zinc might be harmful; these medicines should always be used appropriately. If you are accidentally exposed to large amounts of zinc, consult a physician immediately.

## 1.8 IS THERE A MEDICAL TEST TO DETERMINE WHETHER I HAVE BEEN EXPOSED TO ZINC?

Medical tests can determine whether your body fluids contain high levels of zinc. Samples of blood or feces can be collected in a doctor's office and sent to a laboratory that can measure zinc levels. It is easier for most laboratories to measure zinc in blood than in feces. The presence of high levels of zinc in the feces can mean recent high zinc exposure. High levels of zinc in the blood can mean high zinc consumption and/or high exposure. High zinc levels in blood or feces reflect the level of exposure to zinc. Measuring zinc levels in urine and saliva also may provide information about zinc exposure. Tests to measure zinc in hair may provide information on long-term zinc exposure; however, no useful correlation has been found between hair zinc levels and zinc exposure and these tests are not routinely used. Since zinc levels can be affected by dietary deficiency and cell stress, these results may not be directly related to current zinc exposure. More information on tests to measure zinc in the body can be found in Chapter 7.

## 1.9 WHAT RECOMMENDATIONS HAS THE FEDERAL GOVERNMENT MADE TO PROTECT HUMAN HEALTH?

The federal government develops regulations and recommendations to protect public health. Regulations can be enforced by law. The EPA, the Occupational Safety and Health Administration (OSHA), and the Food and Drug Administration (FDA) are some federal agencies that develop regulations for toxic substances. Recommendations provide valuable guidelines to protect public health, but cannot be enforced by law. The Agency for Toxic Substances and Disease Registry (ATSDR) and the National Institute for Occupational Safety and Health (NIOSH) are two federal organizations that develop recommendations for toxic substances.

Regulations and recommendations can be expressed as “not-to-exceed” levels, that is, levels of a toxic substance in air, water, soil, or food that do not exceed a critical value that is usually based on levels that affect animals; they are then adjusted to levels that will help protect humans. Sometimes these not-to-exceed levels differ among federal organizations because they used different exposure times (an 8-hour workday or a 24-hour day), different animal studies, or other factors.

Recommendations and regulations are also updated periodically as more information becomes available. For the most current information, check with the federal agency or organization that provides it. Some regulations and recommendations for zinc include the following:

The federal government has set standards and guidelines to protect individuals from the potential health effects of excessive zinc. EPA has stated that drinking water should contain no more than 5 mg of zinc per liter of water (5 mg/L or 5 ppm) because of taste. Furthermore, any release of more than 1,000 pounds (or in some cases 5,000 pounds) of zinc or its compounds into the environment (i.e., water, soil, or air) must be reported to EPA.

The National Academy of Sciences (NAS) estimates an RDA for zinc of 11 mg/day (men). Eleven mg/day is the same as 0.16 mg per kilogram (kg) of body weight per day for an average adult male (70 kg). An RDA of 8 mg/day, or 0.13 mg per kg of body weight for an average adult female (60 kg), was established for women because they usually weigh less than men. Lower zinc intake was recommended for infants (2–3 mg/day) and children (5–9 mg/day) because of their lower average body weights. The RDA provides a level of adequate nutritional status for most of the population. Extra dietary levels of zinc are recommended for women during pregnancy and lactation. An RDA of 11–12 mg/day was set for pregnant women. Women who nurse their babies need 12–13 mg/day.

To protect workers, OSHA has set an average legal limit of 1 mg/m^3^ for zinc chloride fumes and 5 mg/m^3^ for zinc oxide (dusts and fumes) in workplace air during an 8-hour workday, 40-hour work week. This regulation means that the workroom air should contain no more than an average of 1 mg/m^3^ of zinc chloride over an 8-hour working shift of a 40-hour work week. NIOSH similarly recommends that the level of zinc oxide in workplace air should not exceed an average of 1 mg/m^3^ over a 10-hour period of a 40-hour work week. For more information on recommendations and standards for zinc exposure, see Chapter 8.

## 1.10 WHERE CAN I GET MORE INFORMATION?

If you have any more questions or concerns, please contact your community or state health or environmental quality department, or contact ATSDR at the address and phone number below.

ATSDR can also tell you the location of occupational and environmental health clinics. These clinics specialize in recognizing, evaluating, and treating illnesses that result from exposure to hazardous substances.

Toxicological profiles are also available on-line at www.atsdr.cdc.gov and on CD-ROM. You may request a copy of the ATSDR ToxProfiles^™^ CD-ROM by calling the toll-free information and technical assistance number at 1-888-42ATSDR (1-888-422-8737), by e-mail at atsdric@cdc.gov, or by writing to:

- Agency for Toxic Substances and Disease Registry
  Division of Toxicology
  1600 Clifton Road NE
  Mailstop F-32
  Atlanta, GA 30333
  Fax: 1-770-488-4178

Organizations for-profit may request copies of final Toxicological Profiles from the following:

- National Technical Information Service (NTIS)
  5285 Port Royal Road
  Springfield, VA 22161
  Phone: 1-800-553-6847 or 1-703-605-6000
  Web site: http://www.ntis.gov/