# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Zinc and compounds
CAS number:
Date: | May 6, 2005
Profile status: | Final Draft Post-Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 25
Species: | Human
MRL: | 0.3 [X] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Yadrick MK, Kenney MA, Winterfelt EA. 1989. Iron, copper, and zinc status: Response to supplementation with zinc or zinc and iron in adult females. Am J Clin Nutr 49:145–150.2912000

[underlined: Experimental design]: Eighteen healthy women, ages 25–40 years, were given zinc gluconate supplements twice daily (50 mg supplemental zinc/day, or 0.83 mg supplemental zinc/kg/day assuming a 60-kg mean body weight for healthy women) for a 10-week period (Yadrick et al. 1989). Blood was drawn from each subject prior to treatment for use as a referent. Erythrocyte superoxide dismutase (ESOD) activity declined over the 10-week supplementation period and, at 10 weeks, was significantly (p<0.05) lower (47% decrease) than pretreatment values; a decrease at 6 weeks of exposure (15%) was not statistically significant. ESOD levels are considered to be a sensitive indicator of systemic copper status. Ceruloplasmin levels were not altered. Serum zinc was significantly increased at both 6 and 10 weeks. There was also a significant decline in serum ferritin (23%) and hematocrit (4%) values at 10 weeks. In women similarly-exposed but also receiving 0.42 mg supplemental iron/day, serum ferritin was increased at both 6 and 10 weeks of exposure, while serum ESOD levels were significantly decreased at 6 weeks (24%) and 10 weeks (47%).

[underlined: Effects noted in study and corresponding doses]: Statistically significant decreases in erythrocyte SOD and serum ferritin levels at 0.83 mg supplemental zinc/kg/day. Since these effects were subclinical, they were designated as non-adverse, as described below.

[underlined: Dose end point used for MRL derivation]: Yadrick et al. (1989) reported a significant decrease in ESOD, which is considered to be a sensitive indicator of body copper status, in women exposed to 50 mg supplemental zinc/day. Because the observed effect is considered to be a precursor event to the more severe symptoms seen with zinc-induced copper deficiency, rather than a toxic effect of itself, the 50 mg supplemental zinc/day value is considered to be NOAEL. At the same exposure level, serum ferritin levels decreased from 36.6 to 28.2 μg/L (23% decrease), which was statistically significant. According to the most recent NHANES data (cited in IOM 2000), the median range for serum ferritin levels in menstruating women is 36–40 μg/L, while a value of <12 μg/L represents depleted iron stores. Thus, the subjects dropped below the median range for women of their age group, but were still considerably above the level that would represent a depletion of iron stores; in the absence of other effects indicating changes in iron status, this subclinical effect was also designated as a NOAEL. Assuming a reference female body weight of 60 kg, this represents 0.83 mg zinc/kg/day.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation]:

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [X] 3 [ ] 10 (for human variability)

[underlined: The intermediate oral MRL for zinc is derived as follows]:

- MRL = NOAEL÷ UF
- MRL = 0.83 mg zinc/kg/day ÷ 3
- MRL = 0.3 mg zinc/kg/day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: Was a conversion used from intermittent to continuous exposure? If so, explain:] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

It should be noted that the MRL is calculated based on the assumption of healthy dietary levels of zinc (and copper), and represents the level of exposure above and beyond the normal diet that is believed to be without an appreciable risk of toxic response.

Fischer et al. (1984) gave groups of 13 healthy adult male volunteers (ages not specified) 0 (cornstarch) or 25 mg supplemental zinc (as zinc gluconate) twice daily for 6 weeks (0 or 0.71 mg supplemental zinc/kg/day). Nonfasting blood samples were taken at the beginning and at biweekly intervals and tested for measures of copper status. ESOD activity decreased after 4 weeks in the supplement group and was significantly lower than controls by 6 weeks. An inverse correlation between plasma zinc levels and erythrocyte superoxide dismutase activity was also observed at 6 weeks. Plasma copper levels and levels of ferroxidase activity did not change during the course of the study.

Groups (n=10–13) of postmenopausal women (mean age 64.9±6.7 years) with an average body weight of 65.1±9.5 kg were evaluated for the effects of excess zinc exposure (Davis et al. 2000; Milne et al., 2001). After an initial equilibration period during which they received 2 mg Cu and 9 mg zinc/day (the RDA for women of that age is 8 mg zinc/day) for 10 days, subjects received either low (1 mg) or high (3 mg) copper diets, and either low (3 mg) or high (56 mg) zinc for 90 days; it is noteworthy that the “low copper” subjects were still receiving copper levels greater than the current RDA for copper. After a 10-day equilibration period, the study was repeated with the same copper level in the diet, such that each subject received both low and high zinc throughout the course of the study. Blood was drawn during each equilibration period, and twice monthly during the exposure periods. Levels during the equilibration periods were used as the referent for the exposure periods. Zinc supplementation resulted in significant increases in plasma and platelet zinc levels. In high-zinc subjects, increases were seen in bone-specific alkaline phosphatase levels (~25%) and extracellular superoxide dismutase (~15%), while significant decreases were seen in mononuclear white cell 5'-nucleotidase (~30%) and plasma 5'-nucleotidase activity (~36%). Slight (<10%) changes were also seen in erythrocyte copper/zinc SOD and plasma free thyroxine. Other evaluated end points were not significantly modified by zinc supplementation. Copper status indicators were decreased by supplementation with zinc, including copper balance (total intake-total eliminated in urine and feces), serum-immunoreactive ceruloplasmin, platelet cytochrome-c oxidase activity, total cholesterol, glutathione, and glutathione peroxidase activity. No effect was seen on concentration of zinc in red blood cells or on indicators of iron status.

Groups of 9, 13, or 9 healthy white men were administered 0, 50, or 75 mg/day supplemental zinc as zinc gluconate (total zinc intakes were 0.16, 0.85, and 1.10 mg supplemental zinc/kg/day, respectively, based on mean group body weights) for 12 weeks (Black et al. 1988). The subjects were given instructions to avoid foods high in calcium, fiber, and phytic acid, dietary constituents that are known to decrease zinc absorption. Subjects were also told to restrict their intake of zinc-rich foods in order to minimize the variation in daily dietary zinc. There was a general decline in the mean serum HDL-cholesterol for the 75-mg supplement group between weeks 6 and 12. HDL values for this group were significantly lower than those for the placebo group at weeks 6 and 12 (p<0.05). There was also a decline in the HDL values for the 50-mg group between weeks 8 through 12; however, this decline was not significantly different from that for the controls until the 12th week of treatment. Serum zinc, copper, total cholesterol, LDL-cholesterol, and triglycerides did not appear to be affected by treatment.

Freeland-Graves et al. (1982) exposed groups of eight healthy women to 0, 15, 50, or 100 mg supplemental zinc as zinc acetate (approximately 0, 0.25, 0.83, or 1.7 mg supplemental zinc/kg/day, assuming a reference female body weight of 60 kg) daily for 60 days. In the highest exposure group only, plasma HDL-cholesterol was significantly reduced at 4 weeks of exposure, but not at any other timepoint examined. A correlation between dietary zinc and whole-blood copper was observed in treated subjects. In the 50 and 100 mg groups, some bloating, nausea, and abdominal cramps were reported unless the supplement was taken with a large glass of water at mealtime.

Prasad et al. (1978) fed a patient with sickle cell anemia supplements of 150–200 mg supplemental zinc/day for 2 years. The supplement resulted in copper deficiency; serum copper and plasma ceruloplasmin levels were decreased. When copper was administered, the plasma ceruloplasmin levels became normal. In a follow-up study, of 13 patients on zinc therapy (similar treatment levels assumed), 7 patients had ceruloplasmin levels at the lower limit of normal after 24 weeks of dosing.

[underlined: Agency Contact (Chemical Managers)]: Nickolette Roney, M.S.; Cassandra V. Smith, M.S.; Malcolm Williams, D.V.M., Ph.D.