# 9 REFERENCES

*Not cited in text

Abdel-Rahman MS, Skowronski GA, Turkall RM. 1993. A comparative study of the kinetic and bioavailability of pure and soil-adsorbed benzene, toluene, and m-xylene after dermal exposure. In: Wang RGM, Knaak JB, Maibach HI, eds. Health risk assessment: Dermal and inhalation exposure and absorption of toxicants. Boca Raton: CRC Press, 105–116.
Abdul AS, Gibson TL, Rai DN. 1987. Statistical correlations for predicting the partition coefficient for nonpolar organic contaminants between aquifer organic carbon and water. Hazard Waste Hazard Mater 4:211–222.
Abu Al Ragheb S, Salhab AS, Amr SS. 1986. Suicide by xylene ingestion: A case report and review of literature. Am J Forensic Med Pathol 7(4):327–329.3799567
ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. Cincinnati, OH: American Conference of Government Industrial Hygenists Inc., 109–110.
ACGIH. 2004. Xylene. In: Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adams JC, Dills RL, Morgan MS, . 2005. A physiologically based toxicokinetic model of inhalation exposure to xylenes in Caucasian men. Regul Toxicol Pharmacol 43(2):203–214.16169135
Adey WH, Luckett C, Smith M. 1996. Purification of industrially contaminated groundwaters using controlled ecosystems. Ecolog Eng 7:191–212.
Adgate JL, Church TR, Ryan AD, . 2004b. Outdoor, indoor and personal exposure to VOCs in children. Environ Health Perspect 112(14):1386–1392.15471730
Adgate JL, Eberly LE, Stroebel C, . 2004a. Personal, indoor, and outdoor VOC exposures in a probability sample of children. J Expo Anal Environ Epidemiol 14:S4–S13.15118740
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 2005. Toxicological profile for benzene. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Ahaghotu E, Babu RJ, Chaterjee A, . 2005. Effect of methyl substitution of benzene in the percutaneous absorption and skin irritation in hairless rats. Toxicol Lett 159(3):261–271.16087301
*AIChE. 1996. m-, o-, p-Xylenes. C8H10. In: Physical and thermodynamic properties of pure chemicals. American Institute of Chemical Engineers, Design Institute for Physical Property Data. Philadelphia, PA: Taylor and Francis.
Al-Ghamdi SS, Raftery MJ, Yaqoob MM. 2003a. Acute solvent exposure induced activation of cytochrome P4502E1 causes proximal tubular cell necrosis by oxidative stress. Toxicol in Vitro 17:335–341.12781212
Al-Ghamdi SS, Raftery MJ, Yaqoob MM. 2003b. Organic solvent-induced proximal tubular cell toxicity via caspase-3 activation. J Toxicol Clin Toxicol 41(7):941–945.14705839
Al-Ghamdi SS, Raftery MJ, Yaqoob MM. 2004. Organic solvent-induced proximal tubular cell apoptosis via caspase-9 activation. Environ Toxicol Pharmacol 16:147–152.21782701
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amin TA, Narang RS. 1985. Determination of volatile organics in sediment at nanogram-per-gram concentrations by gas chromatography. Anal Chem 57:648–651.
Amoozegar A, Warrick AW, Fuller WH. 1986. Movement of selected organic liquids into dry soils. Hazard Waste Hazard Mater 3(1):29–41.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson BE, Zeiger E, Shelby MD, . 1990. Chromosome aberration and sister chromatid exchange test results with 42 chemicals. Environ Mol Mutagen 16(18):55–137.2091924
Anderson C, Sundberg K, Groth O. 1986. Animal model for assessment of skin irritancy. Contact Dermatitis 15:143–151.3780215
Anderson TA, Beuchamp JJ, Walton BT. 1991. Organic chemicals in the environment: Fate of volatile and semivolatile organic chemicals in soils: Abiotic versus biotic losses. J Environ Qual 20:420–424.
Andersson K, Fuxe K, Nilsen OG, . 1981. Production of discrete changes in dopamine and noradrenaline levels and turnover in various parts of the rat brain following exposure to xylene, ortho-, meta-, and para-xylene, and ethylbenzene. Toxicol Appl Pharmacol 60:535–548.7292492
Ansari EA. 1997. Ocular injury with xylene-a report of two cases. Hum Exp Toxicol 16:273–275.9192207
Antoine SR, Deleon IR, Ildefonso R, . 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
APHA. 1992. Standard methods for the examination of water and wastewater. 18th ed. Greenberg AE, Clesceri LS, Eaton AD, eds. Washington, DC: American Public Health Association, American Water Works Association, Water Environment Federation, 6-26–6-36, 6-42–6-46, 6-55–6-57.
API. 1994. A study to characterize air concentrations of methyl tertiary butyl ether (MTBE) at service stations in the Northeast. Washington, DC: American Petroleum Institute.
API. 1995. Service station personnel exposures to oxygenated fuel components - 1994. Washington, DC: American Petroleum Institute.
Arp EW Jr, Wolf PH, Chekoway H. 1983. Lymphocytic leukemia and exposures to benzene and other solvents in the rubber industry. J Occup Med 25:598–602.6886869
Arthur LJ, Curnock DA. 1982. Xylene-induced epilepsy following innocent glue sniffing. Br Med J 284:1787.6805706
Arthur CL, Killam LM, Motlagh S, . 1992. Analysis of substituted benzene compounds in groundwater using solid-phase microextraction. Environ Sci and Technol 26:979–983.
Ashley DL, Bonin MA, Cardinali FL, . 1994. Blood concentrations of volatile organic compounds in a nonoccupationally exposed US population and in groups with suspected exposure. Clin Chem 40(7):1401–1404.8013127
Ashley DL, Bonin MA, Cardinali FL, . 1992. Determining volatile organic compounds in human blood from a large sample production by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
Ashley DL, Bonin MA, Hamar B, . 1995. Removing the smoking confounder from blood volatile organic compound measurements. Environ Res 71:39–45.8757237
Ashley DL, Bonin MA, Cardinali FL, . 1996. Measurement of volatile organic compounds in human blood. Environ Health Perspect 104:871–877.8933028
Askergren A. 1981. Studies on kidney function in subjects exposed to organic solvents: III. Excretion of cells in the urine. Acta Med Scand 210:103–106.7293819
Askergren A. 1982. Organic solvents and kidney function. In: Englund A, Ringen K, Mehlman MY, eds. Advances in modern environmental toxicology: Occupational health hazards of solvents. 2nd ed. Princeton Scientific Publishers Inc., 157–172.
*Askergren A, Allgen L-G, Bergstrom J. 1981a. Studies on kidney function in subjects exposed to organic solvents: II. The effect of desmopressin in a concentration test and the effect of exposure to organic solvents on renal concentrating ability. Acta Med Scand 209:485–488.7257866
Askergren A, Allgen L-G, Karlsson C, . 1981b. Studies on kidney function in subjects exposed to organic solvents: I. Excretion of albumin and beta-2-microglobulin in the urine. Acta Med Scand 209:479–483.6167143
Askergren A, Brandt R, Gullquist R, . 1981c. Studies on kidney function in subjects exposed to organic solvents: IV. Effect on 51-Cr-EDTA clearance. Acta Med Scand 210:373–376.6801928
Assmuth T, Kalevi K. 1992. Concentrations and toxicological significance of trace organic compounds in municipal solid waste landfill gas. Chemosphere 24(9):1207–1216.
Astier A. 1992. Simultaneous high-performance liquid chromatographic determination of urinary metabolites of benzene, nitrobenzene, toluene, xylene and styrene. J Chromatogr 573:318–322.1601967
Astrand I. 1982. Work load and uptake of solvents in tissues of man. In: Mehlman MA, ed. Advances in modern environmental toxicology. Vol. 2. Princeton Junction, NJ: Senate Press, 141–152.
Astrand I, Engstrom J, Ovrum P. 1978. Exposure to xylene and ethylbenzene: I. Uptake, distribution and elimination in man. Scand J Work Environ Health 4:185–194.705285
Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. J Phys Chem Ref Data 1:227–228.
Atkinson R. 1990. Gas-phase tropospheric chemistry of organic compounds: A review. Atmos Environ 24A:1–41.
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470.
Atkinson R, Aschmann SM, Arey J. 1991. Formation of ring-retaining products from the OH radical-initiated reactions of o-, m-, and p-xylene. Int J Chem Kinet 23:77–97.
Atkinson R, Aschmann SM, Fitz DR, . 1982. Rate constants for the gas-phase reactions of O3 with selected organics at 296 K. Int J of Chem Kinet 14:13–18.
Atkinson R, Carter WPL, Plum CN, . 1984. Kinetics of the gas-phase reactions of NO3 radicals with a series of aromatics at 296 +/− 2K. Int J Chem Kinet 16:887–898.
Aurelius MW, Brown KW. 1987. Fate of spilled xylene as influenced by soil moisture content. Water Air Soil Pollut 36:23–31.
Austern BM, Dobbs RA, Cohen JM. 1975. Gas chromatographic determination of selected organic compounds added to wastewater. Environ Sci and Technol 9:588–590.
Backes WL, Sequeira DJ, Cawley GF, . 1993. Relationship between hydrocarbon structure and induction of P450: Effects on protein levels and enzyme activities. Xenobiotica 23(12):1353–1366.8135039
Bakke OM, Scheline RR. 1970. Hydroxylation of aromatic hydrocarbons in the rat. Toxicol Appl Pharmacol 16:691–700.5422210
Balogh S, Onayiga R, Edblad D. 1998. Evaluation of an automatic composite sampler for volatile organic compounds in raw wastewater. J Air Waste Manage Assoc 48:271–275.
Balogh T, Tatrai E, Barczai G, . 1982. [Study of the embryotoxic effect of xylene mixtures.] Egeszsegtudomany 26:42–48. (Hungarian)
Bandow H, Washida N. 1985. Ring-cleavage reactions of aromatic hydrocarbons studied by FT-IR spectroscopy: II. Photooxidation of o-, m-, and p-xylenes in the NO_x_-air system. Bull Chem Soc Jpn 58:2541–2548.
Barbee GC, Brown KW. 1986. Movement of xylene through unsaturated soils following simulated spills. Water Air Soil Pollut 29:321–331.
Barker JF. 1987. Volatile aromatic and chlorinated organic contaminants in groundwater at six Ontario landfills. Water Pollut Res J Canada 22:33–48.
Barlow SM, Sullivan FM. 1982. Reproductive hazards of industrial chemicals: An evaluation of animal and human data. London: Academic Press, 1–42.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bellanca JA, Davis PL, Donnelly B, . 1982. Detection and quantitation of multiple volatile compounds in tissues by GC and GC/MS. J Anal Toxicol 6:238–240.7176553
Beller HR. 2000. Metabolic indicators for detecting in situ anaerobic alkylbenzene degradation. Biodegradation 11:125–139.11440240
Beller HR, Ding WH, Reinhard M. 1995. Byproducts of anaerobic alkylbenzene metabolism useful as indicators of in situ bioremediation. Environ Sci Technol 29:2864–2870.22206536
Berenblum I. 1941. The cocarcinogenic action of croton resin. Cancer Res 1:44–48.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Bergert KD, Nestler K. 1991. Solvent uptake in relation to physical activity. Sci Total Environ 101:111–119.2057759
Bergman K. 1983. Application and results of whole-body autoradiography in distribution studies of organic solvents. CRC Crit Rev Toxicol 12(1):59–118.
*Bernard AM, de Russis R, Normand JC, . 1989. Evaluation of the subacute nephrotoxicity of cyclohexane and other industrial solvents in the female Sprague-Dawley rat. Toxicol Lett 45(2–3):271–280.2645690
*Bernardelli BC, Gennari MC. 1987. Death caused by ingestion of endosulfan. J Forensic Sci 32:1109–1112.3612067
Bieniek G, Wilczok T. 1981. Thin-layer chromatography of hippuric and m-methylhippuric acid in urine after mixed exposure to toluene and xylene. Br J Ind Med 38:304–306.7272246
Bio/dynamics Inc. 1983. Parental and fetal reproduction toxicity study in rats with mixed xylenes. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. FYI00002091.
Blanchard KT, Morris JB. 1994. Effects of m-xylene on rat nasal cytochrome P-450 mixed function oxidase activity. Toxicol Lett 70:253–259.8296328
*Bleeker ML, Bolla KI, Agnew J. 1991. Dose-related subclinical neurobehavioral effects of chronic exposure to low levels of organic solvents. Am J Ind Med 19:715–728.1652894
Bonnet P, Raoult G, Gradiski D. 1979. [Lethal concentration 50 of main aromatic hydrocarbons.] Arch Mal Prof 40:805–810. (French)
Borden RC, Black DC, McBleif KV. 2002. MTBE and aromatic hydrocarbons in North Carolina stormwater runoff. Environ Pollut 118:141–152.11996377
Bos RP, Brouns RME, Van Doorn R, . 1981. Nonmutagenicity of toluene, o-, m-, p-xylene, o-methylbenzylalcohol and o-methyl benzylsulfate in the Ames assay. Mutat Res 88:273–279.7019688
Boutelet-Bochan H, Huang Y, Juchau MR. 1997. Expression of CYP2E1 during embryogenesis and fetogenesis in human cephalic tissues: Implications for the fetal alcohol syndrome. Biochem Biophys Res Commun 238(2):443–447.9299528
Bouwer EJ. 1989. Biotransformation of aromatics in strip-pit pond. J Environ Eng 115:741–755.
Bowen SE, Hamilton J, Balster RL. 1998. A method for adjusting exposure levels of volatile solvents based on effects on schedule-controlled behavior. Neurotoxicol Teratol 20(2):169–180.9536462
*Bowers DJ, Cannon MS, Jones DH. 1982. Ultrastructural changes in livers of young and aging rats exposed to methylated benzenes. Am J Vet Res 43:679–683.7073090
Braddock JF, McCarthy KA. 1996. Hydrologic microbiological factors affecting persistence and migration of petroleum hydrocarbon spilled in a continuous-permafrost region. Environ Sci Technol 30:2626–2633.
Brasington RD, Thorpe-Swenson AJ. 1991. Systemic sclerosis associated with cutaneous exposure to solvent: Case report and review of the literature. Arthritis Rheum 34:631–633.2025315
Bratveit M, Hollund BE, Moen BE. 2004. Reduced exposure to organic solvents by use of water-based paint systems in car repair shops. Int Arch Occup Environ Health 77(1):31–38.14605898
Bray HG, Humphris BG, Thorpe WV. 1949. Metabolism of derivatives of toluene: 3. o-, m-, and p-Xylenes. Biochem J 45:241–244.
Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: C.V. Mosby Company, 221–222.
Brown RH. 1988a. Method 1- determination of benzene, toluene and xylene in industrial air by charcoal tube, solvent desorption and gas chromatography. IARC Sci Publ (85):225–233.3182045
Brown RH. 1988b. Method 2- determination of benzene, toluene and xylene in industrial air by porous polymer adsorption tube, thermal desorption and gas chromatography. IARC Sci Publ (85):235–242.3182046
Brown SK, Sim MR, Abramson MJ, . 1994. Concentrations of volatile organic compounds in indoor air - A review. Indoor Air 4:123–134.
Bruce BW, McMahon PB. 1996. Shallow ground-water quality beneath a major urban center: Denver, Colorado, USA. J Hydrol 186:129–151.
Brzezinski MR, Boutelet-Bochan H, Person RE, . 1999. Catalytic activity and quantitation cytochrome P-450 2E1 in prenatal human brain. J Pharmacol Exp Ther 289:1648–1653.10336564
Bushnell, PJ. 1989. Behavioral effects of acute p-xylene inhalation in rats: Autoshaping, motor activity, and reversal learning. Neurotoxicol Teratol 10:569–577.
Calabrese EJ. 1978. Pollutants and high-risk groups: The biological basis of increased human susceptibility to environmental and occupational pollutants. New York, NY: John Wiley and Sons, 4–8.
Cameron GR, Paterson JLH, DeSaram GSW, . 1938. The toxicity of some methyl derivatives of benzene with special reference to pseudocumene and heavy coal tar naphtha. J Pathol Bacteriol 46:95–107.
Campbell L, Wilson HK, Samuel AM, . 1988. Interactions of m-xylene and aspirin metabolism in man. Br J Ind Med 45:127–132.3342195
Cannella WJ. 1998. Xylenes and ethylbenzene. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. http://www.mrw.interscience.wiley.com/kirk/articles/xylecann.a01. February 15, 2005.
*Cannon Laboratories. 1976. Report on rabbit eye irritation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206126.
Canter LW, Sabatini DA. 1994. Contamination of public ground water supplies by Superfund sites. Int J Environ Stud 46:35–57.
Caperos JR, Fernandez JG. 1977. Simultaneous determination of toluene and xylene metabolites in urine by gas chromatography. Br J Ind Med 34:229–233.911693
Carlone MF, Fouts JR. 1974. In vitro metabolism of p-xylene by rabbit lung and liver. Xenobiotica 4:705–715.
Carlsson A. 1981. Distribution and elimination of 14C-xylene in rat. Scand J Work Environ Health 7:51–55.7313610
Carpenter CP, Kinkead ER, Geary DJ, . 1975a. Petroleum hydrocarbon toxicity studies: V. Animal and human response to vapors of mixed xylenes. Toxicol Appl Pharmacol 33:543–558.1188950
*Carpenter CP, Kinkead ER, Geary DJ, . 1975b. Petroleum hydrocarbon toxicity studies: I. Methodology. Toxicol Appl Pharmacol 32:246–262.1154392
Carpenter SP, Lasker JM, Raucy JL. 1996. Expression, induction, and catalytic activity of the ethanol-inducible cytochrome P450 (CYP2E1) in human fetal liver and hepatocytes. Mol Pharmacol 49:260–268.8632758
Casto BC. 1981. Detection of chemical carcinogens and mutagens in hamster cells by enhancement of adenovirus transformation. In: Mishra N, Dunkel V, Mehlman, eds. Advances in modern environmental toxicology. Princeton, NJ: Senate Press, 241–271.
Cha YJ, Cadwallader KR. 1995. Volatile components in salt-fermented fish and shrimp pastes. J Food Sci 60:19–24.
Chan CC, Lin SH, Her GR. 1994. Office worker’s exposure to volatile organic compounds while commuting and working in Taipei City. Atmos Environ 28(1–4):2351–2359.
Chan C-C, Nien C-K, Tsai C-Y, . 1995. Comparison of tail-pipe emissions from motorcycles and passenger cars. J Air Waste Manage Assoc 45:116–124.
Chan CC, Vainer L, Martin JW, . 1990. Determination of organic contaminants in residential indoor air using an adsorption-thermal desorption technique. J Air Waste Manage Assoc 40:62–67.2306363
Chao J, Lin CT, Chung TH. 1983. Vapor pressure of coal chemicals. J Phys Chem Ref Data 12:1033–1063.
*Charney W, Lipnowski M, Wugofski L. 1990. Biological exposure index testing: Two case studies. In: Charney W, Schirmer J, eds. Essentials of modern hospital safety. Chelsea, MI: Lewis Publishers, Inc., 273–281.
Chatterjee A, Babu RJ, Ahaghotu E, . 2005. The effect of occlusive and unocclusive exposure to xylene and benzene on skin irritation and molecular responses in hairless rats. Arch Toxicol 79(5):294–301.15902427
Chen CS, Zolteck J. 1995. Organic priority pollutants in wetland-treated leachates at a landfill in central Florida. Chemosphere 31(6):3455–3464.
Chevance FFV, Farmer LJ. 1999. Identification of a major volatile odor compounds in frankfurters. J Agric Food Chem 47:5151–5160.10606587
Chiou CT, Schmedding DW, Manes M. 1982. Partitioning of organic compounds in octanol-water systems. Environ Sci Technol 16:4–10.
Cho SI, Damokosh AI, Ryan LM, . 2001. Effects of exposure to organic solvents on menstrual cycle length. J Occup Environ Med 43(6):565–575.
CHRIS. 1999. m-Xylene, o-xylene, and p-xylene. Chemical Hazards Response Information System. U.S. Coast Guard, U.S. Department of Transportation. http://www.chrismanual.com/. May 23, 2007.
Chung HY. 1999. Volatile components in crabmeats of Charybdis feriatus. J Agric Food Chem 47:2280–2287.10794623
Clapp LW, Talarczyk MR, Park JK, . 1994. Performance comparison between activated sludge and fixed film processes for priority pollutant removals. Water Environ Res 66:153–160.
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coleman CA, Hull BE, McDougal JN, . 2003. The effect of m-xylene on cytotoxicity and cellular antioxidant status in rat dermal equivalents. Toxicol Lett 142:133–142.12765247
Coleman EC, Ho C, Chang SS. 1981. Isolation and identification of volatile compounds from baked potatoes. J Agric Food Chem 29:42–48.
Condie LW, Hill JR, Borzelleca JF. 1988. Oral toxicology studies with xylene isomers and mixed xylenes. Drug Chem Toxicol 11:329–354.3243184
Connor TH, Theiss JC, Hanna HA, . 1985. Genotoxicity of organic chemicals frequently found in the air of mobile homes. Toxicol Lett 25:33–40.3887653
Consumer Product Testing. 1976. Primary dermal irritation (rabbit); occular irritation (rabbit). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206121.
Cramer PH, Boggess KE, Hosenfeld JM, . 1988. Determination of organic chemicals in human whole blood: Preliminary method development for volatile organics. Bull Environ Contam Toxicol 40:612–618.3370355
Crofton KM, Lassiter TL, Rebert CS. 1994. Solvent-induced ototoxicity in rats: An atypical selective mid-frequency hearing deficit. Hearing Res 80:25–30.
Daniell W, Stebbins A, Kalman D, . 1992. The contributions to solvent uptake by skin and inhalation exposure. Am Ind Hyg Assoc J 53(2):124–129.1543128
Darnall KR, Atkinson R, Pitts JN Jr. 1979. Observation of biacetyl from the reaction of OH radicals with o-xylene: Evidence for ring cleavage. J Phys Chem 83:1943–1946.
David A, Flek J, Frantik E, . 1979. Influence of phenobarbital on xylene metabolism in man and rats. Int Arch Occup Environ Health 44:117–125.521166
Davis NR, Mapleson WW. 1981. Structure and quantification of a physiological model of the distribution of injected agents and inhaled anaesthetics. Br J Anaesth 53:399–405.7225273
Day BJ, DeNicola DB, Marcus CB, . 1992. Effect of p-xylene on the bioactivation of bromobenzene in rat lung and liver. Fundam Appl Toxicol 19:50–56.1397801
de Carvalho D, Lanchote VL, Bonato PS, . 1991. A new derivatization procedure for the analysis of hippuric acid and m-methyl-hippuric acid by gas chromatography. Int Arch Occup Environ Health 63:33–37.1856021
De Ceaurriz JC, Micillino JC, Bonnet P, . 1981. Sensory irritation caused by various industrial airborne chemicals. Toxicol Lett 9:137–143.7302985
De Ceaurriz J, Desiles JP, Bonnet P, . 1983. Concentration-dependent behavioral changes in mice following short-term inhalation exposure to various industrial solvents. Toxicol Appl Pharmacol 67(3):383–389.6845368
De Fré R, Bruynseraede P, Kretzschmar JG. 1994. Air pollution measurements in traffic tunnels. Environ Health Perspect 102(Suppl 4):31–37.
*DeGandarias JM, Echevarria E, Irazusta J, . 1993. Brain aminopeptidase activity after subacute xylene exposure. Neurotoxicol and Teratol 15:51–53.
Delzer GC, Zogorski JS, Lopes TJ. 1997. Occurrence of the gasoline oxygenate MTBE and BTEX compounds in municipal stormwater in the United States, 1991-1995. Prepr Ext Abst Div Environ Chem Am Chem Soc 37(1):374–376.
DeMarini DM, Lawrence BK, Brooks HG, . 1991. Compatibility of organic solvents with the microscreen prophage-induction assay: Solvent-mutagen interactions. Mutat Res 263:107–113.1828534
Derr RF. 1993. Simulation studies on ethanol metabolism in different human populations with a physiological pharmacokinetic model. J Pharm Sci 82:677–682.8360839
Desi I, Kovacs F, Zahumenszky Z, . 1967. Maze learning in rats exposed to xylene intoxication. Psychopharmacologia 11:224–230.6055522
Desideri PG, Lepri L, Checchini L, . 1994. Organic compounds in surface and deep Antarctic snow. Int J Environ Anal Chem 55:33–46.
Desideri PG, Lepri L, Udisti R, . 1998. Analysis of organic compounds in Antarctic snow and their origin. Int J Environ Anal Chem 7(3–4):331–351.
DeWulf J, Vanlangenhove H. 1997. Chlorinated C1 and C2-hydrocarbons and monocyclic aromatic hydrocarbons in marine waters: an overview on fate processes, sampling, analysis and measurements. Water Res 31(8):1825–1838.
Dolara P, Lodovici M, Buffoni F, . 1982. Variations of some parameters of enzyme induction in chemical workers. Ann Occup Hyg 25(1):27–32.6124202
Dudek B, Gralewicz K, Jakubowski M, . 1990. Neurobehavioral effects of experimental exposure to toluene, xylene and their mixture. Pol J Occup Med 3(1):109–116.2132931
Dumont JP, Adda J. 1978. Occurence of sesquiterpenes in mountain cheese volatiles. J Agric Food Chem 26:364–367.
Dutkiewicz T, Tyras H. 1968. Skin absorption of toluene, styrene, and xylene by man. Br J Ind Med 25:243.5663430
Dyer RS, Bercegeay MS, Mayo LM. 1988. Acute exposures to p-xylene and toluene alter visual information processing. Neurotoxicol Teratol 10:147–153.3398823
ECETOC. 1986. Joint assessment of commodity chemicals: No. 6. Xylenes. Brussels, Belgium: European Chemical Industry Ecology and Toxicology Centre.
Eganhouse RP, Cozarelli IM, Scholl MA, . 2001. Natural attenuation of volatile organic compounds (VOCs) in the leachate plume of a municipal landfill: Using alkylbenzenes as process probes. Ground Water 39:192–202.11286066
Eganhouse RP, Dorsey TF, Phinney CS, . 1996. Processes affecting the fate of monoaromatic hydrocarbons in an aquifer contaminated by crude oil. Environ Sci Technol 30:3304–3312.
Eichmann R, Ketseridis G, Schebeske G, . 1980. n-Alkane studies in the troposphere: II. Gas and particulate concentrations in Indian Ocean air. Atmos Environ 14:695–703.
Eichmann R, Neuling P, Ketseridis G, . 1979. n-Alkane studies in the troposphere: I. Gas and particulate concentrations in North Atlantic air. Atmos Environ 13:587–599.
Eitzer BD. 1995. Emissions of volatile organic chemicals from municipal solid waste composting facilities. Environ Sci Technol 29:896–902.22176396
Eklund B, Anderson EP, Walker BL, . 1998. Characterization of landfill gas composition at the fresh kills municipal solid-waste landfill. Environ Sci Technol 32(32):2233–2237.
Ellenhorn MJ, Barceloux DG, eds. 1988. Xylene. In: Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 962–964.
Elovaara E. 1982. Dose-related effects of m-xylene inhalation on the xenobiotic metabolism of the rat. Xenobiotica 12:345–352.7136002
Elovaara E, Collan Y, Pfaffli P, . 1980. The combined toxicity of technical grade xylene and ethanol in the rat. Xenobiotica 10:435–445.6774488
Elovaara E, Engstrom K, Hayri L, . 1989. Metabolism of antipyrine and m-xylene in rats after prolonged pretreatment with xylene alone or xylene with ethanol, phenobarbital, or 3-methylcholanthrene. Xenobiotica 19(9):945–960.2815836
Elovaara E, Zitting A, Nickels J, . 1987. m-Xylene inhalation destroys cytochrome P-450 in rat lung at low exposure. Arch Toxicol 61:21–26.3439869
Elshahed MS, Gieg LM, McInerney MJ, . 2001. Signature metabolites attesting to the in situ attenuation of alkylbenzenes in anaerobic environments. Environ Sci Technol 35:682–689.11349278
Endoh K, Kaneko T, Sato A. 1989. A physiologically based pharmacokinetic model to describe the transfer of organic solvents in the human body: Simulation of kinetic behavior of trichloroethylene using a spreadsheet program. Jpn J Ind Health 31:335–341.
English CW, Loehr RC. 1991. Degradation of organic vapors in unsaturated soils. J Hazard Mater 28:55–64.
Engstrom J, Bjurstrom R. 1978. Exposure to xylene and ethylbenzene: II. Concentration in subcutaneous adipose tissue. Scand J Work Environ Health 4:195–203.705286
Engstrom K, Husman K, Rantanen J. 1976. Measurement of toluene and xylene metabolites by gas chromatography. Int Arch Occup Environ Health 36:153–160.1248880
Engstrom K, Husman K, Riihimaki V. 1977. Percutaneous absorption of m-xylene in man. Int Arch Occup Environ Health 39:181–189.924688
Engstrom K, Riihimaki V, Laine A. 1984. Urinary disposition of ethylbenzene and m-xylene in man following separate and combined exposure. Int Arch Occup Environ Health 54:355–363.6511105
EPA. 1978. Initial report of the TSCA testing committee to the administrator, Environmental Protection Agency. U.S. Enviornmental Protection Agency. EPA5601078001.
EPA. 1980a. Acquisition and chemical analysis of mother’s milk for selected toxic substances. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA5600380029. PB81231029.
EPA. 1980b. Discarded commercial chemical products off-specification species, container residues and split residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
EPA. 1981a. Engineering handbook for hazardous waste incineration. Washington, DC: U.S. Environmental Protection Agency. PB81248163.
EPA. 1981b. Hazardous wastes from nonspecific sources. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.31.
EPA. 1983. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Sciences Research Laboratory. EPA600383027a.
EPA. 1984a. Health effects assessment for xylene. Washington, DC: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Office of Health and Environmental Assessment, Office of Research and Development, and Office of Emergency and Remedial Response. EPA540186006.
*EPA. 1984b. Proposed guidelines for carcinogenic risk. U.S. Environmental Protection Agency. Fed Regist 49:46294–46299.
EPA. 1985a. Drinking water criteria document for xylenes. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office for the Office of Drinking Water. EPA600X8485. PB86117942.
*EPA. 1985b. Xylene; exemption from the requirement of a tolerance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1025.
EPA. 1989. Determination of C2 to C12 ambient air hydrocarbons in 39 U.S. cities, from 1984 through 1986. Project summary. Research Triangle Park, NC: Atmospheric Research and Exposure Assessment Laboratory. EPA600S389058.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1991a. DOAS urban pollution measurements. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600D91044. PB91176966.
EPA. 1991b. Indoor air pollutants from household product sources. Washington, DC: U.S. Environmental Protection Agency. EPA600491025.
*EPA. 1992. Health and safety data reporting: Substances and listed mixtures to which this subpart applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.120.
EPA. 1993. Ambient concentration summaries for Clean Air Act. Title III: Hazardous air pollutants. EPA600R94090.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066F.
*EPA. 1997a. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
EPA. 1997b. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 2001a. Occurrence of unregulated contaminants in public water systems: A national summary. Washington, DC: U.S. Environmental Protection Agency. EPA815P00005.
EPA. 2001b. Exploration of perinatal pharmacokinetic issues. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R01004. http://cfpub.epa.gov/ncea/raf/recordisplay.cfm?deid=29420. March 25, 2005.
EPA. 2002a. Inventory update rule. Cas. No. 1330-2-07. Toxic Substance Control Act (TSCA) Inventory Update Database. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opt/uiru/iur02/index.htm. February 15, 2004.
EPA. 2002b. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F02013. http://www.epa.gov/safewater/mcl.html. February 15, 2005.
EPA. 2003. Toxicological review of xylenes. Washington, DC: U.S. Environmental Protection Agency EPA635R03001. http://www.epa.gov/iris/toxreviews/0270-tr.pdf. February 15, 2005.
EPA. 2004a. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822R04005. http://www.epa.gov/waterscience/drinking/standards/dwstandards.pdf. February 15, 2005.
EPA. 2004b. Hazardous air pollutants. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. February 15, 2005.
EPA. 2005a. Acute Exposure Guideline Levels (AEGLs) Washington, DC: Office of Pollution Prevention and Toxic Substances. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/chemlist.htm. March 28, 2005.
EPA. 2005b. National primary and secondary ambient air quality standards for lead. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 50.12. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, 2005.
EPA. 2005c. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005d. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, 2005.
EPA. 2005e. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005f. Tolerances and exemptions from tolerances for pesticide chemicals in food. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1025. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 25, 2005.
EPA. 2005g. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2005h. Xylenes. Modernized STORET system: Regular results by geographic location (stormodb): Characteristic search by CAS number. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dbtop.html. May 24, 2007.
EPA. 2007. Acute exposure guideline levels (AEGLs). Washington, DC: Office of Pollution Prevention and Toxic Substances. U.S. Environmental Protection Agency. http://www.epa.gov/opptintr/aegl/pubs/results85.htm. May 24, 2007.
Epler JL, Rao TK, Geurin MR. 1979. Evaluation of feasibility of mutagenic testing of shale oil products and effluents. Environ Health Perspect 30:179–184.376308
Eriksson M, Dalhammar G, Borg-Karlson AK. 1999. Aerobic degradation of a hydrocarbon mixture in natural uncontaminated potting soil by indigenous microorganisms at 20°C and 6°C. Appl Microbiol Biotechnol 51:532–535.10341436
Eriksson K, Tjarner D, Marqvardsen, . 2003. Exposure to benzene, toluene, xylenes and total hydrocarbons among snowmobile drivers in Sweden. Chemosphere 50:1343–1347.12586165
Ernstgard L, Gullstrand E, Lof A, . 2002. Are women more sensitive than men to 2-propanol and m-xylene vapours. Occup Environ Med 59(1):759–767.12409535
Ernstgard L, Sjogren B, Warholm M, . 2003. Sex differences in the toxicokinetics of inhaled solvent vaporsin humans. Toxicol Appl Pharmacol 193(2):147–157.14644617
Esposito GG, Jacobs BW. 1977. Chromatographic determination of aromatic hydrocarbons in ambient air. Am Ind Hyg Assoc J 38:401–407.900028
Fang Z, Sonner J, Laster MJ, . 1996. Anesthetic and convulsant properties of aromatic compounds and cycloalkanes: Implications for mechanisms of narcosis. Anesth Analg 83(5):1097–1104.8895293
FDA. 2006. Beverages. Bottled water. Washington, DC: U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. May 24, 2007.
FED R&D. 2005. Federal Research and Development summaries. Dialog Information Service, Incorporated.
FEDRIP. 2006. Federal Research in Progress. Dialog Information Service, Incorporated.
Feldt EG. 1986. [Evaluation of the mutagenic hazards of benzene and some of its derivatives.] Gig Sanit (7):21–23. (Russian)
Fellin P, Otson R. 1994. Assessment of the influence of climatic factors on concentration levels of volatile organic compounds (VOCs) in Canadian homes. Atmos Environ 28:3581–3586.
Fishbein L. 1985. An overview of environmental and toxicological aspects of aromatic hydrocarbons: III. Xylene. Sci Total Environ 43:165–183.3892684
Fishbein L. 1988. Xylenes: Uses, occurrence and exposure. In: Fishbein L, O’Neill IK, eds. Environmental carcinogens: Methods of analysis and exposure measurement. Vol. 10: Benzene and alkylated benzenes. Lyon, France: World Health Organization, International Agency for Research on Cancer, 109–120.
Fisher J, Male D, Bankston L, . 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–431.9183837
Florin I, Rutberg L, Curvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames’ test. Toxicol 18:219–232.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA:WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Food and Drug Research Labs. 1976a. Primary skin irritation study with rabbits. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206121.
Food and Drug Research Labs. 1976b. Rabbit eye irritation study. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0200298.
Först C, Stieglitz L, Roth W, . 1989a. Determination of volatile organic pollutants in leachate from different landfills. Vom Wasser 72:295–305.
Först C, Stieglitz L, Roth W, . 1989b. Quantitative analysis of volatile organic compounds in landfill leachates. Int J Environ Anal Chem 37:287–293.
Fortmann R, Roache N, Chang JCS, . 1998. Characterization of emmisions of volatile organic compounds from interior alkyd paint. J Air Waste Manage Assoc 48:931–940.
Foster P, Ferronato C, Jacob V. 1994. Organic compound transfer between gas-phase and raindrops. Fresenius Environ Bull 3:318–323.
Fox DL, Gary M, Jeffries HE. 1984. Organic aerosol formation: OH vs. ozone oxidation pathways. Atlanta, GA: Coordinating Research Council, Inc.
Foy JWD, Schatz RA. 2004. Inhibition of rat respiratory-tract cytochrome P-450 activity after acute low-level m-xylene inhalation: Role in 1-nitronaphthalene toxicity. Inhal Toxicol 16:125–132.15204773
Foy JWD, Silverman DM, Schatz RA. 1996. Low-level m-xylene inhalation alters pulmonary and hepatic cytochrome p-450 activity in the rat. J Toxicol Environ Health 47(2):135–144.8598570
Franchini I, Cavatorta A, Falzoi M, . 1983. Early indicators of renal damage in workers exposed to organic solvents. Int Arch Occup Environ Health 52:1–9.6603422
*Fraser MP, Cass GR, Simoneit BRT, . 1998a. Air quality model evaluation data for organics. C6-C22 nonpolar and semipolar aromatic compounds. Environ Sci Technol 32:1760–1770.
Fraser MP, Cass GR, Simoneit BRT. 1998b. Gas-phase and particle-phase organic compounds emitted from motor vehicle traffic in a Los Angeles roadway tunnel. Environ Sci Technol 32:2051–2060.
Fraser MP, Kleeman MJ, Schauer JJ, ; 2000. Modeling the atmospheric concentrations of individual gas-phase and particle-phase organic compounds. Environ Sci Technol 34:302–312.
Freundt KJ, Romer KG, Federsel RJ. 1989. Decrease of inhaled toluene, ethyl benzene, m-xylene, or mesitylene in rat blood after combined exposure to ethyl acetate. Bull Environ Contam Toxicol 42: 495–498.2713522
Fuentes HR, Polzer WL, Smith JL. 1991. Laboratory measurements of diffusion coefficients for trichloroethylene and orthoxylene in undisturbed turf. J Environ Qual 20:215–221.
Furnas DW, Hine CH. 1958. Neurotoxicity of some selected hydrocarbons. Arch Ind Health 18:9–15.
Gabele P. 1997. Exhaust emissions from four-stroke lawn mower engines. J Air Waste Manage Assoc 47:945–952.
Gabele PA. 2000. Emissions from two outboard engines operating on reformulated gasoline containing MTBE. Environ Sci Technol 34:368–372.
Gagnaire F, Langlais C. 2005. Relative ototoxicity of 21 aromatic solvents. Arch Toxicol 79(6):346–354.15660228
Gagnaire F, Langlais C, Grossman S, . 2006. Ototoxicity in rats exposed to ethylbenzene and to two technical xylene vapours for 13 weeks. Arch Toxicol 81(2):127–143.16786347
Gagnaire F, Marignac B, Langlais C, . 2001. Ototoxicity in rats exposed to ortho-, meta- and para-xylene vapours for 13 weeks. Pharmacol Toxicol 89:6–14.11484912
Gamberale F, Annwall G, Hultengren M. 1978. Exposure to xylene and ethylbenzene: III. Effects on central nervous functions. Scand J Work Environ Health 4:204–211.705287
Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
Gerarde HW. 1959. Toxicological studies on hydrocarbons: III. The biochemorphology of the phenylalkanes and phenylalkenes. Arch Ind Health 19:403–418.
Gerarde HW. 1960. Toxicology and biochemistry of aromatic hydrocarbons. London: Elsevier Publishing Co., 171–180.
Gerin M, Siemiatycki J, Desy M, . 1998. Associations between several sites of cancer and occupational exposure to benzene, toluene, xylene, and styrene: Results of a case-control study in Montreal. Am J Ind Med 34:144–156.9651624
Gerner-Smidt P, Friedrich U. 1978. The mutagenic effect of benzene, toluene and xylene studied by the SCE technique. Mutat Res 58:313–316.370577
Gery MW, Fox DL, Kamens RM, . 1987. Investigation of hydroxyl radical reactions with o-xylene and m-xylene in a continuous stirred tank reactor. Environ Sci Technol 21:339–348.22280173
Ghantous H, Danielsson BR. 1986. Placental transfer and distribution of toluene, xylene and benzene, and their metabolites during gestation in mice. Biol Res Pregnancy Perinatol 7:98–105.3778990
*Ghantous H, Dencker L, Gabrielsson J, . 1990. Accumulation and turnover of metabolites of toluene and xylene in nasal mucosa and olfactory bulb in the mouse. Pharmacol Toxicol 66:87–92.2315269
Gherini SA, Summers KV, Munson RK, . 1989. Chemical data for predicting the fate of organic compounds in water: Volume 1, Technical basis: Final report. Palo Alto, CA: Electrical Power Research Institute. EPRI-EA-5818.
Gholson AR, Albritton JR, Jayanty RKM, . 1991. Evaluation of an enclosure method for measuring emissions of volatile organic compounds from quiescent liquid surfaces. Environ Sci Technol 25:519–24.
Ghosh TK, Copeland RJ, Parui RN, . 1987. Effects of xylene inhalation on fixed-ratio responding in rats. Pharmacol Biochem Behav 27:653–657.3659092
Giger W, Schaffner C. 1981. Groundwater pollution by volatile organic chemicals. Stud Environ Sci 17:517–522.
Ginsberg G, Hattis D, Sonawane B. 2004. Incorporating pharmacokinetic differences between children and adults in assessing children’s risk to environmental toxicants. Toxicol Appl Pharmacol 198:164–183.15236952
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glaser RA, Arnold JE. 1989. Investigation of charcoal cloth as a sorbent for integrated sampling of solvent vapors in mixed-expired breath using a new stainless steel sampler. Am Ind Hyg Assoc J 50:112–21.2929429
Glaser RA, Arnold JE, Shulman SA. 1990. Comparison of 3 sampling and analytical methods for measuring meta-xylene in expired air of exposed humans. Am Ind Hyg Assoc J 51:139–150.2327325
Gleason MN, Gosselin RE, Hodge HC, . 1969. Clinical toxicology of commercial products: Acute poisoning. 3rd ed. Baltimore, MD: Williams and Wilkins, 227–230.
Goldfrank LR, Kulberg AG, Bresnitz EA. 1990. Hydrocarbons. In: Goldfrank LR, ed. Goldfrank’s toxicologic emergencies. Norwalk, CT: Appleton and Lange, 759–768.
Goldie I. 1960. Can xylene (xylol) provoke convulsive seizures. Ind Med Surg 29:33–35.13850655
Gomez E, Ledbetter CA, Hartsell PL. 1993. Volatile compounds in apricot, plum, and their interspecific hybrids. J Agric Food Chem 41:1669–1676.
Gonzalez-Reche LM, Schettgen T, Angerer J. 2003. New approaches to the metabolism of xylenes: Verification of the formation of phenylmercapturic acid metabolites of xylenes. Arch Toxicol 77:80–85.12590359
Gosselin RE, Smith RP, Hodge HC. 1984. Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams & Wilkins, 397–404.
Gossett RW, Brown DA, Young DR. 1983. Predicting the bioaccumulation of organic compounds in marine organisms using octanol/water partition coefficients. Marine Pollut Bull 14:387–392.
Graham LA, Noseworthy L, Fugler D, . 2004. Contribution of vehicle emissions from an attached garage to residential indoor air pollution levels. J Air Waste Manage Assoc 54:563–584.
Gralewicz S, Wiaderna D. 2001. Behavior effects following subacute inhalation exposure to m-xylene or trimethylbenzene in the rat a comparative study. Neurotoxicology 22(1):79–89.11307854
Gralewicz S, Wiaderna D, Tomas T. 1995. Development of spontaneous, age-related nonconvulsive seizure electrocortical activity and radial-maze learning after exposure to m-xylene in rats. Int J Occup Med Environ Health 8(4):347–360.8907413
Green WJ, Lee GF, Jones RA. 1981. Clay-soils permeability and hazardous waste storage. J Water Pollut Control Fed 53:1347–1354.
Greenberg JP, Zimmerman PR. 1984. Nonmethane hydrocarbons in remote tropical, continental and marine atmospheres. J Geophys Res 89:4767–4778.
Griffin RA, Hughes RE, Follmer IR, . 1984. Migration of industrial chemicals and soil-waste interactions at Wilsonville, Illinois. In: Land disposal of hazardous waste. Proceedings of the Tenth Annual Research Symposium. Ft. Mitchell, KY: U.S. Environmental Protection Agency, 61–77.
Grosjean D, Fung K. 1984. Hydrocarbons and carbonyls in Los Angeles air. J Air Pollut Control Assoc 34:537–543.
Guisti DM, Conway RA, Lawson CT. 1974. Activated carbon adsorption of petrochemicals. J Water Pollut Control Fed 46:947–965.
Gunasekar PG, Rogers JV, Kabbur MB, . 2003. Molecular and histological responses in rat skin exposed to m-xylene. J Biochem Mol Toxicol 17(2):92–94.12717741
Gupta BN, Kumar P, Srivastava AK. 1990. An investigation of the neurobehavioral effects on workers exposed to organic solvents. J Soc Occup Med 40:94–96.2214700
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad S, Beliveau M, Tardif R, . 2001. A PBPK modeling-based approach to account for interactions in the health risk assessment of chemical mixtures. Toxicol Sci 63:125–131.11509752
Haddad S, Charest-Tardif G, Tardif R, . 2000. Validation of a physiological modeling framework for simulating the toxicokinetics of chemicals in mixtures. Toxicol Appl Pharmacol 167:199–209.10986011
Haddad S, Tardif R, Viau C, . 1999. A modeling approach to account for toxicokinetic interactions in the calculation of biological hazard index for chemical mixtures. Toxicol Lett 108:303–308.10511275
Haglund U, Lundberg I, Zech L. 1980. Chromosome aberrations and sister chromatid exchanges in Swedish paint industry workers. Scand J Work Environ Health 6:291–298.7233117
Haigler BE, Pettigrew CA, Spain JC. 1992. Biodegradation of mixtures of substituted benzenes by Pseudomonas sp. strain JS150. Appl Environ Microbiol 58:2237–2244.1637161
Hakkola M, Saarinen L. 1996. Exposure of tanker drivers to gasoline and some of its components. Ann Occup Hyg 40(1):1–10.9054298
Hampton CV, Pierson WR, Harvey TM, . 1982. Hydrocarbon gases emitted from vehicles on the road: 1. A qualitative gas chromatography/mass spectrometry survey. Environ Sci Technol 16:287–298.22257255
*Hansch C, Leo A. 1979. Substituent constants for correlation analysis in chemistry and biology. New York, NY: John Wiley & Sons, 232.
Hansch C, Leo A, Hoekman D. 1995. Xylene. Exploring QSAR hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 43.
Harper C, Drew RT, Fouts JR. 1975. Benzene and p-xylene: A comparison of inhalation toxicities and in vitro hydroxylations. In: Jollow J, ed. Biological reactive intermediates: Formation, toxicity, and inactivation. Proceedings of an International Conference, Turku, Finland, July 26-27, 1975. New York, NY: Plenum Press, 302–311.
Hass U, Jakobsen BM. 1993. Prenatal toxicity of xylene inhalation in the rat: A teratogenicity and postnatal study. Pharmacol and Toxicol 73:20–23.
Hass U, Lund SP, Simonsen L. 1995. Long-lasting neurobehaviorl effects of prenatal exposure to xylene in rats. Neurotoxicology 16(4):761.
Hass U, Lund SP, Simonsen L. 1997. Long-lasting neurobehavioral effects of prenatal exposure to xylene in rats. Neurotoxicology 18(2):547–552.9291502
Hastings L, Cooper GP, Burg W. 1986. Human sensory response to selected petroleum hydrocarbons. In: MacFarland HN, Holdsworth CE, MacGregor JA, . eds. Advances in modern environmental toxicology. Vol. 6. Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 255–270.
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen (Suppl) 1:3–142.
HazDat. 2006. Xylene. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. www.atsdr.cdc.gov/hazdat.html. July 10, 2006.
Heavner DL, Morgan WT, Ogden MW. 1995. Determination of volatile organic compounds and its apportionment in 49 homes. Environ Int 21:3–21.
Heavner DL, Morgan WT, Ogden MW. 1996. Determination of volatile organic compounds and respirable suspended particulate matter in New Jersey and Pennsylvania homes and workplaces. Environ Int 22:159–183.
Heikes DL, Jensen SR, Fleming-Jones ME. 1995. Purge and trap extraction with GC-MS determination of volatile organic compounds in table-ready foods. J Agric Food Chem 43:2869–2875.
Hejtmankova N, Simanek V, Holcik J, . 1979. Antifungal and mutagenic activity of phenolic substances with different alkyl groups: II. A study of the relationship between the biological activity and the constitution of the investigated compounds. Acta Univ Palacki Olomuc Fac Med 90:75–87.
Herman DC, Mayfield CI, Inniss WE. 1991. The relationship between toxicity and bioconcentration of volatile aromatic-hydrocarbons by the alga Selenastrum-capricornutum. Chemosphere 22:665–676.
Hester NE, Meyer RA. 1979. A sensitive technique for measurement of benzene and alkylbenzenes in air. Environ Sci Technol 13:107–109.
Hiatt MH. 1983. Determination of volatile organic compounds in fish samples by vacuum distillation and fused silica capillary gas chromatography/mass spectrometry. Anal Chem 55:506–516.6846846
Hiatt MH, Pia JH. 2004. Screening processed milk for volatile organic compounds using vacuum distillation/gas chromatography/mass spectrometry. Arch Environ Contam Toxicol 46:189–196.15106669
Higgins E, Griest WH, Olerich G. 1983. Applications of Tenax trapping to analysis of gas phase organic compounds. J Assoc Off Anal Chem 66:1074–1083.
Hillefors-Berglund M, Liu Y, von Euler G. 1995. Persistent, specific and dose-dependent effects of toluene exposure on dopamine D_2_ agonist binding in the rat caudate-putamen. Toxicology 100(1–3):185–194.7624876
Hine CH, Zuidema HH. 1970. The toxicological properties of hydrocarbon solvents. Ind Medicine 39:39–44.
Hipolito RN. 1980. Xylene poisoning in laboratory workers: Case reports and discussion. Lab Med 11:593–595.
Ho CT, Lee KN, Jin QZ. 1983. Isolation and identification of volatile flavor compounds in fried bacon. J Agric Food Chem 31:336–342.
Hodge HC, Sterner JH. 1949. Tabulation of toxicity classes. Am Ind Hyg Assoc Q 10:93–96.24536943
Hodgson AT, Rudd AF, Beal D, . 2000. Volatile organic compound concentrations and emission rates in new manufactures and site-built houses. Indoor Air 10:178–192.10979199
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoffmann K, Krause C, Seifert B, . 2000. The German Environmental Survey 1990/92 (GERES II) Sources of personal exposure to volatile organic compounds. J Expo Anal Environ Epidemiol 10:115–125.10791593
Holmberg PC, Nurminen M. 1980. Congenital defects of the central nervous system and occupational factors during pregnancy, case-referent study. Am J Ind Med 1:167–176.7342764
Holz O, Scherer G, Brodtmeier S, . 1995. Determination of low level exposure to volatile aromatic hydrocarbons and genotoxic effects in workers at a styrene plant. Occup Environ Med 52:420–428.7627321
Honma T, Sudo A, Miyagawa M, . 1983. Significant changes in the amounts of neurotransmitter and related substances in rat brain induced by subacute exposure to low levels of toluene and xylene. Ind Health 21:143–151.6138322
HSDB. 2007. Xylene. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. May 4, 2007.
Hsieh CC, Chang KH, Kao YS. 1999. Estimating the ozone formation potential of volatile aromatic compounds in vehicle tunnels. Chemosphere 39(9):1433–1444.10481245
Hudak A, Ungvary G. 1978. Embryotoxic effects of benzene and its methyl derivatives: Toluene, xylene. Toxicology 11:55–63.705804
Hung IF, Liao MH. 1991. Aromatic hydrocarbons in indoor air. J Environ Sci Health A26:487–492.
Hunt MJ, Shafer MB, Barlaz MA, . 1997. Anaerobic biodegradation of alkylbenzenes in laboratory microcosms representing ambient conditions. Biorem J 1:53–64.
Hutchins SR. 1991. Optimizing BTEX biodegradation under denitryfying conditions. Environ Tox Chem 10:1437–1448.
Iannuzzi TJ, Huntley SL, Schmidt CW, . 1997. Combined sewer overflows (CSOs) as sources of sediment contamination in the lower Passaic River, New Jersey. I. Priority pollutants and inorganic chemicals. Chemosphere 34(2):213–231.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1-82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. February 15, 2005.
Ilgen E, Karfich N, Levsen K, . 2001a. Aromatic hydrocarbons in the atmospheric environment: Part I. Indoor outdoor sources, the influence of traffic. Atmos Environ 35:1235–1252.
Ilgen E, Levesen K, Angerer J, . 2001b. Aromatic hydrocarbons in the atmospheric environment. Part II: Univariate and multivariate analysis and case studies of indoor concentrations. Atmos Environ 35:1253–1264.
Ilgen E, Levsen K, Angerer J, . 2001c. Aromatic hydrocarbons in the atmospheric environment. Part III: Personal monitoring. Atmos Environ 35:1265–1279.
Inoue O, Seiji K, Kawai T . 1993. Excretion of methylhippuric acids in urine of workers exposed to a xylene mixture: Comparison among three xylene isomers and toluene. Int Arch Occup Environ Health 64:533–539.8482596
IPCS. 1992. Xylene. Poisons information monograph 565. International Programme on Chemical Safety. http://www.inchem.org/documents/pims/xylene.htm. April 07, 2005.
IRIS. 2005. Xylenes. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. February 15, 2004.
Ito T, Yoshitome K, Horike T, . 2002. Distribution of inhaled m-xylene in rat brain and its effect on GABAA receptor binding. J Occup Health 44(2):69–75.
Iyadomi M, Ichiba M, Zhang J, . 2000. Evaluation of skin irritants caused by organic solvents by means of the mouse ear thickness measurement method. J Occup Health 42:44–46.
Jajte J, Stetkiewicz J, Wronska-Nofer T. 2003. Combined exposure to m-xylene and ethanol: Oxidative stress in the rat liver. Int J Occup Med Environ Health 16(4):345–350.14964644
*Jakubowski M, Kostrzewski P. 1989. Excretion of methylbenzoic acid in urine as a result of single and combined exposure to m-xylene. Pol J Occup Med 2:238–247.2489427
Jang JY, Droz PO. 1997. Ethnic differences in biological monitoring of several organic solvents II. A simulation study with a physiologically based pharmacokinetic model. Int Arch Occup Environ Health 70:41–50.9258706
Jang JY, Droz PO, Berode M. 1997. Ethnic differences in biological monitoring of several organic solvents. I. Human exposure experiment. Int Arch Occup Environ Health 69:343–349.9192219
Jay K, Stieglitz L. 1995. Identification and quantification of volatile organic components in emissions of waste incineration plants. Chemosphere 30(7):1249–1260.
Jenkins J, Runes H, Moate T. 2004. Xylenes in Oregon hazelnuts. Bull Environ Contam Toxicol 72:1152–1156.15362443
Jenkins LJ, Jones RA, Siegel J. 1970. Long-term inhalation screening studies of benzene, toluene, o-xylene, and cumene on experimental animals. Toxicol Appl Pharmacol 16:818–823.4987190
Jepson GW, McDougal JN. 1997. Physiologically based modeling of nonsteady state dermal absorption of halogenated methanes from an aqueous solution. Toxicol Appl Pharmacol 144:315–324.9194415
Jo WK, Choi SJ. 1996. Vehicle occupants’ exposure to aromatic volatile organic compounds while commuting on an urban-suburban route in Korea. J Air Waste Manage Assoc 46:749–754.
Jo WK, Kim SH. 2001. Worker exposure to aromatic volatile organic compounds in dry cleaning. Am Ind Hyg Assoc J 62(4):466–471.
Jo WK, Moon KC. 1999. Housewives’ exposure to volatile organic compounds relative to proximity to roadside service stations. Atmos Environ 33:2921–2928.
Jo WK, Kim KY, Park KH, . 2003. Comparison of outdoor and indoor mobile source-related volatile organic compounds between low- and high- floor apartments. Environ Res 92:166–171.12854697
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190:3–16.6769537
Jonai H, Sato M. 1988. Exposure indices for painters exposed to toluene and xylene at low concentrations. Ind Health 26:197–202.3182307
Jori A, Calamari D, Di Domenico A, . 1986. Ecotoxicological profile of xylenes: Working party on ecotoxicological profiles of chemicals. Ecotoxicol Environ Safety 11:44–80.3956431
Jovanovic JM, Jovanovic MM, Spasic MJ, . 2004. Peripheral nerve conduction study in workers exposed to a mixture of organic solvents in paint and lacquer industry. Croat Med J 45(6):769–774.15578814
Juttner F. 1994. Emission of aromatic hydrocarbons and aldehydes into the water by a pour-stroke outboard motor: Quantitative measurements. Chemosphere 29(2):191–200.
Kaneko T, Endoh K, Sato A. 1991a. Biological monitoring of exposure to organic solvent vapors. I. A physiological simulation model of m-xylene pharmacokinetics in man. Yamanashi Med J 6(3):127–135.
Kaneko T, Endoh K, Sato A. 1991b. Biological monitoring of exposure to organic solvent vapors. II. Simulation studies using a physiological pharmacokinetic model for m-xylene. Yamanashi Med J 6(3):137–149.
Kaneko T, Horiuchi J, Sato A. 2000. Development of a physiologically based pharmacokinetic model of organic solvent in rats. Pharm Res 42(5):465–470.
Kaneko T, Wang P-Y, Sato A. 1993. Enzyme induction by ethanol consumption affects the pharmacokinetics of inhaled m-xylene only at high levels of exposure. Arch Toxicol 67:473–477.8239996
Kaneko T, Wang PY, Tsukada H, . 1995. m-Xylene toxicokinetics in phenobarbital-treated rats: Comparison among inhalation exposure, oral administration, and intraperitoneal administration. Toxicol Appl Pharmacol 131:13–20.7878667
Kango RA, Quinn JG. 1989. Adsorption studies of xylenes and ethylbenzene on soil and humic-acid by a purge and trap gas-chromatographic method. Chemosphere 19:1269–1276.
Kao CM, Wang YS. 2001. Field investigation of the natural attenuation and intrinsic biodegradation rates at an underground storage tank site. Environ Geol 40(4–5):622–631.
Karlson U, Frankenberger WT Jr. 1989. Microbial degradation of benzene and toluene in groundwater. Bull Environ Contam Toxicol 43:505–510.2804391
Kataoka H, Manabe K, Nakase S, . 1991. Determination of hippuric acid and o-, m- and p-methylhippuric acids in urine by capillary gas chromatography. J Pharm Biomed Anal 9:699–704.1821145
Katsuyama H, Tsuchiya G, Saijoh K, . 1998. Occupational exposure to low concentrations of organic solvents in shipyards. J Occup Health 40:186–192.
Kawai T, Mizunuma K, Yasugi T, . 1991. Urinary methylhippuric acid isomer levels after occupational exposure to a xylene mixture. Int Arch Occup Environ Health 63:69–75.1856026
Kawai T, Yasugi T, Mizunuma K. 1992. Comparative evaluation of urinalysis and blood analysis as means of detecting exposure to organic solvents at low concentrations. Int Arch Occup Environ Health 64:223–234.1468790
Kawata K, Tanabe A, Saito S, . 1997. Screening of volatile organic compounds in river sediment. Bull Environ Contam Toxicol 58:893–900.9136651
Keith LH, Garrison AW, Allen FR, . 1976. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers Inc., 329–373.
Kelly TJ, Muklund R, Spicer CW, . 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28:378–387.
Kennah HE, Hignet HS, Laux PE, . 1989. An objective procedure for quantitating eye irritation based upon changes of corneal thickness. Fundam Appl Toxicol 12:258–268.2714526
Kent B, Spycher N. 1994. Major chemical parameters in groundwater control. Environmental science and pollution control. New York, NY: Dekker M, 479–495.
Kezic S, Janmaat A, Kruse J, . 2004. Percutaneous absorption of m-xylene vapour in volunteers during pre-steady and steady state. Toxicol Lett 153:273–282.15451559
Kezic S, Monster AC, Kruse J, . 2000. Skin absorption of some vaporous solvents in volunteers. Int Arch Occup Environ Health 73:415–422.11007346
Kezic S, Monster AC, van de Gevel IA, . 2001. Dermal absorption of neat liquid solvents on brief exposures in volunteers. Am Ind Hyg Assoc J 62:12–18.
Kilburn KH, Seidman BC, Warshaw R. 1985. Neurobehavioral and respiratory symptoms of formaldehyde and xylene exposure in histology technicians. Arch Env Health 40:229–233.4051579
*Kim SK, Kim YC. 1996. Effect of a single administration of benzene, toluene or m-xylene on carboxyhaemoglobin elevation and metabolism of dichloromethane in rats. J Appl Toxicol 16:437–444.8889796
Kim YM, Harrad S, Harrison RM. 2001. Concentrations and sources of VOCs in urban domestic and public microenvironments. Environ Sci Technol 35:997–1004.11347947
King MF, Hamilton BL, Matthews MA, . 1993. Isolation and identification of volatiles and condensable material in raw beef with supercritical carbon dioxide extraction. J Agric Food Chem 41:1974–1981.
Kinlin EK, Muralidhara R, Pittet AO, . 1972. Volatile components of roasted filberts. J Agric Food Chem 20(5):1021–1028.
Kinney PL, Chillrud SN, Ramstrom S, . 2002. Exposures to multiple air toxics in New York City. Environ Health Perspect 110(Suppl. 4):539–546.12194883
Kira S. 1977. Measurement by gas chromatography of urinary hippuric acid and methylhippuric acid as indices of toluene and xylene exposure. Br J Ind Med 34:305–309.588486
Klaucke DN, Johansen M, Vogt RL. 1982. An outbreak of xylene intoxication in a hospital. Am J Ind Med 3:173–178.7137174
*Klimisch H-J, Pauluhn J, Hollander HW, . 1988. Inhalation hazard test: Interlaboratory trial with OECD method 403. Arch Toxicol 61:318–320.3377686
Koe LCC, Tan NC. 1990. GC-MS Identification of gaseous volatiles in wastewater. Environ Monit Assess 15:13–24.24243425
Kolpin DW, Squillace PJ, Zogorski JS, . 1997. Pesticides and volatile organic compounds in shallow urban groundwater of the United States. Int Contrib Hydrogeol 21:469–474.
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Korsak Z, Sokal JA, Dedyk A, . 1988. Toxic effects of combined exposure to toluene and xylene in animals: I. Acute inhalation study. Pol J Occup Med 1:45–50.2980149
Korsak Z, Sokal JA, Gorny R. 1992. Toxic effects of combined exposure to toluene and m-xylene in animals. III. Subchronic inhalation study. Pol J Occup Med Environ Health 5(1):27–33.1392650
Korsak Z, Sokal JA, Swiercz R. 1991. The toxic effects of combined exposure to toluene and m-xylene in animals: II. Blood toluene and m-xylene during single and combined exposure in rats. Pol J Occup Med 4:377–381.
Korsak Z, Sokal JA, Wasiela T, . 1990. Toxic effects of acute exposure to particular xylene isomers in animals. Pol J Occup Med 3:221–226.2130876
Korsak Z, Swiercz R, Jedrychowski R. 1993. Effects of acute combined exposure to n-butyl alcohol and m-xylene. Pol J Occup Med Environ Health 6(1):35–41.8219896
Korsak Z, Wisniewska-Knypl J, Swiercz R. 1994. Toxic effects of subchronic combined exposure to n-butyl alcohol and m-xylene in rats. Int J Occup Med Environ Health 7(2):155–166.7820390
Kostianen R. 1995. Volatile organic compounds in the indoor air of normal and sick houses. Atmos Environ 29:693–702.
Kramer A, Linnert M, Wrbitzky R, . 1999. Occupational chronic exposure to organic solvents XVII. Ambient and biological monitoring of workers exposed to xyelens. Int Arch Occup Environ Health 72:52–55.10029231
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kucera J. 1968. Exposure to fat solvents: A possible cause for sacral agenesis in man. J Pediatr 72:857–859.5652613
Kumarathasan P, Oyson R, Chu I. 1998. Application of an automated HS-GC method in partition coefficient determination for xylenes and ethylbenzene in rat tissues. Chemosphere 37(1):159–178.9637007
Kurppa K, Husman K. 1982. Car painters’ exposure to a mixture of organic solvents: Serum activities of liver enzymes. Scand J Work Environ Health 8:137–140.6127809
Kwok ESC, Atkinson R. 1995. Estimation of hydroxyl radical reaction rate constants for gas-phase organic compounds using a structure-reactivity relationship: An update. Atmos Environ 29(14):1685–1695.
Kyrklund T, Kjellstrand P, Haglid K. 1987. Brain lipid changes in rats exposed to xylene and toluene. Toxicology 45:123–133.3603578
LaGrone FS. 1991. Potential community exposure to toxic chemicals. Environ Sci Technol 25:366–368.
Lahvis MA, Baehr AL, Baker RJ. 1999. Quantification of aerobic biodegradation and volatilization rates of gasoline hydrocarbons near the water table under natural attenuation conditions. Water Resour Res 35(3):753–765.
Laine A, Savolainen K, Riihimaki V, . 1993. Acute effects of m-xylene inhalation on body sway, reaction times, and sleep in man. Int Arch Occup Environ Health 65:179–188.8282416
Lapare S, Tardiff R, Brodeur J. 1993. Effect of various exposure scenarios on the biological monitoring of organic solvents in alveolar air. I. Toluene and m-xylene. Int Arch Environ Health 64:569–580.
Lawryk NJ, Weisel CP. 1996. Concentrations of volatile organic compounds in the passenger compartments of automobiles. Environ Sci Technol 30:810–816.
*Lee S-H, Lee SH. 1993. A study on the neurobehavioral effects of occupational exposure to organic solvents in Korean workers. Environ Res 60:227–232.8472651
Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leguen S, Prost C, Demaimay M. 2000. Critical comparison of three olfactometric methods for the identification of the most potent odorants in cooked mussels (Mytilus edulis). J Agric Food Chem 48:1307–1314.10775390
Lemire S, Ashley D, Olaya P, . 2004. Environmental exposure of commuters in Mexico City to volatile organic compounds as assessed by blood concentrations, 1998. Salud Pub Mexico 46(4):32–38.
Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Leung P-L, Harrison RM. 1998. Evaluation of personal exposure to monoaromatic hydrocarbons. Occup Environ Med 55:249–257.9624279
Leung P-L, Harrison RM. 1999. Roadside and in-vehicle concentrations of monoaromatic hydrocarbons. Atmos Environ 33:191–204.
Lewis RJ. 1997. Xylene. In: Hawley’s condensed chemical dictionary. 13th ed. New York, NY: John Wiley & Sons, Inc., 1188.
Lewis RJ. 2000. Xylene. In: Sax’s dangerous properties of industrial materials. 10th ed. New York, NY: John Wiley & Sons Inc., 3702–3703.
Lewis RJ. 2001. Xylene. In: Hawley’s condensed chemical dictionary. 14th ed. New York, NY: John Wiley & Sons, Inc., 1183–1185.
Lide DR. 2005. Xylene. In: CRC handbook of chemistry and physics. 86th ed. Boca Raton, FL: CRC Press, 3-520 to 3-521.
Liira J, Elovaara E, Raunio H, . 1991. Metabolic interaction and disposition of methylethylketone and m-xylene in rats at single and repeated inhalation exposures. Xenobiotica 21:53–64.2003367
Liira J, Riihimaki V, Engstrom K, . 1988. Coexposure of man to m-xylene and methyl ethyl ketone: Kinetics and metabolism. Scand J Work Environ Health 14:322–327.3201193
Lindbohm M-L, Taskinen H, Sallmen M, . 1990. Spontaneous abortions among women exposed to organic solvents. Am J Ind Med 17:449–463.2327413
Litton Bionetics. 1978a. Teratology study in rats xylene (final report). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0205935.
Litton Bionetics. 1978b. Mutagenicity evaluation of xylene. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0205935.
Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Loizou GD, Jones K, Akrill P, . 1999. Estimation of the dermal absorption of m-xylene vapor in humans using breath sampling and physiologically based pharmacokinetic analysis. Toxicol Sci 48(2):170–179.10353308
Lonneman WA, Kopczynski SL, Darley PE, . 1974. Hydrocarbon composition of urban air pollution. Environ Sci Technol 8:229–236.
Lovegren N, Fisher GS, Legendre MG, . 1979. Volatile constituents of dried legumes. J Agric Food Chem 27:851–853.
Lysyj I, Perkins G, Farlow JS. 1980. Trace analysis for aromatic hydrocarbons in natural waters. Environ Int 4:407–416.
MacDonald AJ, Rostami-Hodjegan A, Tucker GT, . 2002. Analysis of solvent central nervous system toxicity and ethanol interactions using a human population physiologically based kinetic and dynamic model. Regul Toxicol Pharmacol 35:165–176.12052002
Mackay D, Leinonen PJ. 1975. Rate of evaporation of low-solubility contaminants from water bodies to atmosphere. Environ Sci Technol 9:1178–1180.
Maltoni C, Conti B, Cotti G. 1983. Benzene: A multipotential carcinogen: Results of long-term bioassays performed at the Bologna Institute of Oncology. Am J Ind Med 4:589–630.6353911
Maltoni C, Conti B, Cotti G, . 1985. Experimental studies on benzene carcinogenicity at the Bologna Institute of Oncology: Current results and ongoing research. Am J Ind Med 7:415–446.4003403
Marks TA, Ledoux TA, Moore JA. 1982. Teratogenicity of a commercial xylene mixture in the mouse. J Toxicol Environ Health 9:97–105.7062354
Martinez JS, Sala JJG, Vea AM, . 1989. Renal tubular acidosis with an elevated anion gap in a glue sniffer: Letter to editor. Human Toxicol 8:139–140.
Matiella JE, Hsieh CY. 1991. Volatile compounds in scrambled eggs. J Food Sci 56:387–390.
Mattie DR, Bates GD Jr., Jepson GW, . 1994. Determination of skin: air partition coefficients for volatile chemicals: Experimental method and applications. Fundam Appl Toxicol 22:51–57.8125213
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mayer GJ, Cheng IS, Pau P, . 1994. Emissions of air toxics from wastewater treatment plants. Water Environ Res 66:140–144.
McCarroll NE, Keech BJ, Piper CE. 1981a. A microsuspension adaptation of the Bacillus subtilis “rec” assay. Environ Mutagen 3:607–616.
McCarroll NE, Piper CE, Keech BH. 1981b. An E coli microsuspension assay for the detection of DNA damage induced by direct-acting agents and promutagens. Environ Mutagen 3:429–444.7021147
McDougal JN, Jepson GW, Clewell HJ, . 1990. Dermal absorption of organic chemical vapors in rats and humans. Fundam Appl Toxicol 14:299–308.2318354
Merian E, Zander M. 1982. Volatile aromatics. In: Hutzinger G, ed. Handbook of environmental chemistry. Vol. 3 (Pt B). Berlin, Germany: Springer, 117–161.
Mill T. 1980. Chemical and photo oxidation. In: Hutzinger O, ed. Handbook of environmental chemistry. Vol. 2. Berlin, Germany: Springer-Verlag, 77–105.
Minoia C, Meroni G, Aprea C, . 1996. Environmental and urinary reference values as markers of exposure to hydrocarbons in urban areas. Sci Total Environ 192:163–182.8956525
Mirkova E, Hinkova L, Vassileva L, . 1979. Xylene neurotoxicity in pregnant rats and fetuses. Act Nerv Super (Praha) 21:265–268.
Mirkova E, Zaikov C, Antov G, . 1983. Prenatal toxicity of xylene. J Hyg Epidemiol Microbiol Immunol 27:337–343.
Misharina TA, Golovnya RV. 1992. Hydrocarbon contaminants of boiled shrimp and crab meat. J High Resolut Chromatogr 15:332–334.
*Mobil Oil Company. 1975. Report on rabbit eye irritation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206126.
Moen BE, Hollund BE. 2000. Exposure to organic solvents among car painters in Bergen, Norway. Ann Occup Hyg 44(3):185–189.10775667
Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47:863–882.12079081
Mohtashamipur E, Northpoth K, Woelke U, . 1985. Effects of ethylbenzene, toluene, and xylene on the induction of micronuclei in bone marrow polychromatic erythrocytes of mice. Arch Toxicol 58:106–109.4091654
Molnar J, Paksy KA, Naray M. 1986. Changes in the rat’s motor behavior during 4-hr inhalation exposure to prenarcotic concentrations of benzene and its derivatives. Acta Physiol Hung 67:349–354.3751604
Morgan DL, Cooper SW, Carlock DL, . 1991. Dermal absorption of neat and aqueous volatile organic chemicals in the Fischer 344 rat. Environ Res 55:51–63.1855490
*Morikawa K, Fukuoka M, Kakiuchi M, . 1990. Detrusor hyperreflexia induced by intravesical instillation of xylene in conscious rats. Jpn J Pharmacol 52:587–595.1692889
Morin M, Chambon P, Chambon R, . 1981. Measurement of exposure to xylenes by separate determination of m- and p- methyl hippuric-acid in urine. J Chromatogr 210:346–349.7263793
Moriwaki H, Tsujimoto Y, Shimizu M, . 2005. Influence of sodium benzoate on the metabolism of o-xylene in the rat. Xenobiotica 35(5):487–497.16012080
Morley R, Eccleston DW, Douglas CP, . 1970. Xylene poisoning: A report on one fatal case and two cases of recovery after prolonged unconsciousness. Br Med J 3:442–443.5454325
Morozzi G, De Bartolomeo A, Fabiani R, . 1999. Induction of DNA damage and apoptosis by volatile organic compounds and by benzene metabolites. Ig Mod 112:1503–1513.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Morvai V, Hudak A, Ungvary G, . 1976. ECG changes in benzene, toluene and xylene poisoned rats. Acta Med Acad Sci Hung 33:275–286.1031554
Morvai V, Ungvary G, Herrmann HJ, . 1987. Effects of quantitative undernourishment, ethanol and xylene on coronary microvessels of rats. Acta Morphol Hung 35:199–206.3137783
Moser VC, Coggeshall EM, Balster RL. 1985. Effects of xylene isomers on operant responding and motor performance in mice. Toxicol Appl Pharmacol 80:293–298.4024118
Moszczynski P, Lisiewicz J. 1983. Occupational exposure to benzene, toluene and xylene and the T lymphocyte functions. J Clin Hematol Oncol 13:37–41.
Moszczynski P, Lisiewicz J. 1984a. Occupational exposure to benzene, toluene and xylene and the T lymphocyte functions. Haematologia 17:449–453.6335879
*Moszczynski P, Lisiewicz J. 1984b. [Cytochemical and immunological tests of those exposed to paint-and-varnish organic solvents: IV. Activity of nonspecific esterase in lymphocytes.] Med Pr 35:273–278. (Polish)6521638
Muralidhara, Krishnakumari MK. 1980. Mammalian toxicity of aromex and xylene used in pesticidal formulations. Indian J Exp Biol 18:1148–1151.6894291
Mushrush GW, Mose DG, Sullivan KT. 1994. Soil vapor and groundwater analysis from a recent oil spill. Bull Environ Contam Toxicol 52:31–38.8130414
*Nakajima T, Sato A. 1979a. Enhanced activity of liver drug-metabolizing enzymes for aromatic and chlorinated hydrocarbons following food deprivation. Toxicol Appl Pharm 50:549–556.
Nakajima T, Sato A. 1979b. [Metabolic antagonism among benzene, toluene and m-xylene in vitro.] Jpn J Ind Health 21:546–547. (Japanese)
Nakamura S, Oda Y, Shimada T, . 1987. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: Examination with 151 chemicals. Mutat Res 192:239–246.3317033
Narvaez J, Song CD. 2003. Letter to the editor. Cancer 22(5):495.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Nathwani JS, Phillips CR. 1977. Adsorption-desorption of selected hydrocarbons in crude oil in soils. Chemosphere 4:157–162.
NCI. 1985. Monograph on human exposure to chemicals in the workplace: Xylene. Bethesda, MD: National Cancer Institute, Division of Cancer Etiology. PB86155124.
Nelson KW, Ege JF Jr, Ross M, . 1943. Sensory response to certain industrial solvent vapors. J Ind Hyg Toxicol 25:282–285.
NEMI. 2005. Xylene. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. April 17, 2005.
Nersesian W, Booth H, Hoxie D, . 1985. Illness in office attributed to xylene [Letter]. Occup Health Saf 54:88.
NIOSH. 1975. Criteria for a recommended standard--occupational exposure to xylene. Rockville, MD: U.S. Department of Health, Education, and Welfare, Public Health Service, Center for Disease Control, National Institute for Occupational Safety and Health. NIOSH 75-168. PB246702.
NIOSH. 1976. National occupational hazard survey (1970). Cincinnati, OH: National Institute for Occupational Safety and Health, Department of Health and Human Services.
NIOSH. 1981. p-Xylene: Development of a biological standard for the industrial worker. Cincinnati, OH: National Institute for Occupational Safety and Health. PB82152844.
NIOSH. 1990a. Indoor air quality and work environment study. Volume 2: Results of indoor air environmental monitoring. Cincinnati, OH: U.S. Department of Health and Human Services, Hazards Evaluation and Technical Assistance Branch, National Institute for Occupational Safety and Health. PB92103183.
*NIOSH. 1990b. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHHS (NIOSH) Publ. No. 90-117.
NIOSH. 1990c. National occupational exposure survey (1980-83). Cincinnati, OH: National Institute for Occupational Safety and Health, Department of Health and Human Services.
NIOSH. 1994. NIOSH manual of analytical methods. 4th ed. U.S. Department of Health and Human Services. Methods 1501 and 8301.
NIOSH. 2005. Xylenes. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgdname.html. February 15, 2004.
Norstrom A, Scheepers PTJ. 1990. Determination of n-decane and m-xylene in blood using amberlite XAD-2. Chemosphere 21:459–466.
Norstrom A, Andersson B, Aringer L, . 1988. Determination of specific mercapturic acids in human urine after experimental exposure to toluene or o-xylene. In: Bartsch H, Hemminki K, O’Neill IK, eds. Methods for detecting DNA damaging agents in humans: Applications in cancer epidemiology and prevention; Symposium on detection of DNA-damaging agents in man. Lyon, France: World Health Organization, International Agency for Research on Cancer. IARC Sci Publ (89):232–234.
Norstrom A, Andersson B, Levin JO, . 1989. Biological monitoring of o-xylene after experimental exposure in man: Determination of urinary excretion products. Chemosphere 18:1513–1523.
NRC. 1980. Drinking water and health. Vol. 3. Washington, DC: National Research Council, National Academy Press, 178–181, 231–261.
NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
NTP. 1986. National Toxicology Program technical report on the toxicology and carcinogenesis studies of xylenes (mixed) (60% m-xylene, 14% p-xylene, 9% o-xylene, and 17% ethylbenzene) (CAS No. 1330-20-7) in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program. NTP TR 327. NIH Publication No. 87-2583.
NTP. 2005. Report on carcinogens. 11th ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. February 15, 2004.
Nunes P, Benville PJ. 1979. Uptake and depuration of petroleum hydrocarbons in the manila clam, tapes semidecussata reeve. Bull Environ Contam Toxicol 21:719–726.465754
Nutmagul W, Cronn DR, Hill HJ. 1983. Photoionization/flame-ionization detection of atmospheric hydrocarbons after capillary gas chromatography. Anal Chem 55:2160–2164.
Nylen P. 1996. Differing non-additive alterations in different parts of the nervous system of the rat. Food Chem Toxicol 34:1121–1123.9119324
Nylen P, Hagman M. 1994. Function of the auditory and visual systems, and of peripheral nerve, in rats after long-term combined exposure to n-hexane and methylated benzene derivatives. II. Xylene. Pharmacol and Toxicol 74:124–129.
Nylen P, Ebendal T, Eriksdotter-Nilsson M, . 1989. Testicular atrophy and loss of nerve growth factor-immunoreactive germ cell line in rats exposed to n-hexane and a protective effect of simultaneous exposure to toluene or xylene. Arch Toxicol 63: 296–307.2764718
Odermatt JR. 1994. Relative proportions of aromatic compounds (BTEX) in a gasoline impacted aquifer in San Diego County, California. Hydrocarbon Contam Soils Groundwater 4:33–45.
Ogata M, Miyake Y. 1978. Disappearance of aromatic hydrocarbons and organic sulfur compounds from fish flesh reared in crude oil suspension. Water Res 12:1041–1044.
Ogata M, Taguchi T. 1987. Quantitation of urinary metabolites of toluene, xylene, styrene, ethylbenzene, benzene and phenol by automated high performance liquid chromatography. Int Arch Occup Environ Health 59:263–272.3570490
Ogata M, Taguchi T. 1988. Simultaneous determination of urinary creatinine and metabolites of toluene, xylene, styrene, ethylbenzene and phenol by automated high performance liquid chromatography. Int Arch Occup Environ Health 61:131–140.3198279
Ogata M, Tomokuni K, Takatsuka Y. 1970. Urinary excretion of hippuric acid and m- or p-methylhippuric acid in the urine of persons exposed to vapours of toluene and m- or p-xylene as a test of exposure. Br J Ind Med 27:43–50.5418918
Ogata M, Yamasaki Y, Meguro T, . 1979. Quantitation of urinary o-xylene metabolites in rats and human beings by high-performance liquid chromatography. Ind Health 17:123–125.
Ogata M, Yamazaki Y, Sugihara R, . 1980. Quantitation of urinary o-xylene metabolites of rats and human beings by high performance liquid chromatography. Int Arch Occup Environ Health 46:127–139.7399721
Olson BA, Gamberale F, Iregren A. 1985. Coexposure to toluene and p-xylene in man: Central nervous functions. Br J Ind Med 42:117–122.3970870
O’Neil MJ, Smith A, Heckelman PE, , eds. 2001. The Merck index. An encyclopedia of chemicals, drugs, and biologicals. 13th ed. Whitehouse Station, NJ: Merck & Co, Inc., 1799.
OSHA. 2005a. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005c. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. February 15, 2005.
Otson R, Williams DT. 1981. Evaluation of a liquid-liquid extraction technique for water pollutants. J Chromatogr 212:187–197.
Otson R, Williams DT. 1982. Headspace chromatographic determination of water pollutants. Anal Chem 54:942–946.
*Otson R, Williams DT, Biggs DC. 1982a. Relationships between raw water quality, treatment, and occurrence of organics in Canadian potable water. Bull Environ Contam Toxicol 28:396–403.7093534
Otson R, Williams DT, Bothwell PD. 1982b. Volatile organic compounds in water at thirty Canadian potable water treatment facilities. J Assoc Off Anal Chem 65:1370–1374.
Otson R, Williams DT, Bothwell PD. 1983. Charcoal tube technique for simultaneous determination of selected organics. Am Ind Hyg Assoc J 44:489–494.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Padilla SS, Lyerly DP. 1989. Effects of p-xylene inhalation on axonal transport in the rat retinal ganglion cells. Toxicol Appl Pharmacol 101:390–398.2603159
Palmer KT, Rycroft RJG. 1993. Occupational airborne contact urticaria due to xylene. Contact Dermatitis 28:44.
Pap M, Varga C. 1987. Sister-chromatid exchanges in peripheral lymphocytes of workers occupationally exposed to xylenes. Mutat Res 187:223–225.3561431
Park SH, Schatz RA. 1999. Effect of low-level short-term o-xylene inhalation of benzo[a]pyrene (BaP) metabolism and BaP-DNA adduct formation in rat liver and lung microsomes. J Toxicol Environ Health A 58(5):299–312.10598955
Park SH, AuCoin TA, Silverman DM, . 1994. Time-dependent effects of o-xylene on rat lung and liver microsomal membrane structure and function. J Toxicol Environ Health 43(4):469–481.7990171
Patel JM, Harper C, Drew RT. 1978. The biotransformation of p-xylene to a toxic aldehyde. Drug Metab Dispos 6:368–374.28915
Patel JM, Harper C, Gupta BN, . 1979. Changes in serum enzymes after inhalation exposure of p-xylene. Bull Environ Contam Toxicol 21:17–24.36187
Pedersen BA, Higgins GM. 1995. Evaluation of chemical exposures in the hazardous waste industry. J Air Waste Manage Assoc 45:89–94.
Pelekis M, Gephart LA, Lerman SE. 2001. Physiological-model-based derivation of the adult and child pharmacokinetic intraspecies uncertainty factors for volatile organic compounds. Regul Toxicol Pharmacol 33:12–20.11259175
Pellizzari ED, Wallace LA, Gordon SM. 1992. Elimination kinetics of volatile organics in humans using breath measurements. J Expos Anal Environ Epidemiol 2:341–355.
Pellizzari ED, Zweidinger RA, Sheldon LS. 1988. Determination of benzene, toluene, and xylene in breath samples by gas chromatography/mass spectrometry. IARC Sci Publ (85):267–279.3182049
Perbellini L, Pasini F, Romani S, . 2002. Anaylsis of benzene, toluene, ethylbenzene and m-xylene in biological samples from the general population. J Chromatogr B Analyt Technol Biomed Life Sci 778:199–210.
*Pezzagno G, Imbriani M, Ghittori S, . 1988. Urinary concentration, environmental concentration, and respiratory uptake of some solvents: Effect of the work load. Am Ind Hyg Assoc J 49:546–52.3195471
Pierce CH, Dills RL, Silvey GW, . 1996. Partition coefficients between human blood or adipose tissue and air for aromatic solvents. Scand J Work Environ Health 22:112–118.8738889
Pleil JD, Oliver KD, McClenny WA. 1988. Ambient air analyses using nonspecific flame ionization and electron capture detection compared to specific detection by mass spectrometry. J Air Pollut Control Assoc 38:1006–1010.
Poggi G, Giusiani M, Palagi U, . 1982. High-performance liquid chromatography for the quantitative determination of the urinary metabolites of toluene, xylene, and styrene. Int Arch Occup Environ Health 50:25–31.7085085
Pool BL, Lin PZ. 1982. Mutagenicity testing in the Salmonella typhimurium assay of phenolic compounds and phenolic fractions obtained from smokehouse smoke condensates. Food Chem Toxicol 20:383–391.6751955
Poulin P, Krishnan K. 1996a. A tissue composition-based algorithm for predicting tissue: Air partition coefficients of organic chemicals. Toxicol Appl Pharmacol 136:126–130.8560465
Poulin P, Krishnan K. 1996b. A mechanistic algorithm for predicting blood: Air partition coefficients of organic chemicals with the consideration of reversible binding in hemoglobin. Toxicol Appl Pharmacol 136:131–137.8560466
Pound AW. 1970. Induced cell proliferation and the initiation of skin tumor formation in mice by ultraviolet light. Pathology 2:269–275.5520772
Pound AW, Withers HR. 1963. The influence of some irritant chemicals and scarification on tumor initiation by urethane in mice. Br J Cancer 17:460–470.14062492
Pratt GC, Palmer K, Wu CY, . 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825.11017885
Pryor GT, Rebert CS, Howd RA. 1987. Hearing loss in rats caused by inhalation of mixed xylene and styrene. J Appl Toxicol 7:55–61.3611598
Pyykko K. 1980. Effects of methylbenzenes on microsomal enzymes in rat liver, kidney and lung. Biochim Biophys Acta 633:1–9.6778508
Quigley CJ, Corsi RL. 1995. Emissions of VOCs from a municipal sewer. J Air Waste Manage Assoc 45:395–403.
Raaschou-Nielsen O, Lohse C, Thomsen BL, . 1997. Ambient air levels and the exposure of children to benzene, toluene, and xylenes in Denmark. Environ Res 75(2):149–159.9417846
Ramarathnam N, Rubin LJ, Diosady LL. 1991. Studies on meat flavor. 2. A quantitative investigation of the volatile carbonyls and hydrocarbons in uncured and cured beef and chicken. J Agric Food Chem 39:1839–1847.
Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
Rank J. 1985. Xylene induced feeding and drinking behavior and central adrenergic receptor binding. Neurobehav Toxicol Teratol 7:421–426.3001550
Rankin C, Sacks R. 1991. Computer-controlled, high speed, repetitive gas chromatography system. LC-GC 9:428, 430, 432–434.
Ransley DL. 1984. Xylenes and ethylbenzene. In: Grayson M, ed. Kirk-Othmer encyclopedia of chemical technology. Vol. 24, 3rd ed. New York, NY: John Wiley & Sons, 709–744.
Rasheed A, Hines RN, McCarver-May DG. 1997. Variation in induction of human placental CYP2E1: Possible role in susceptibility to fetal alcohol syndrome? Toxicol Appl Pharmacol 144:396–400.9194424
Rathbun RE. 1998. Transport, behavior, and fate of volatile organic compounds in streams. In: Transport, behavior, and fate of volatile organic compounds in streams. Washington, DC: U.S. Geological Survey Professional Paper 1589.
Rebert CS, Schwartz RW, Svendsgaard DJ, . 1995. Combined effect of paired solvents on the rat’s auditory system. Toxicology 105:345–354.8571371
Recchia G, Perbellini L, Prati GF, . 1985. [Coma due to accidental ingestion of xylene: Treatment with charcoal hemoperfusion.] Med Lav 76:67–73. (Italian)4010616
Reisch MS. 1992. Top 50 chemicals production stagnated last year. Chem Eng News 70:16–22.
Rembold H, Wallner P, Nitz S, . 1989. Volatile components of chickpea (Cicer arietinum L.) seed. J Agric Food Chem 37:659–662.
Reusser DE, Istok JD, Beller HR, . 2002. In situ transformation of deuterated toluene and xylene to benzylsuccinic acid analogues in BTEX-contamination aquifers. Environ Sci Technol 36:4127–4134.12380085
Richer C-L, Chakrabarti S, Senecal-Quevillon M, . 1993. Cytogenetic effects of low-level exposure to toluene, xylene and their mixture on human blood lymphocytes. Int Arch Occup Environ Health 64:581–585.8314617
Riediker M, Williams R, Devlin R, . 2003. Exposure to particulate matter, volatile organic compounds, and other sir pollutants inside patrol cars. Environ Sci Technol 37:2084–2093.12785511
*Riihimaki V. 1979a. Conjugation and urinary excretion of toluene and m-xylene metabolites in a man. Scand J Work Environ Health 5:135–142.472684
Riihimaki V. 1979b. Percutaneous absorption of m-xylene from a mixture of m-xylene and isobutyl alcohol in man. Scand J Work Environ Health 5:143–150.472685
Riihimaki V, Hanninen O. 1987. Xylenes. In: Browning E. Toxicity and metabolism of industrial solvents. Vol. 1. Amsterdam: Elsevier Science Publishers B.V., 64–84.
Riihimaki V, Pfaffli P. 1978. Percutaneous absorption of solvent vapors in man. Scand J Work Environ Health 4:73–85.644269
Riihimaki V, Savolainen K. 1980. Human exposure to m-xylene: Kinetics and acute effects on the central nervous system. Ann Occup Hyg 23:411–422.7258933
Riihimaki V, Laine A, Savolainen K, . 1982a. Acute solvent-ethanol interactions with special references to xylene. Scand J Work Environ Health 8:77–79.7134927
Riihimaki V, Pfaffli P, Savolainen K. 1979a. Kinetics of m-xylene in man: Influence of intermittent physical exercise and changing environmental concentrations on kinetics. Scand J Work Environ Health 5:232–248.20120571
Riihimaki V, Pfaffli P, Savolainen K, . 1979b. Kinetics of m-xylene in man: General features of absorption, distribution, biotransformation and excretion in repetitive inhalation exposure. Scand J Work Environ Health 5:217–231.20120570
Riihimaki V, Savolainen K, Pfaffli P, . 1982b. Metabolic interaction between m-xylene and ethanol. Arch Toxicol 49:253–263.7092564
Roberts JM, Fehsenfeld FC, Liu SC, . 1984. Measurements of aromatic hydrocarbon ratios and NOx concentrations in the rural troposphere: Observation of air mass photochemical aging and NOx removal. Atmos Environ 18:2421–2432.
Roberts FP, Lucas EG, Marsden CD, . 1988. Near-pure xylene causing reversible neuropsychiatric disturbance [Letter]. Lancet 2(8605):273.
Rogers JV, Gunasekar PG, Garrett CM, . 2001. Dermal exposure to m-xylene leads to increasing oxidative species and low molecular weight DNA levels in rat skin. J Biochem Mol Toxicol 15(4):228–230.11673852
Romer KG, Federsel RJ, Freundt KJ. 1986. Rise of inhaled toluene, ethyl benzene, m-xylene, or mesitylene in rat blood after treatment with ethanol. Bull Environ Contam Toxicol 37:874–876.3790759
Romieu I, Ramirez M, Meneses F, . 1999. Environmental exposure to volatile organic compounds among workers in Mexico City assessed by personal monitors and blood concentrations. Environ Health Perspect 107:511–515.10378996
Rosen MB, Crofton KM, Chernoff N. 1986. Postnatal evaluation of prenatal exposure to p-xylene in the rat. Toxicol Lett 34:223–229.3798481
Rosengren LE, Kjellstrand P, Aurell A, . 1986. Irreversible effects of xylene on the brain after long term exposure: A quantitative study of DNA and the glial cell marker proteins S-100 and GFA. Neurotoxicology 7:121–136.
Roy WR. 1994. Groundwater contamination form municipal landfills in the USA. In: Adriano DC, ed. Contamination of groundwaters: Case studies. Northwood, UK: Scientific Review, 411–446.
RTECS. 2007. Xylene. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. May 14, 2007.
*Rumsey TS, Cabell CA, Bond J. 1969. Effects of an organic phosphorus systemic insecticide on reproductive performance in rats. Am J Vet Res 30: 2209–2214.5353068
Rydzynski K, Korsak Z, Jedlinska U, . 1992. The toxic effects of combined exposure to toluene and m-xylene in animals. IV. Liver ultrastructure after subchronic inhalatory exposure. Polish J Occup Med Environ Health 5(1):35–42.
Sack TM, Steel DH, Hammerstrom K, . 1992. A survey of household products for volatile organic-compounds. Atmos Environ A Gen Top 26:1063–1070.
Saillenfait AM, Gallissot F, Morel G, . 2003. Developmental toxicities of ethylbenzene, ortho-, meta-, para-xylene and technical xylenes in rats following inhalation exposure. Food Chem Toxicol 41:415–429.12504174
Sanborn HR, Malins DC. 1980. The disposition of aromatic hydrocarbons in adult spot shrimp (Pandalus piatyceros) and the formation of metabolites of naphthalene in adult and larval spot shrimp. Xenobiotica 10:193–200.7467403
Sandmeyer EE. 1981. Aromatic hydrocarbons. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. 2B. 3rd ed. New York, NY: John Wiley & Sons, 3253–3431.
Sanemasa I, Araki M, Deguchi T, . 1982. Solubility measurements of benzene and the alkylbenzenes in water by making use of solute vapor. Bull Chem Soc Jpn 55:1054–1062.
Sato A. 1988. Toxicokinetics of benzene, toluene and xylenes. IARC Sci Publ (85):47–64.3053448
Sato A, Nakajima T. 1979. Partition coefficients of some aromatic hydrocarbons and ketones in water, blood and oil. Br J Ind Med 36:231–234.500783
Sauer TJ, Sackett WM, Jeffrey LM. 1978. Volatile liquid hydrocarbons in the surface coastal waters of the Gulf of Mexico. Marine Chem 7:1–16.
Saunders RA, Blachly CH, Kovacina TA, . 1975. Identification of volatile organic contaminants in Washington, D.C. municipal water. Water Res 9:1143–1145.
Savolainen K. 1980. Combined effects of xylene and alcohol on the central nervous system. Acta Pharmacol Toxicol 46:366–372.
Savolainen K, Linnavuo M. 1979. Effects of m-xylene on human equilibrium measured with a quantitative method. Acta Pharmacol Toxicol 44:315–318.
Savolainen H, Pfaffli P. 1980. Dose-dependent neurochemical changes during short-term inhalation exposure to m-xylene. Arch Toxicol 45:117–122.7469788
Savolainen H, Seppalainen AM. 1979. Biochemical and physiological effects of organic solvents on rat axon membranes isolated by a new technique. Neurotoxicology 1:467–477.
Savolainen K, Riihimaki V. 1981a. An early sign of xylene effect on human equilibrium. Acta Pharmacol Toxicol 48:279–283.
Savolainen K, Riihimaki V. 1981b. Xylene and alcohol involvement of the human equilibrium system. Acta Pharmacol Toxicol 49:447–451.
Savolainen H, Pfaffli P, Helojoki M, . 1979a. Neurochemical and behavioral effects of long-term intermittent inhalation. Acta Pharmacol Toxicol 44:200–207.
Savolainen H, Vainio H, Helojoki M, . 1978. Biochemical and toxicological effects of short-term, intermittent xylene inhalation exposure and combined ethanol intake. Arch Toxicol 41:195–205.736790
Savolainen K, Kekoni J, Riihimaki V, . 1984. Immediate effects of m-xylene on the human central nervous system. Arch Toxicol 7(Suppl):412–417.
Savolainen K, Riihimaki V, Laine A. 1982a. Biphasic effects of inhaled solvents on human equilibrium. Acta Pharmacol Toxicol 51:237–242.
Savolainen K, Riihimaki V, Laine A, . 1982b. Short-term exposure of human subjects to m-xylene and 1,1,1-trichloroethane. Arch Toxicol 5(Suppl):96–99.
Savolainen K, Riihimaki V, Linnoila M. 1979b. Effects of short-term xylene exposure on psychophysiological functions in man. Int Arch Occup Environ Health 44:201–211.536046
Savolainen K, Riihimaki V, Luukkonen R, . 1985a. Changes in the sense of balance correlate with concentrations of m-xylene. Br J Ind Med 42:765–769.4063219
*Savolainen K, Riihimaki V, Muona O, . 1985b. Conversely exposure-related effects between atmospheric m-xylene concentrations and human body sense of balance. Acta Pharmacol Toxicol 57:67–71.
Savolainen K, Riihimaki V, Seppalainen AM, . 1980a. Effects of short-term m-xylene exposure and physical exercise on the central nervous system. Int Arch Occup Environ Health 45:105–121.7364487
Savolainen K, Riihimaki V, Vaheri E, . 1980b. Effects of xylene and alcohol on vestibular and visual functions in man. Scand J Work Environ Health 6:94–103.6968975
Schauer J, Kleeman MJ, Cass GR, . 1999. Measurement of emissions from air pollution sources. 2. C1 through C29 organic compounds from medium duty diesel trucks. Environ Sci Technol 33:1578–1587.
Schauer JJ, Kleeman MJ, Cass GR, . 2001. Measurement of emissions from air pollution sources 3 C1-C29 organic compounds for fireplace combustion of wood. Environ Sci Technol 35:1716–1728.11355184
Schauer JJ, Kleeman MJ, Cass GR, . 2002. Measurement of emissions from air pollution sources. C_1_-C_32_ organic compounds from gasoline-powered motor vehicles. Environ Sci Technol 36:1169–1180.11944666
*Sedivec V, Flek J. 1976a. Exposure test for xylenes. Int Arch Occup Environ Health 37:219–232.977142
Sedivec V, Flek J. 1976b. The absorption, metabolism, and excretion of xylenes in man. Int Arch Occup Environ Health 37:205–217.977141
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratog Carcinog Mutagen 6:361–374.2878502
Seifert B, Abraham H-J. 1982. Indoor air concentrations of benzene and some other aromatic hydrocarbons. Ecotoxicol Environ Saf 6:190–192.
Seip HM, Alstad J, Carlberg GE, . 1986. Measurement of mobility of organic compounds in soils. Sci Total Environ 50:87–101.
Selgrade MJ, Daniels MJ, Jaskot RH, . 1993. Enhanced mortality and liver damage in virus-infected mice exposed to p-xylene. J Toxicol Environ Health 40:129–144.8395606
Senczuk W, Orlowski J. 1978. Absorption of m-xylene vapours through the respiratory track and excretion. Br J Ind Med 35:50–55.629889
Seppalainen AM, Laine A, Salmi T, . 1989. Changes induced by short-term xylene exposure in human evoked potentials. Int Arch Environ Health 61:443–449.
Seppalainen AM, Laine A, Salmi T, . 1991. Electroencephalographic findings during experimental human exposure to meta-xylene. Arch Environ Health 46:16–24.1992928
Seppalainen AM, Salmi T, Savolainen K, . 1983. Visual evoked potentials in short-term exposure of human subjects to m- xylene and 1,1,1-trichloroethane. Appl Behav Pharmacol Toxicol 1983:349–352.
*Seppalainen AM, Savolainen K, Kovala T. 1981. Changes induced by xylene and alcohol in human evoked potentials. Electroencephalogr Clin Neurophysiol 51:148–155.6161788
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Sevcik P, Hep A, Peslova M. 1992. Intravenous xylene poisoning. Intensive Care Med 18:377–378.1469168
Sexton K, Adgate JL, Fredrickson AL, . 2006. Using biologic markers in blood to assess exposure to multiple environmental chemicals for inner-city children 3-6 years of age. Environ Health Perspect 114(3):453–459.16507471
Shepson PB, Edney EO, Corse EW. 1984. Ring fragmentation reactions on the photooxidations of toluene and o-xylene. J Phys Chem 88:4122–4126.
Shields HC, Fleischer DM, Weschler CJ. 1996. Comparisons among VOCs measured in three types of U.S. commercial buildings with different occupant densities. Indoor Air 6:2–17.
Shimizu H, Suzuki Y, Takemura N, . 1985. The results of microbial mutation test for forty-three industrial chemicals. Jpn J Ind Health 27:400–419.
Silverman DM, Schatz RA. 1991. Pulmonary microsomal alterations following short-term low-level inhalation of para-xylene in rats. Toxicology 65:271–281.1992561
Simmons JE, Allis JW, Grose EC, . 1991. Assessment of the hepatotoxicity of acute and short-term exposure to inhaled p-xylene in F-344 rats. J Toxicol Environ Health 32:295–306.2002513
Singh HB, Salas LJ, Cantrell Bk, . 1985. Distribution of aromatic hydrocarbons in the ambient air. Atmos Environ 11:1911–1919.
Singh M. 2006. Written communication (August 29, 2006) to Margaret Fransen, Syracuse Research Corporation, regarding ortho-xylene.
Skender LJ, Karacic V, Bosner B. 1993. A selection of biological indicators in occupational exposure to toluene and xylene. Arch Ind Hyg Toxicol 44:27–33.
Skowronski GA, Turkall RM, Kadry AR, . 1990. Effects of soil on the dermal bioavailability of m-xylene in male rats. Environ Res 51:182–193.2335159
Smith BR, Plummer JL, Wolf CR, . 1982. p-Xylene metabolism by rabbit lung and liver and its relationship to the selective destruction of pulmonary cytochrome P-450. J Pharmacol Exp Ther 223:736–742.7143236
Smolik R, Grzybek-Hryncewicz K, Lange A, . 1973. Serum complement level in workers exposed to benzene, toluene and xylene. Int Arch Arbeitsmed 31:243–247.4784739
Smyth HJ, Carpenter CP, Weil CS, . 1962. Range-finding toxicity data: List VI. Am Ind Hyg Assoc J 23:95–107.13914538
Sollinger S, Levsen K, Wunsch G. 1994. Indoor pollution by organic emissions from textile floor coverings: Climate test chamber studies under static conditions. Atmos Environ 28:2369–2378.
Sovik AK, Alfnes E, Breedveld GD, . 2002. Transport and degradation of toluene and o-xylene in an unsaturated soil with dipping sedimentary layers. J Environ Qual 31:1809–1823.12469830
Spicer CW, Buxton BE, Holdren MW, . 1996. Variability of hazardous air pollutants in an urban area. Atmos Environ 30:3443–3456.
Spirtas R, Stewart PA, Lee JS, . 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. I. Epidemiological results. Br J Ind Med 48:515–530.1878308
Squillace PJ, Moran MJ, Lapman WW, . 1999. Volatile organic compounds in untreated ambient groundwater of the United States, 1985-1995. Environ Sci Technol 33(23):4176–4187.
SRI. 2006. Directory of chemical producers: United States of America. Menlo Park, CA: SRI Consulting.
Stefaniak AB, Breysse PN, Murray MPM, . 2000. An evaluation of employee exposure to volatile organic compounds in three photocopy centers. Environ Res 83:162–173.10856189
Stewart PA, Lee JS, Marano DE, . 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. II. Exposures and their assessment. Br J Ind Med 48:531–537.1878309
Stickney JA, Roberts AE, Silverman DM, . 1989. The effect of m-xylene on rat lung benzo[a]pyrene metabolism and microsomal membrane lipids: Comparison with p-xylene. Toxicology 58:155–165.2799823
Stickney JA, Silverman DM, Schatz RA. 1991. Role of isozyme-specific inhibition of cytochrome-P450IIB1 activity in meta-xylene-induced alterations in rat pulmonary benzo(a)pyrene metabolism. Xenobiotica 21:641–649.1949897
Storm DL. 1994. Chemical monitoring of California’s public drinking water sources: Public exposures and health impacts. In: Wang RGM, ed. Water contamination and health: Integration of exposure assessment, toxicology, and risk assessment. New York: Marcel Dekker, Inc., 67–124.
Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 298–299.
Sugihara R, Ogata M. 1978. Quantitation of urinary m- and p-methylhippuric acids as indices of m- and p-xylene exposure. Int Arch Occup Environ Health 41:281–286.680988
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ration, and water solubility. Residue Rev 85:17–28.
Sweet CW, Vermette SJ. 1992. Toxic volatile organic compounds in urban air in Illinois. Environ Sci Technol 26:165–173.
Swiercz R, Lorsak Z, Rydzynski K. 1995. Kinetics of n-butyl alcohol and m-xylene in blood during single and combined inhalation exposure in rats. Int J Occup Med Environ Health 8(4):361–365.8907414
Szybalski W. 1958. Special microbiological systems: II. Observations on chemical mutagenesis in microorganisms. Ann NY Acad Sci 76:465–489.
Takagi H, Washida N, Akimoto H, . 1980. Photooxidation of o-xylene in the NO-H_2_O-air system. J Phys Chem 84:478–483.
Tahti H. 1992. The neurotoxicity of organic-solvents, studied with in vitro models. Altern Lab Anim 20:290–296.
Takeoka GR, Flath RA, Guntert M, . 1988. Nectarine volatiles: Vacuum steam distillation versus headspace sampling. J Agric Food Chem 36:553–560.
Takeuchi A, Kawai T, Zhang ZW, . 2002. Toluene, xylenes and xylene isomers in urine as biological indicators of low-level exposure to each solvent; a comparative study. Int Arch Occup Environ Health 75:387–393.12070634
Tanaka M, Shimizu M, Tsujimoto Y. 1990. High-performance liquid chromatographic determination of urinary mercapturic acids in rat. J Chromatogr 526:289–292.2341541
Tang J, Jin QZ, Shen G-H, . 1983. Isolation and identification of volatile compounds from fried chicken. J Agric Food Chem 31:1287–1292.
Tansel B, Eyma RR. 1999. Volatile organic contaminant emissions from wastewater treatment plants during secondary treatments. Water Air Soil Pollut 112:315–325.
Tardif R, Charest-Tardif G. 1999. The importance of measured end-points in demonstrating the occurrence of interactions: A case study with methylchloroform and m-xylene. Toxicol Sci 49:312–317.10416277
Tardif R, Brodeur J, Plaa GL. 1989. Simultaneous high-performance liquid chromatographic analysis of hippuric acid and ortho-, meta-, and para-methylhippuric acids in urine. J Anal Toxicol 13:313–316.2607759
Tardif R, Charest-Tardif G, Brodeur J. 1996. Comparison of the influence of binary mixtures versus a ternary mixture of inhaled aromatic hydrocarbons on their blood kinetics in the rat. Arch Toxicol 70:405–413.8740534
Tardif R, Charest-Tarif G, Brodeur J, . 1997. Physiologically based pharmacokinetic modeling of a ternary mixture of alkyl benzenes in rats and humans. Toxicol Appl Pharmacol 144:120–134.9169076
Tardif R, Lapar S, Charest-Tardif G, . 1995. Physiologically-based pharmacokinetic modeling of a mixture of toluene and xylene in humans. Risk Anal 15(3):335–342.7604167
Tardif R, Lapare S, Krishnan K, . 1993a. Physiological based modeling of the toxicokinetic interaction between toluene and m-xylene in the rat. Toxicol Appl Pharmacol 120:266–273.8511796
Tardif R, Lapare S, Krishnan K, . 1993b. A descriptive and mechanistic study of the interaction between toluene and xylene in humans. Int Arch Occup Environ Health, 65:S135–S137.8406910
Tardif R, Lapare S, Plaa GL, . 1991. Effect of simultaneous exposure to toluene and xylene on their respective biological exposure indices in humans. Int Arch Occup Environ Health 63:279–284.1743770
Tardif R, Plaa GL, Brodeur J. 1992. Influence of various mixtures of inhaled toluene and xylene on the biological monitoring of exposure to these solvents in rats. Can J Physiol Pharmacol 70:385–393.1600471
Tardif R, Sato A, Lapare S, . 1994. Ethanol induced modification of m-xylene toxicokinetics in humans. Occup Environ Med 51:187–191.8130847
Taskinen H, Anttila A, Lindbohm ML, . 1989. Spontaneous abortions and congenital malformations among the wives of men occupationally exposed to organic solvents. Scand J Work Environ Health 15:345–352.2799322
Taskinen H, Kyyronen P, Hemminki K, . 1994. Laboratory work and pregnancy outcome. J Occup Med 36(3):311–319.8195901
Tassaneeyakul W, Birkett DJ, Edwards JW, . 1996. Human cytochrome P450 isoform specificity in the regioselective metabolism of toluene and o-, m- and p-xylene. J Pharmacol Exp Ther 276(1):101–108.8558417
Tatrai E, Ungvary G. 1980. Changes induced by o-xylene inhalations in the rat liver. Acta Med Acad Sci Hung 37:211–216.7457028
Tatrai E, Ungvary G, Cseh IR, . 1981. The effects of long-term inhalation of ortho-xylene on the liver. Ind Enviv Xenobiotica, Proceedings of International Conference, Prague, Czechoslovakia, May 27-30, 1980. New York, NY: Springer-Verlag, 293–300.
Teschke K, Ahrens W, Andersen A, . 1999. Occupational exposure to chemical and biological agents in the nonproduction departments of pulp, paper, and paper product mills: An international study. Am Ind Hyg Assoc J 60:73–83.10028618
Thierrin J, David GB, Barber C. 1995. A ground-water tracer test with deuterated compounds for monitoring in situ biodegradation and retardation of aromatic hydrocarbons. Ground Water 33(3):469–475.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thrall KD, Gies RA, Muniz J, . 2002. Route-of-entry and brain tissue partition coefficients for common superfund contaminants. J Toxicol Environ Health A 65(24):2075–2086.12515587
Thrall KD, Poet TS, Corley RA, . 2000. A real-time in-vivo method for studying the percutaneous absorption of volatile chemicals. Int J Occup Environ Health 6(2):96–103.10828137
Thrall KD, Woodstock AD. 2003. Evaluation of the dermal bioavailability of aqueous xylene in F344 rats and human volunteers. J Toxicol Environ Health A 66:1267–1281.12851123
Toftgard R, Gustafsson J-A. 1980. Biotransformation of organic solvents: A review. Scand J Work Environ Health 6:1–18.
Toftgard R, Nilsen OG. 1981. Induction of cytochrome P-450 in rat liver after inhalation of aromatic organic solvents. In: Industrial and environmental xenobiotics: Metabolism and pharmacokinetics of organic chemicals and metals: Proceedings of International Conference, Prague, Czechoslovakia, May 27-30, 1980. New York, NY: Springer-Verlag, 307–317.
Toftgard R, Nilsen OG. 1982. Effects of xylene and xylene isomers on cytochrome P-450 and in vitro enzymatic activities in rat liver, kidney, and lung. Toxicology 23:197–212.7112593
Toftgard R, Nilsen OG, Gustafsson J-A. 1981. Changes in rat liver microsomal cytochrome P-450 and enzymatic activities after the inhalation of n-hexane, xylene, methyl ethyl ketone and methylchloroform for four weeks. Scand J Work Environ Health 7:31–37.7313607
Tran NK, Steinberg SM, Johnson BJ. 2000. Volatile aromatic hydrocarbons and dicarboxylic acid concentrations in air at an urban site in the southwestern US. Atmos Environ 34:1845–1852.
TRI04. 2006. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. July 10, 2006.
Triebig G, Barocka A, Erbguth F, . 1992a. Neurotoxicity of solvent mixtures in spray painters. II. Neurologic, psychological, and neuroradiologic findings. Int Arch Occup Environ Health 64:361–372.1487334
Triebig G, Schaller KH, Weltle D. 1992b. Neurotoxicity of solvent mixtures in spray painters. I. Study, design, workplace exposure, and questionnaire. Int Arch Occup Environ Health 64(5):353–359.1487333
Trost B, Stutz J, Platt U. 1997. UV-absorption cross sections of a series of monocylic aromatic compounds. Atmos Environ 31(23):3999–4008.
Tsao CW, Song HG, Bartha AR. 1998. Metabolism of benzene, toluene, and xylene hydrocarbons in soil. Appl Environ Microbiol 64:4924–4929.9835584
Tsuruta H. 1982. Percutaneous absorption of organic solvents: III. On the penetration rates. Ind Health 20:335–345.7153067
Tsuruta H, Iwasaki K. 1984. A procedure for determining volatile solvents in mouse whole body. Ind Health 22:219–222.6501007
Tuazon EC, McLeod H, Atkinson R, . 1986. α-Dicarbonyl yields from the NOx-air photooxidation of a series of aromatic hydrocarbons in air. Environ Sci Technol 20:383–393.22300209
Turkall RM, Skowronski GA, Kadry ARM, . 1992. Sex-differences in the bioavailability of soil-adsorbed meta-xylene in orally exposed rats. Toxicol Lett 63:57–67.1412523
Uchida Y, Nakatsuka H, Ukai H, . 1993. Symptoms and signs in workers exposed predominantly to xylenes. Int Arch Occup Environ Health 64:597–605.8314620
Ungvary G. 1985. The possible contributions of industrial chemicals (organic solvents) to the incidence of congenital defects caused by teratogenic drugs and consumer goods-an experimental study. Prog Clin Biol Res 160:295–300.
Ungvary G. 1990. The effect of xylene exposure on the liver. Acta Morphol Hung 38:245–258.2102606
Ungvary G, Tatrai E. 1985. On the embryotoxic effects of benzene and its allkyl derivatives in mice, rats, and rabbits. Arch Toxicol (Supplement) 8:425–430.
Ungvary G, Cseh J, Manyai S, . 1980a. Enzyme induction by o-xylene inhalation. Acta Med Acad Sci Hung 37:115–120.7457013
Ungvary G, Tatrai E, Hudak A, . 1980b. Studies on the embryotoxic effects of ortho-, meta- and para-xylene. Toxicology 18:61–74.7210024
Ungvary G, Varga B, Horvath E, . 1981. Study on the role of maternal sex steroid production and metabolism in the embryotoxicity of para-xylene. Toxicology 19:263–268.7233451
USDOC. 2005. U.S. Trade quick reference tables. U.S. Department of Commerce, Bureau of the Census, Foreign Trade Division. http://www.ita.doc.gov/td/industry/otea/Trade-Detail/. January 23, 2007.
USITC. 1991. Synthetic organic chemicals: United States production and sales, 1990. Washington, DC: U.S. International Trade Commission. USITC Publication 2470.
Vaidyanathan A, Foy JWD, Schats RA. 2003. Inhibition of rat respiratory-tract cytochrome P-450 isozymes following inhalation of m-xylene: Possible role of metabolites. J Toxicol Environ Health A 66(12):1133–1143.12791539
van Doorn R, Bos RP, Brouns RME, . 1980. Effect of toluene and xylenes on liver glutathione and their urinary excretion as mercapturic acids in the rat. Arch Toxicol 43:293–304.7387389
VCCEP. 2006. Report of the peer consultation meeting on xylenes. Erlanger, KY: American Chemistry Council Benzene, Toluene, and Xylenes Consortium for the Volunary Children’s Chemical Evaluation Program. http://www.tera.org/peer/vccep. October 01, 2006.
Verschueren K. 2001. Xylene. Handbook of environmental data on organic chemicals. New York, NY: John Wiley & Sons, Inc., 2189–2195.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vincent R, Poirot P, Subra I, . 1994. Occupational exposure to organic solvents during paint stripping and painting operations in the aeronautical industry. Int Arch Occup Environ Health 65:377–380.8034362
Vodickova L, Frantik E, Vodickova A. 1995. Neutrotropic effects and blood levels of solvents at combined exposures: Binary mixtures of toluene, o-xylene and acetone in rats and mice. Cent Eur J Public Health 3(2):57–64.
Von Burg R. 1982. Toxicology updates: Xylene. J Appl Toxicol 2:269–271.7184948
Wallace L, Nelson W, Ziegenfus R, . 1991. The Los Angeles team study: Personal exposures, indoor-outdoor air concentrations, and breath concentrations of 25 volatile organic compounds. J Exposure Anal Environ Epidemiol 1:157–142.
Wallace L, Pellizzari E, Hartwell T, . 1986. Concentrations of 20 volatile organic compounds in the air and drinking water of 350 residents of New Jersey compared with concentrations in their exhaled breath. J Occup Med 28:603–608.3746480
Wallace L, Pellizzari E, Hartwell T, . 1987a. Exposures to benzene and other volatile compounds from active and passive smoking. Arch Environ Health 42:272–279.3452294
Wallace L, Pellizzari E, Hartwell T, . 1987b. The TEAM study: Personal exposures to toxic substances in air, drinking water, and breath of 400 residents of New Jersey, North Carolina, and North Dakota. Environ Res 43:290–307.3608934
Wallace L, Pellizzari E, Hartwell T, . 1988. The California team study: Breath concentrations and personal exposures to 26 volatile compounds in air and drinking water of 188 residents of Los Angeles, Antioch, and Pittsburg, CA. Atmos Environ 22:2141–2163.
Wallen M, Holm S, Byfalt Nordqvist M. 1985. Coexposure to toluene and p-xylene in man: Uptake and elimination. Br J Ind Med 42:111–116.3970869
Wang W, Liszewski M, Buchmiller R. 1995. Occurrence of active and inactive herbicide ingredients at selected sites in Iowa. Water Air Soil Pollut 83:21–35.
Washington WJ, Murthy RC, Doye A, . 1983. Induction of morphologically abnormal sperm in rats exposed to o-xylene. Arch Androl 11:233–237.6660973
Weidemeier TH, Swanson MA, Wilson JT, . 1995. Patterns of intrinsic bioremediation at two U.S. Air Force Bases. In: Hinchee RE, eds. Intrinsic bioremediation. Columbus, OH: Battelle Press, 31–51.
Weschler CJ, Shields HC, Rainer D. 1990. Concentrations of volatile organic compounds at a building with health and comfort complaints. Am Ind Hyg Assoc J 51:261–268.2346114
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Whitehead LW, Ball GL, Fine LJ, . 1984. Solvent vapor exposures in booth spray painting and spray glueing, and associated operations. Am Ind Hyg Assoc J 45:767–772.6507277
Whitman NE, Johnston AE. 1964. Sampling and analysis of aromatic vapors in air: A gas-liquid chromatographic method. Am Ind Hyg Assoc J 25:464–469.14209669
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/Activities/20050104_1. February 15, 2005.
WHO. 2004. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. February 15, 2005.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wilcosky TC, Checkoway H, Marshall EG, . 1984. Cancer mortality and solvent exposures in the rubber industry. Am Ind Hyg Assoc J 45:809–811.6549104
Williams DT, Nestmann ER, LeBel GL, . 1982. Determination of mutagenic potential and organic contaminants of Great Lakes drinking water. Chemosphere 11:263–276.
Wilson JT, Kampbell DH, Armstrong J. 1994. Natural bioreclamation of alkylbenzenes (BTEX) from a gasoline spill in methanogenic groundwater. In: Hinchee RE, ed. Hydrocarbon bioremediation. Boca Raton, FL: Lewis Publishers, 210–218.
Wilson SC, Jones KC. 1996. The fate and behavior of volatile aromatic hydrocarbons in sewage sludge-amended soil. In: Schnoor J, Doi J, eds. Volatile organic compounds in the environment. West Conshahocken, PA: American Society for Testing and Materials, 119–123.
Wilson SC, Alcock RE, Sewart AP, . 1997. Organic chemicals in the environment: Persistence of organic contaminants in sewage sludge-amended soil: A field experiment. J Environ Qual 26:1467–1477.
Wimolwattanapun S, Ghosh TK, Mookherjee S, . 1987. Effect of inhalation of xylene on intracranial self-stimulation behavior in rat. Neuropharmacology 26:1629–1632.3431665
Windham GC, Shusterman D, Swan SH, . 1991. Exposure to organic solvents and adverse pregnancy outcome. Am J Ind Med 20:241–259.1951371
Wisniewska-Knypl JM, Wronska-Nofer T, Jajte J, . 1989. The effect of combined exposures to ethanol and xylene on rat hepatic microsomal monooxygenase activities. Alcohol 6:347–352.2818836
Wolf MA, Rowe VK, McCollister DD, . 1956. Toxicological studies of certain alkylated benzenes and benzene: Experiments on laboratory animals. Arch Ind Health 14:387–398.
Wolfe GW. 1988a. Subchronic toxicity study in rats with m-xylene. Rockville MD: Dynamac Corporation.
Wolfe GW. 1988b. Subchronic toxicity study in rats with p-xylene. Rockville MD: Dynamac Corporation.
Wronska-Nofer T, Rosin J, Bartosz G. 1991. Interaction of ethanol and xylene in their effects on erythrocytes and other hematological parameters in the rat. J Appl Toxicol 11:289–292.1940003
Wu CM, Liou SE. 1992. Volatile components of water-boiled duck meat and Cantonese style roasted duck. J Agric Food Chem 40:838–841.
Yalkowsky SH, He Y. 1992. Handbook of aqueous solubility data. New York, NY: CRC Press, 490–493.
Zabiegala B, Namiesnik J, Przyk E, . 1999. Changes in concentration levels of selected VOCs in newly erected and remodeled buildings in Gdansk. Chemosphere 39(12):2035–2046.10576105
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zhong B, Baozhen, Tang, . 1980. A comparative study of the cytogenetic effects of benzene, toluene and xylene. Hereditas 2(2): 29–31.
Zielinska B, Fung KK. 1994. The composition and concentration of hydrocarbons in the range of C2 to C18 emitted from motor vehicles. Sci Total Environ 146/147:281–288.
Zielinska B, Fujita E, Sagebiel J, . 1998. Arizona hazardous air pollutants monitoring program. J Air Waste Manage Assoc 48:1038–1050.
Zimmermann R, Blumenstock M, Heger HJ, . 2001. Emission of nonchlorinated and chlorinated aromatics in the flue gas of incineration plants during and after transient disturbances of combustion conditions: Delayed emission effects. Environ Sci Technol 35:1019–1030.11347909