# 8 REGULATIONS AND ADVISORIES

The international and national regulations and guidelines regarding xylenes in air, water, and other media are summarized in Table 8-1.

ATSDR has derived inhalation and oral MRLs that apply to mixed xylenes and the individual isomers. An acute-duration inhalation MRL of 2 ppm is based on a minimal LOAEL of 50 ppm (217 mg/m^3^) for mild objective and subjective respiratory effects and subjective neurological effects in subjects exposed to m-xylene vapor for 2 hours (Ernstgard et al. 2002); an uncertainty factor of 30 was applied to the minimal LOAEL. An intermediate-duration inhalation MRL of 0.6 ppm is based on a minimal LOAEL of 50 ppm (217 mg/m^3^) for a small decrease in the latency of the paw-lick response in male rats exposed to m-xylene vapor 6 hours/day, 5 days/week for 3 months (Korsak et al. 1992); an uncertainty factor of 90 was applied to the human equivalent minimal LOAEL. A chronic-duration inhalation MRL of 0.05 ppm is based on a LOAEL of 14 ppm (geometric mean) for mild subjective respiratory and neurological symptoms in workers exposed to 70% xylene 8 hours/day, 5 days/week for 1–7 years (Uchida et al. 1993); an uncertainty factor of 100 and modifying factor of 3 was applied to the LOAEL. An acute-duration oral MRL of 1 mg/kg/day is based on a NOAEL of 125 mg/kg and a LOAEL of 250 mg/kg for alteration of visual evoked brain potentials in rats exposed to p-xylene for 45 minutes (Dyer et al. 1988); an uncertainty factor of 100 was applied to the NOAEL. An intermediate-duration oral MRL of 0.4 mg/kg/day is based on a NOAEL of 500 mg/kg/day (duration-adjusted, 360 mg/kg/day) and a LOAEL of 1,000 mg/kg/day (duration-adjusted, 710 mg/kg/day) for hyperactivity in mice immediately after oral gavage dosing with mixed xylene (plus 17% ethylbenzene) 5 days/week during weeks 4–51 of a 2-year study (NTP 1986); an uncertainty factor of 100 was applied to the duration-adjusted NOAEL. In addition, a modifying factor of 10 was applied to account for the lack of testing for sensitive neurological effects and lack of developmental and multi-generational data. A chronic-duration oral MRL of 0.2 mg/kg/day is based on a NOAEL of 250 mg/kg/day (duration-adjusted, 179 mg/kg/day) for the lack of any overt neurological toxicity or systemic toxicity in rats that received oral gavage doses of mixed xylene (plus 17% ethylbenzene) 5 days/week for 2 years (NTP 1986); an uncertainty factor of 100 was applied to the duration-adjusted NOAEL of 179 mg/kg/day. In addition, a modifying factor of 10 was applied for the lack of testing for sensitive neurological end points and lack of developmental and multi-generational data. Specific details about the MRL derivations are in Appendix A.

EPA (IRIS 2005) has derived an inhalation reference concentration (RfC) for mixed xylenes of 0.1 mg/m^3^ (0.02 ppm) based on a NOAEL of 50 ppm (217 mg/m^3^) and a LOAEL of 100 ppm (434 mg/m^3^) for impaired motor coordination (decreased rotarod performance) in male rats exposed to m-xylene vapor 6 hours/day, 5 days/week for 3 months (Korsak et al. 1992); an uncertainty factor of 300 was applied to the NOAEL. EPA (IRIS 2005) has derived an oral reference dose (RfD) for mixed xylenes of 0.2 mg/kg/day, based on a NOAEL of 250 mg/kg/day and a LOAEL of 500 mg/kg/day for dose-related decrease in body weight and increase in mortality in male rats treated by oral gavage 5 days/week for 2 years (NTP 1986); an uncertainty factor of 1,000 was applied to the NOAEL.

Table 8-1 Regulations and Guidelines Applicable to Xylenes

Agency | | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
| IARC | Carcinogenicity classification | Group 3^a^ | IARC 2004
| WHO | Air quality guidelines | No data | WHO 2000
| WHO | Drinking water quality guidelines | 0.5 mg/L^b^ | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. | Air
a. | ACGIH | TLV (TWA) | 435 mg/m^3^ | ACGIH 2004
a. | ACGIH | STEL | 655 mg/m^3^
a. | EPA | Hazardous air pollutant (isomers and mixture) | Yes | EPA 2004b; 42 USC 7412
a. | NAS/NRC | AEGL-1^c^ | | EPA 2007
a. | NAS/NRC | 10, 30, and 60 minutes, 4 and 8 hours | 130 ppm
a. | NAS/NRC | AEGL-2^c^
a. | NAS/NRC | 10 minutes | 2500 ppm^d^
a. | NAS/NRC | 30 minutes | 1300 ppm^d^
a. | NAS/NRC | 60 minutes | 920 ppm^d^
a. | NAS/NRC | 4 hours | 500 ppm
a. | NAS/NRC | 8 hours | 400 ppm
a. | NAS/NRC | AEGL-3^c^
a. | NAS/NRC | 10 minutes | 7,200 ppm^e^
a. | NAS/NRC | 30 minutes | 3,600 ppm^d^
a. | NAS/NRC | 60 minutes | 2,500 ppm^d^
a. | NAS/NRC | 4 hours | 1,300 ppm^d^
a. | NAS/NRC | 8 hours | 1,000 ppm^d^
a. | NIOSH | REL (15-minute ceiling limit) | 435 mg/m^3^ | NIOSH 2005
a. | NIOSH | IDLH | 3,906 mg/m^3^
a. | NIOSH | STEL | 655 mg/m^3^
a. | OSHA | PEL (8-hour TWA) for general industry | 435 mg/m^3^ | OSHA 2005c; 29 CFR 1910.1000
a. | OSHA | PEL (8-hour TWA) for construction industry | 435 mg/m^3^ | OSHA 2005b; 29 CFR 1926.55
a. | OSHA | PEL (8-hour TWA) for shipyard industry | 435 mg/m^3^ | OSHA 2005a; 29 CFR 1915.1000
b. | Water
b. | EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2005b; 40 CFR 116.4
b. | EPA | Drinking water standards and health advisories | | EPA 2004a
b. | EPA | 1-day HA (10-kg child) | 40 mg/L
b. | EPA | 10-day HA (10-kg child) | 40 mg/L
b. | EPA | DWEL | 7.0 mg/L
b. | EPA | National primary drinking water standards (total xylenes) | | EPA 2002b
b. | EPA | MCLG | 10 mg/L
b. | EPA | MCL | 10 mg/L
b. | EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 100 pounds | EPA 2005c; 40 CFR 117.3
c. | Food
c. | EPA | Exemption from the requirement of a tolerance | | EPA 2005f; 40 CFR 180.1025
c. | EPA | Xylenes applied as an emulsion | Initial concentration not to exceed 750 ppm
c. | EPA | Maximum residue of xylenes in potable water system/return flows of treated irrigation water into receiving rivers and streams | 10 ppm
c. | FDA | Bottled drinking water | 10 mg/L | FDA 2006; 21 CFR 165.110
d. | Other
d. | ACGIH | Carcinogenicity classification | A4^f^ | ACGIH 2004
d. | ACGIH | Biological exposure indices | 1.5 g/g creatinine
d. | ACGIH | Methylhippuric acids in urine (end of shift)
d. | EPA | Carcinogenicity classification | Data are inadequate for an assessment of the carcinogenic potential | IRIS 2005
d. | EPA | Inhalation unit risk | Not applicable
d. | EPA | Oral slope factor | Not applicable
d. | EPA | RfC | 0.1 mg/m^3^
d. | EPA | RfD | 0.2 mg/kg/day
d. | EPA | Superfund, emergency planning, and community right-to-know
d. | EPA | Designated CERCLA hazardous substance | | EPA 2005d; 40 CFR 302.4
d. | EPA | Reportable quantity
d. | EPA | Xylenes and p-xylenes | 100 pounds
d. | EPA | m-Xylenes and o-xylenes | 1,000 pounds
d. | EPA | Effective date of toxic chemical release reporting | 01/01/87 | EPA 2005e; 40 CFR 372.65
d. | NTP | Carcinogenicity classification | No data | NTP 2005

a Group 3: Not classifiable as to carcinogenicity to humans

b Concentrations of the substance at or below the health-based guideline value may affect the appearance, taste, or odor of the water, leading to consumer complaints.

c AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects. AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape. AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death.

d Values denoted as having safety considerations against the hazard of explosion; the Lower Explosive Limit (LEL)=9,000 ppm and each value should be ≥10% LEL. Safety considerations against the hazard(s) of explosion(s) must be taken into account.

e Extreme safety considerations against the hazard(s) of explosion(s) must be taken into account.

f A4: Not classifiable as a human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline level; CERCLA = Comprehensive Environmetnal Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HA = health advisory; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Informatin System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NAS/NRC = National Academy of Sciences/National Research Council; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization