# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes)
CAS Numbers: | 1330-20-7, 95-47-6, 108-38-3, 106-42-3
Date: | August 2007
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 49
Species: | Human

[underlined: Minimal Risk Level]: 2 [ ] mg/kg/day [X] ppm

[Note: A single acute-duration inhalation MRL has been derived based on data for m-xylene that applies to mixed xylenes and all of the individual isomers. The justification for deriving a common value is that the isomers have similar toxicokinetic properties and elicit similar toxicological effects, with no isomer consistently exhibiting the greatest potency, depending on the end point. Further discussion of this rationale is presented in Section 3.2.]

[underlined: Reference]: Ernstgard L, Gullstrand E, Lof A, . 2002. Are women more sensitive than men to 2-propanol and m-xylene vapors? Occup Environ Med 59:759–767.12409535

[underlined: Experimental design]: Fifty-six healthy volunteers (28 per sex) between the ages of 20 and 49 years were exposed to 50 ppm (200 mg/m^3^) m-xylene, clean air (controls), or 150 ppm 2-propanol in a dynamic exposure chamber for 2 hours. Each subject experienced the three treatments. Sessions were separated by intervals of 2 weeks. The experiment was initially designed to be balanced with two men and two women exposed on each occasion with all six possible orders of treatment represented. (Schedule changes by the volunteers resulted in imbalances in treatment orders, but ANOVA analysis indicated that the imbalance had no significant effect on the results.) Subjects rated the level of perceived discomfort using a visual analog scale (0–100 mm) in a questionnaire with 10 questions during exposure (3, 60, and 118 minutes from the start of exposure), and post-exposure (140 and 350 minutes from onset). Items included discomfort in eyes, nose, throat, or airways; breathing difficulty; solvent smell; headache; fatigue; nausea; dizziness; and feeling of intoxication. Pulmonary function measurements were conducted via spirometer prior to exposure, immediately after exposure, and 3 hours post-exposure. These included vital capacity (VC), forced vital capacity (FVC), forced expiratory volume in one second (FEV_1_), peak expiratory flow (PEF), and forced expiratory flow in 25, 50, or 75% of FVC (FEF_25_, FEF_50_, FEF_75_). Nasal swelling was assessed by acoustic rhinometry before, immediately after, and 3 hours after the end of exposure. Nasal lavages obtained before and 3 hours after the end of exposure were evaluated for markers of inflammation (lysozyme, albumin, myeloperoxidase, and eosinophilic cationic protein). Eye blinking was measured throughout exposure by electromyography and color vision was assessed before, immediately after, and 3 hours post-exposure.

[underlined: Effect noted in study and corresponding doses]: Statistically significant increases, compared to air-exposure, in the average rating of self-reported symptoms resulting from exposure to m-xylene at 50 ppm were observed for discomfort in the eyes and nose, detection of solvent smell, and feeling of intoxication in both sexes after 60 and 118 minutes, in discomfort in the throat or airways in women after 60 minutes, in breathing difficulty and nausea in men at 118 minutes and women at both timepoints, in headache and fatigue in men at both timepoints, and in dizziness in men at 118 minutes. All of the statistically significant increases in the subjective ratings were minimal except for detection of solvent smell, which was moderate.

Statistically significant minimal changes, compared to air-exposure, were observed in objective measures of respiratory function (percent change from pre-exposure measurements) in women, but not men, 3 hours after the end of the exposure to m-xylene: FVC reduced by 2.81% (compared to reduced by 0.06% for air exposure, p<0.01), FEV_1_/FVC increased by 1.09% (compared to decreased by 0.34% for air exposure, p<0.03), and FEF_75_ increased by 3.32% (compared to decreased by 5.53% for air exposure, p<0.04). No statistically significant change was observed immediately after exposure. Irrespective of exposure condition, there were diurnal changes in lung function (FVC and FEV_1_) that were more pronounced in women than in men. There were no solvent-related changes in nasal volume or cross-sectional area, but ANOVA revealed a sex-dependent decrease in nasal volume over time (greater in women) irrespective of exposure condition. Exposure to m-xylene did not induce significant adverse changes in other parameters.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

The minimal LOAEL of 50 ppm m-xylene is for slight respiratory effects (reduced forced vital capacity, increased discomfort in throat and airways in females, and breathing difficulty in both sexes) and subjective symptoms of neurotoxicity (headache, dizziness, a feeling of intoxication). The LOAEL is minimal because the magnitude of the changes was small. The data were not suitable for benchmark dose analysis because a single exposure level was tested.

[underlined: Uncertainty Factors used in MRL derivation]: 30

- [X] 3 for use of a minimal LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The database for acute-duration inhalation exposure to xylenes includes a number of studies in humans and laboratory animals. Studies in humans identify neurological and respiratory effects as the most sensitive end points for acute-duration inhalation exposure. Effects observed in humans at 50–690 ppm included irritation of the respiratory tract (breathing difficulty, discomfort in nose and throat, reduced forced air capacity), neurotoxicity (dizziness, headache, impaired short-term memory, increase in reaction times), and eye irritation (Carpenter et al. 1975a; Dudek et al. 1990; Gamberale et al. 1978; Nelson et al. 1943; NIOSH 1981). Other neurological effects in humans included altered visual evoked potentials following repeated exposure to 200 ppm m-xylene and impaired body balance following a single 4-hour exposure at 400 ppm (Savolainen et al. 1984; Seppalainen et al. 1989).

Acute-duration neurological effects in animals were observed at concentrations of 113 ppm and higher. These included transiently decreased operant responses in rats repeatedly exposed to 113 ppm mixed xylene (Ghosh et al. 1987), altered responses to electric shock in rats and mice exposed once to 230–320 ppm o-xylene (Vodickova et al. 1995), and decreased axonal transport in rats repeatedly exposed to 800 ppm mixed xylene (Padilla and Lyerly 1989). Effects related to motor incoordination were observed following exposures to mixed xylenes or individual isomers in the range of 1,010–1,982 ppm (Carpenter et al. 1975a; De Ceaurriz et al. 1983; Korsak et al. 1988, 1990, 1993). Sensory-related changes (altered visual- or auditory-evoked potentials or hearing losses) occurred at exposures in the range of 1,400–1,600 ppm p-xylene (Crofton et al. 1994; Dyer et al. 1988; Pryor et al. 1987; Rebert et al. 1995). Other neurological effects included disturbances in brain catecholamine or dopamine following repeated exposure to mixed xylene or individual isomers at 2,000 ppm (Andersson et al. 1981), narcosis in rats at ≥1,940 ppm (Molnar et al. 1986), and ataxia and seizures in cats exposed to 9,500 ppm mixed xylene (Carpenter et al. 1975a).

The lowest effect levels for other end points affected by acute-duration inhalation exposure in animals were higher than the lowest LOAEL for sensitive end points in humans. Rat developmental effects (reduced fetal body weight and delayed ossification) were observed at xylene exposures in the range of 350–2000 ppm (Saillenfait et al. 2003; Ungvary et al. 1980b); maternal body weight effects were observed at 700 ppm (Ungvary et al. 1980b). Acute-duration respiratory effects in animals include decreases in lung surfactant following exposure to mixed xylenes or individual isomers at 1,000 ppm or higher (Elovaara et al. 1987; Patel et al. 1978; Toftgard and Nilsen 1982) and decreased respiratory rates in mice briefly exposed to m- or o-xylene at concentrations of 1,361–2,700 ppm (De Ceaurriz et al. 1981; Korsak et al. 1990, 1991, 1993). Increased mortality has been reported in rodents repeatedly exposed to at 700 ppm (Ungvary et al. 1980b) or once to ≥2,010 ppm (Bonnet et al. 1979; Cameron et al. 1938; Carpenter et al. 1975a; Harper et al. 1975; Hine and Zuidema 1970).

Respiratory and neurological effects are selected as co-critical effects of acute-duration inhalation exposure since they occurred at the lowest tested exposure level of 50 ppm. Ernstgard et al. (2002) was selected as the principal study for acute-duration inhalation exposure because it provides the lowest LOAEL for the co-critical effects.

[underlined: Agency Contacts (Chemical Managers)]: Mike Fay, Ph.D.; John F. Risher, Ph.D.; Jewell D. Wilson, Ph.D.

## Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes)
CAS Number: | 1330-20-7, 95-47-6, 108-38-3, 106-42-3
Date: | August 2007
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 137
Species: | Rat

[underlined: Minimal Risk Level]: 0.6 [ ] mg/kg/day [X] ppm

[Note: A single intermediate-duration inhalation MRL has been derived based on data for m-xylene that applies to mixed xylenes and all of the individual isomers. The justification for deriving a common value is that the isomers have similar toxicokinetic properties and elicit similar toxicological effects, with no isomer consistently exhibiting the greatest potency, depending on the end point. Further discussion of this rationale is presented in Section 3.2.]

[underlined: Reference]: Korsak Z, Wisniewska-Knypl J, Swiercz R. 1994. Toxic effects of subchronic combined exposure to n-butyl alcohol and m-xylene in rats. Int J Occup Med Environ Health 7:155–166.7820390

[underlined: Experimental design]: Groups of 12–24 male Wistar rats were exposed to m-xylene at 0, 50, or 100 ppm, for 6 hours/day, 5 days/week for 3 months. Before the start of the study and at the end of each month of exposure, rats were examined for motor coordination (rotarod performance). The level of analgesia was tested at termination in the paw-lick response to hot-plate test at 54 °C.

[underlined: Effect noted in study and corresponding doses]: A dose-related increase in the failure rate on the rotarod performance test was observed. The change at 100 ppm was significantly different (p≤0.05) from controls. There was no change in severity over time. Increased sensitivity to pain was indicated by a significant decrease (p≤0.05) compared to controls in the latency of the paw-lick response at 50 and 100 ppm: 12.2±3.1, 8.7±3.8, and 8.6±2.7 seconds, respectively, for control, 50, and 100 ppm. The 50 ppm concentration of m-xylene is a LOAEL and serves at the basis for the intermediate inhalation MRL for xylenes.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

The low concentration of 50 ppm was a minimal LOAEL for a statistically significant decrease in the mean latency of the paw-lick response. The LOAEL is considered minimal because the effect was subtle, differing from the control by <29%, and did not significantly increase in severity with dose. The data were not suitable for benchmark dose analysis because the response was essentially a plateau.

[underlined: Uncertainty Factors used in MRL derivation]: 90

- [X ] 3 for use of a minimal LOAEL
- [X] 3 for extrapolation from animals to humans using dosimetric adjustment
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: The minimal rat LOAEL was converted to a human equivalent following the EPA (1994) dosimetric equation for an extra-respiratory effect from an inhaled category 3 gas: minimal LOAEL_(HEC)_ = minimal rat LOAEL × λ_a_/λ_h_, where λ_a_ and λ_h_ are blood:air partition coefficients for rats and humans, respectively. Reported blood:air partition coefficients for m-xylene are 39.9 for Wistar rats and 26.4 for humans (Sato and Nakajima 1979). Since the rat value is higher than the human, the default value of 1 was used for λ_a_/λ_h_ (EPA 1994). The minimal LOAEL_HEC_ is therefore 50 ppm.

[underlined: Was a conversion used from intermittent to continuous exposure]? No. The rapid clearance of xylene from the body does not justify such a conversion.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The database for intermediate-duration inhalation to xylenes includes one controlled-exposure study in humans and several animal bioassays. Effects in humans exposed to 100–150 ppm p-xylene 1–7.5 hours/day, 5 days/week for 4 weeks included increased reporting of subjective symptoms of irritation of the nose and throat (NIOSH 1981). This study found no significant alterations in objective measures of neurological function (electroencephalography, tests of motor activity, and cognitive performance) and no alterations in pulmonary function in human subjects, but the study was limited in that some group sizes were small (n=2). Animal toxicity bioassays that tested at concentrations below 100 ppm reported no clinical signs of neurotoxicity or no adverse effects on brain weight (Hillefors-Berglund et al. 1995; Jenkins et al. 1970). In a special neurobehavioral assay, a LOAEL of 50 ppm was identified for decreased latency of the paw-lick response in rats exposed to m-xylene for 3 months (Korsak et al. 1994); impaired rotarod performance was noted in this study at 100 ppm, but not at 50 ppm. Other intermediate-duration studies also reported neurobehavioral effects (impaired rotarod performance, passive avoidance learning) following exposure to 100 ppm m-xylene for 4 weeks to 6 months (Gralewicz and Wiaderna 2001; Gralewicz et al. 1995; Korsak et al. 1994); some neurological impairment persisted for 5–9 weeks after exposure (Gralewicz and Wiaderna 2001). Other effects included distribution of astroglia cells in the brain of Mongolian gerbils exposed to 160 ppm mixed xylene for 4 months (Rosengren et al. 1986), delayed maxillary ossification and impaired rotarod performance in rats gestationally exposed to 200 ppm technical-grade xylene for 6 hours/day (Hass and Jakobsen 1993), and impaired motor coordination and spatial orientation following gestational exposure at 500 ppm (Hass et al. 1995, 1997). Neurological effects at higher concentrations included tremors in dogs exposed to 780 ppm o-xylene for 6 hours/day, 5 days/week for 6 weeks (Jenkins et al. 1970), alterations in brain neurotransmitters following continuous exposure to 800 ppm mixed xylenes for 30 days (Honma et al. 1983), and auditory effects in rats (mid-range hearing loss, death of hair cells of the Cochlea, or decreases in auditory brainstem responses) following exposure to ≥800 ppm mixed xylenes or 900 ppm p-xylene for 13 weeks (Gagnaire et al. 2001; Nylen and Hagman 1994; Pryor et al. 1987).

Non-neurological effects were observed at higher concentrations. Cardiovascular effects (increased thickness of coronary microvessels) were observed in rats exposed to 230 ppm mixed xylenes 6 hours/day, 5 days/week for 4 weeks (Morvai et al. 1987). Hepatic effects (increased liver weight) were observed at a LOAEL of 600 ppm in rats discontinuously exposed to mixed xylenes for 4 weeks (Toftgard et al. 1981). In rats exposed gestationally to mixed xylenes or o-xylene, a LOAEL of 500 ppm was identified for decreased fetal body weights in the absence of maternal toxicity (Bio/dynamics 1983). LOAELs for adult body weight effects were 1,000 ppm or higher (Tatrai et al. 1981). Increased deaths among squirrel monkeys and rats were noted following discontinuous intermediate-duration exposure to 780 ppm o-xylene (Jenkins et al. 1970), but no systemic effects were noted in rats or dogs exposed to 810 ppm mixed xylenes (Carpenter et al. 1975a).

[underlined: Agency Contacts (Chemical Managers)]: Mike Fay, Ph.D.; John F. Risher, Ph.D.; Jewell D. Wilson, Ph.D.

## Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes)
CAS Number: | 1330-20-7, 95-47-6, 108-38-3, 106-42-3
Date: | August 2007
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 150
Species: | Human

[underlined: Minimal Risk Level]: 0.05 [ ] mg/kg/day [X] ppm

[Note: A single chronic-duration inhalation MRL has been derived based on data for mixed xylene that applies to mixed xylenes and all of the individual isomers. The justification for deriving a common value is that the isomers have similar toxicokinetic properties and elicit similar toxicological effects, with no isomer consistently exhibiting the greatest potency, depending on the end point. Further discussion of this rationale is presented in Section 3.2.]

[underlined: Reference]: Uchida Y, Nakatsuka H, Ukai H, . 1993. Symptoms and signs in workers exposed predominantly to xylenes. Int Arch Occup Environ Health 64:597–605.8314620

[underlined: Experimental design]: 175 workers (107 men, 68 women) were exposed to mixed xylenes in Chinese factories during the production of rubber boots or plastic coated wire, or in printing work. Two hundred forty-one nonexposed workers (116 men, 125 women) were recruited from the same or other factories as a comparison population. Exposures, measured with a diffusive sampler, indicated that xylenes accounted for >70% total exposure, with m-xylene accounting for 50% of the xylene exposure, followed by p- and o-xylenes. Toluene exposure and ethylbenzene exposure were about 1 and 3 ppm, respectively, with no benzene exposure. Subjects were evaluated for subjective symptoms in a questionnaire and also examined for objective parameters (serum biochemistry, hematology, and urinalysis). Exposures were corroborated by measurements of xylene metabolites in urine.

[underlined: Effect noted in study and corresponding doses]: The TWA (arithmetical mean) for xylenes was 21 ppm for an average of 7 years (geometric mean 14 ppm). One man was exposed to 175 ppm. Subjective symptoms included increased prevalence of anxiety, forgetfulness, inability to concentrate, eye and nasal irritation, dizziness, and sore throats. Exposure and urinary metabolites are further described in Inoue et al. (1993). The findings of hematology (red blood cell, platelet and white blood cell counts, hemoglobin), serum biochemistry (total protein, albumin, aspartate aminotransferase, alanine aminotranferase gamma-GTP, alkaline phosphatase, leucine aminopeptidase, lactate dehydrogenase, amylase, BUN, creatinine), and urinalysis were normal, indicating no liver or kidney effects. The geometric mean of 14 ppm, a LOAEL for subjective effects, is used as the basis of the chronic-duration MRL.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

The LOAEL of 14 ppm, the TWA geometric mean, was for subjective symptoms of neurotoxicity (anxiety, forgetfulness, floating sensation) and respiratory toxicity (nasal irritation and sore throat) and eye irritation. The geometric mean was chosen over the arithmetical mean because it is a better representation of central tendency. The data were not suitable for benchmark dose analysis because a single average exposure level was reported.

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying Factors used in MRL derivation]:

- [X] 3 to account for the lack of supporting studies evaluating the chronic neurotoxicity of xylene.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No. The rapid clearance of xylene from the body does not justify such a conversion.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Although no other chronic-duration inhalation data are available for humans, the database for shorter duration exposures supports the findings of Uchida et al. (1993). Neurotoxicity (dizziness, headache, impaired short-term memory, increased reaction times), irritation of the respiratory tract (breathing difficulty, discomfort in nose and throat, reduced forced air capacity), and eye irritation have been reported in humans acutely exposed to ≥50 ppm m-xylene or mixed xylenes or ≥100 ppm p-xylene (Carpenter et al. 1975a; Dudek et al. 1990; Ernstgard et al. 2002; Gamberale et al. 1978; Nelson et al. 1943; NIOSH 1981). Repeated intermediate-duration exposure to ≥100 ppm p-xylene also increased the reporting of subjective symptoms for irritation of the nose and throat (NIOSH 1981).

Studies in animals also confirm that the nervous system is a sensitive target of inhalation exposure to xylene; respiratory function has not been assessed in animals at low concentrations. The most sensitive effects observed in acute-duration studies involved impaired neurological performance (operant responses) in rats exposed to 113 ppm mixed xylenes (Ghosh et al. 1987) and altered responses to electric shock in rats and mice exposed to 230–320 ppm o-xylene (Vodickova et al. 1995). The most sensitive effects in intermediate-duration studies were for increased sensitivity to pain in rats exposed to 50 ppm m-xylene (Korsak et al. 1994) and impairments in rotarod performance and passive avoidance learning in rats exposed to ≥100 ppm m-xylene (Gralewicz and Wiaderna 2001; Gralewicz et al. 1995; Korsak et al. 1994). In addition, rats exposed during gestation to ≥160 ppm mixed xylene exhibited neurological impairments after birth (degraded rotarod performance, motor coordination, and spatial orientation) (Hass and Jakobsen 1993; Hass et al. 1995; Hass et al. 1997). Conversely, the most sensitive non-neurological effects in inhalation assays in animals were developmental effects in rats acutely-exposed at 350 ppm (Ungvary et al. 1980b) and cardiovascular effects in rats exposed for an intermediate duration at 230 ppm (Morvai et al. 1987).

Acute exposure of volunteers to 50 ppm xylene and 50 ppm toluene appeared to reduce the neurological effects of xylenes (Dudek et al. 1990). Therefore, it is unlikely that the low concentration of toluene (1 ppm) reported in the Uchida et al. (1993) contributed to the observed effects.

The only other chronic-duration inhalation study was for rats exposed to 1,096 ppm o-xylene 8 hours/day, 7 days/week for 1 year (Tatrai et al. 1981). Hepatic changes included increases in liver weight and microsomal activity and proliferating endoplasmic reticulum, but no histopathological lesions. Body weight was reduced by 11% in exposed rats. Calculation of a chronic-duration inhalation MRL from this rat study would not be appropriate since the study did not examine neurological effects, which are the most critical end points for inhalation exposure to xylene.

[underlined: Agency Contacts (Chemical Managers)]: Mike Fay, Ph.D.; John F. Risher, Ph.D.; Jewell D. Wilson, Ph.D.

## Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes)
CAS Number: | 1330-20-7, 95-47-6, 108-38-3, 106-42-3
Date: | August 2007
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 20
Species: | Rat

[underlined: Minimal Risk Level]: 1 [X] mg/kg/day [ ] ppm

[Note: A single acute-duration oral MRL has been derived based on data for p-xylene that applies to mixed xylenes and all of the individual isomers. The justification for deriving a common value is that the isomers have similar toxicokinetic properties and elicit similar toxicological effects, with no isomer consistently exhibiting the greatest potency, depending on the end point. Further discussion of this rationale is presented in Section 3.2.]

[underlined: Reference]: Dyer RS, Bercegeay MS, Mayo LM. 1988. Acute exposures to p-xylene and toluene alter visual information processing. Neurotoxicol Teratol 10:147–153.3398823

[underlined: Experimental design]: Male Long-Evans rats had electrodes implanted in their skulls and were allowed to recover from surgery for 1 week prior to exposure and testing for visual processing. Two different experiments were conducted. p-Xylene (99.8% pure) was diluted in corn oil and administered by gavage at 1 mL/kg. Groups of 10–11 rats received single doses of p-xylene at doses of 0, 500, 1,000, or 2,000 mg/kg in corn oil and were tested 75 minutes later. Based on the results of this experiment, groups of 14–16 rats were dosed at 0, 125, or 250 mg/kg and tested 45 minutes later. The eyes of exposed rats were treated with topical atropine (1% in saline) 10 minutes prior to visual testing, which took place in a rectangular box with three mirrored sides. A trial consisted of the response to a single strobe-generated flash. Trials were presented at 0.3 Hz and a total of 128 trials were averaged for each flash-evoked potential. The latencies and amplitudes of the P1, N1, P2, N2, P3, and N3 waveforms were determined in the first experiment and the N3 waveform measured in the second experiment.

[underlined: Effect noted in study and corresponding doses]: Forty-five minutes after administration of 250 mg/kg, the amplitude of the N3 peak was decreased by 47% (statistically significant). At higher doses (500, 1,000, and 2,000 mg/kg), the N3 peak was not observed until 75 minutes after dosing. At 2,000 mg/kg, mild sedation and hypothermia (1 °C) were observed. Increased latencies were observed for the P1, N1, and P2 peaks, but this effect was attributed to the hypothermia. Effects on the N3 amplitude were still apparent 8 hours post dosing. By 16 hours post dosing, recovery was complete. Amphetamines (0.6, 1.2, or 2.5 mg/kg) produced effects on the N3 amplitude similar to p-xylene. The study authors suggested that the effects of xylene may be secondary to changes in arousal or excitability. No effects were noted at 125 mg/kg/day, and this NOAEL serves as the basis for the acute oral MRL for xylenes.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [ ] LOAEL

The NOAEL of 125 mg/kg/day was for alteration of visual evoked potentials. The data were not suitable for benchmark dose analysis because the responses at 250 mg/kg/day (reduction in N3 peak amplitude) and ≥500 mg/kg/day (delay in N3 peak appearance) were not comparable.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Evaluation of the limited database for acute-duration oral exposure to xylenes suggests that neurotoxicity represents the most sensitive end point in laboratory animals; no quantitative human data are available. Effects observed in acute-duration, single-dose oral studies included altered visually evoked potentials in rats receiving 250 mg/kg p-xylene (Dyer et al. 1988) and reduced pulmonary microsomal activity in rats receiving 1,000 mg/kg p-xylene (Patel et al. 1978). In rats exposed 5 days/week for 2 weeks, a significant loss of Cochlear hair cells responsible for detecting midrange frequencies was observed following gavage dosing with 900 mg/kg/day p-xylene but not m- or o-xylene (Gagnaire and Langlais 2005). Reduced body weight gain was observed in rats following repeated dosing for 13 weeks with 1,000 mg/kg mixed xylenes or 2,000 mg/kg/day o- or p-xylene (Condie et al. 1988; NTP 1986). Repeated exposure to mixed xylenes at 2,000 mg/kg/day resulted in impaired respiration (shallow and/or labored breathing) in rats and mice and increased mortality (NTP 1986). At 2,060 mg/kg/day, developmental toxicity (cleft palate) was observed in mice gestationally exposed to mixed xylenes (Marks et al. 1982). Serious neurological effects (coma, incoordination, prostration, decreased hindleg movement) were observed in rats that received single oral gavage doses of ≥4,000 mg/kg mixed xylenes (Muralidhara and Krishnakumari 1980; NTP 1986).

The database for inhalation studies on xylene supports neurotoxicity as the sensitive target following short- or long-term exposure. Neurotoxicity was manifest as self-reported symptoms of headache, dizziness, and a feeling of intoxication in human subjects acutely-exposed to 50 ppm m-xylene (Ernstgard et al. 2002) and decreased operant responses in rats exposed to 113 ppm mixed xylene (Ghosh et al. 1987). Conversely, the most sensitive non-neurological effects in animals were developmental effects in rats exposed at 350 ppm (Ungvary et al. 1980b).

Neurotoxicity was selected as the critical effect for acute-duration oral exposure to xylene because it was observed at the lowest exposure level and demonstrated dose-related increases in severity. The study by Dyer et al. (1988) was selected as the principal study, since it provides the lowest LOAEL for the critical effect.

[underlined: Agency Contacts (Chemical Managers)]: Mike Fay, Ph.D.; John F. Risher, Ph.D.; Jewell D. Wilson, Ph.D.

## Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes)
CAS Number: | 1330-20-7, 95-47-6, 108-38-3, 106-42-3
Date: | August 2007
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 39
Species: | Mouse

[underlined: Minimal Risk Level]: 0.4 [X] mg/kg/day [ ] ppm

[Note: A single intermediate-duration oral MRL has been derived based on data for mixed xylenes that applies to mixed xylenes and all of the individual isomers. The justification for deriving a common value is that the isomers have similar toxicokinetic properties and elicit similar toxicological effects, with no isomer consistently exhibiting the greatest potency, depending on the end point. Further discussion of this rationale is presented in Section 3.2.]

[underlined: Reference]: NTP. 1986. National Toxicology Program technical report on the toxicology and carcinogenesis studies of xylenes (mixed) (60% m-xylene, 14% p-xylene, 9% o-xylene, and 17% ethylbenzene) (CAS No. 1330-20-7) in F344/N rats and B6C3F_1_ mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program. NTP TR 327. NIH Publication No. 87-2583.

[underlined: Experimental design]: B6C3F_1_ mice (50/sex/dose) were administered 500 or 1,000 mg/kg/day mixed xylenes (9.1% o-, 60.2% m-, and 13.6% p-xylene, and 17% ethylbenzene) in corn oil by gavage, 5 days/week for 103 weeks. Mice were observed twice daily for mortality and clinical signs; clinical signs were recorded daily for 16 months and monthly thereafter. Body weights were recorded weekly for the first 12 weeks and once a month thereafter. Animals in a moribund condition and those surviving to 103 weeks were sacrificed humanely. All animals were subjected to gross necropsy at termination; all gross lesions and a full range of tissues in each animal were examined for histopathology.

[underlined: Effect noted in study and corresponding doses]: There were no significant treatment-related effects of mixed xylene on body weight, survival, or the incidence of neoplastic or non-neoplastic lesions in mice receiving doses as high as 1,000 mg/kg/day, 5 days/week for 104 weeks. The only effect of treatment with mixed xylenes was hyperactivity in high-dose male and female mice, consistently observed during the half-hour period following administration in weeks 4–103. Hyperactivity observed from week 4 to week 51 is considered an overt neurological effect of intermediate-duration exposure to mixed xylene.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [ ] LOAEL

The NOAEL of 500 mg/kg/day for hyperactivity in male and female mice was adjusted for intermittent exposure (5 days/7 days), resulting in a duration-adjusted NOAEL of 360 mg/kg/day. The data were not suitable for benchmark dose analysis because the incidence of hyperactivity at the LOAEL was 100% and provides no information as to the shape of the low end of dose-response curve.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying Factor used in MRL derivation]:

- [X ] 10 for the lack of testing for sensitive neurological end points and lack of developmental and multi-generational data.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The mouse NOAEL of 500 mg/kg was multiplied by 5 days/7 days, resulting in a duration-adjusted mouse NOAEL of 360 mg/kg/day.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The intermediate-duration oral toxicity of xylenes has been investigated in several oral gavage bioassays in rodents exposed to mixed xylene (Condie et al. 1988; NTP 1986), m-xylene (Elovaara et al. 1989; Wolfe 1988a), and p-xylene (Wolfe 1988b). The observed effects include increases in minimal chronic nephropathy and–17–37% increases in relative hepatic weight in rats exposed to ≥750 mg/kg/day mixed xylene (Condie et al. 1988); 27–46.3% increases in serum transaminase levels in rats exposed to 750–1,500 mg/kg/day mixed or m-xylene (Condie et al. 1988; Elovaara et al. 1989; Wolfe 1988a); reduced levels of cytochrome P-450 in the lung in rats exposed to 800 mg/kg/day m-xylene (Elovaara et al. 1989); 15–25% decreases in body weight gain in rats exposed to 800–1,000 mg/kg/day mixed, m-, or p-xylene (NTP 1986; Wolfe 1988a, 1988b); hyperactivity or increased aggressiveness subsequent to dosing with mixed xylene in rats at 1,500 mg/kg/day or mice at 1,000 mg/kg/day (Condie et al. 1988; NTP 1986); and 11% increased relative spleen weight, 16% increased relative kidney weight, and increased hematological effects (mild polycythemia and leukocytosis) in female rats dosed with 1,500 mg/kg/day mixed xylene (Condie et al. 1988). No hepatic effects were noted in F344 rats given mixed xylene at doses as high as 1,000 mg/kg/day or B6C3F_1_ mice dosed at ≤2,000 mg/kg/day 5 days/week for 13 weeks (NTP 1986) or in Sprague-Dawley rats dosed with p-xylene at 800 mg/kg/day for 90 days (Wolfe 1988b). No renal effects were observed in rats or mice exposed to mixed xylene in studies by NTP (1986) or in rats exposed to m- or p-xylene (Wolfe 1988a, 1988b). The lack of hepatic or renal effects in some studies may be related to strain differences, exposure differences (discontinuous vs. continuous), or isomer specificities.

A limitation of standard intermediate-duration oral bioassays for xylene is that no testing was conducted for sensitive neurological effects. The only overt neurological effect of long-term exposure to xylene was hyperactivity noted in male and female mice immediately after dosing with 1,000 mg/kg (710 mg/kg/day, duration adjusted) mixed xylene beginning at week 4 of the 2-year NTP (1986) bioassay; hyperactivity was not observed at 500 mg/kg (360 mg/kg/day, duration adjusted). Neurotoxicity (hyperactivity) observed during the first year of that study (week 4–51) is selected as the critical effect of intermediate-duration exposure because it was observed at the lowest LOAEL (710 mg/kg/day, duration-adjusted).

Selection of neurotoxicity as the critical effect is consistent with the inhalation-exposure database. The most sensitive effects from inhalation exposure to xylenes were neurotoxicity: for the acute duration, self-reported symptoms of headache, dizziness, and feeling of intoxication in human subjects exposed to 50 ppm m-xylene (Ernstgard et al. 2002); for the intermediate duration, increased sensitivity to pain in rats exposed to 50 ppm m-xylene (Korsak et al. 1994); and for the chronic duration, increased reporting of symptoms of anxiety, forgetfulness, and a floating sensation in workers exposed to 14 ppm mixed xylene (Uchida et al. 1993). The most sensitive acute inhalation effect in animals was impairment of operant responses observed following exposure to ≥113 ppm m-xylene (Ghosh et al. 1987). Conversely, the most sensitive LOAELs for non-neurological effects in inhalation studies were for developmental effects in rats following acute exposure at ≥350 ppm (Ungvary et al. 1980b) or for cardiovascular effects in rats following intermediate exposure at ≥230 ppm (Morvai et al. 1987).

The NTP (1986) study is selected as the principal study for intermediate-duration exposure to xylene because it provides the lowest adverse effect level, a LOAEL of 710 mg/kg/day, and a NOAEL of 500 mg/kg (360 mg/kg/day, duration adjusted) for the critical effect.

[underlined: Agency Contacts (Chemical Managers)]: Mike Fay, Ph.D.; John F. Risher, Ph.D.; Jewell D. Wilson, Ph.D.

## Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Xylenes (mixed xylenes, ortho-, meta-, and para-xylenes)
CAS Number: | 1330-20-7, 95-47-6, 108-38-3, 106-42-3
Date: | August 2007
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 47
Species: | Rat

[underlined: Minimal Risk Level]: 0.2 [X] mg/kg/day [ ] ppm

[Note: A single chronic-duration oral MRL has been derived based on data for mixed xylenes that applies to mixed xylenes and all of the individual isomers. The justification for deriving a common value is that the isomers have similar toxicokinetic properties and elicit similar toxicological effects, with no isomer consistently exhibiting the greatest potency, depending on the end point. Further discussion of this rationale is presented in Section 3.2.]

[underlined: Reference]: NTP. 1986. National Toxicology Program technical report on the toxicology and carcinogenesis studies of xylenes (mixed) (60% m-xylene, 14% p-xylene, 9% o-xylene, and 17% ethylbenzene) (CAS No. 1330-20-7) in F344/N rats and B6C3F_1_ mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program. NTP TR 327. NIH Publication No. 87-2583.

[underlined: Experimental design]: F344/N rats (50/sex/dose) were administered 250 or 500 mg/kg/day mixed xylenes (9.1% o-, 60.2% m-, and 13.6% p-xylene, and 17% ethylbenzene) in corn oil by gavage, 5 days/week for 103 weeks. Rats were observed twice daily for mortality and clinical signs; clinical signs were recorded daily for 16 months and monthly thereafter. Body weights were recorded weekly for the first 12 weeks and once a month thereafter. Animals in a moribund condition and those surviving to 103 weeks were sacrificed humanely. All animals were subjected to gross necropsy at termination; all gross lesions and a full range of tissues in each animal were examined for histopathology.

[underlined: Effect noted in study and corresponding doses]: No adverse effects were noted in male or female rats treated at the low dose of 250 mg/kg/day. At 500 mg/kg, body weights were 5–8% lower in male rats after week 59, but the differences from controls were not biologically significant. In addition, survival at termination was significantly lower compared to controls in male rats treated at 500 mg/kg/day. No other treatment-related non-neoplastic or neoplastic effects were observed in male or female rats.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [ ] LOAEL

The MRL is based on a NOAEL of 250 mg/kg. Although no histopathology was observed in any organ, including the nervous system, in rats exposed to 500 mg/kg, this dose was not used as the basis for MRL derivation because survival was decreased in male rats at this dose level. Therefore, the next lowest dose level was used as the basis for the MRL. The NOAEL of 250 mg/kg was adjusted for intermittent exposure (5 days/7 days), resulting in a duration-adjusted NOAEL of 179 mg/kg/day. The data were not suitable for benchmark dose analysis because of the lack of measurable adverse effects aside from lethality.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying Factor used in MRL derivation]:

- [X] 10 for the lack of testing for sensitive neurological end points and lack of developmental and multi-generational data.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The NOAEL of 250 mg/kg/day was multiplied by 5 days/7 days, resulting in a duration-adjusted NOAEL of 179 mg/kg/day.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In the absence of data associating health effects in humans with chronic-duration oral exposure to xylenes, the animal bioassays provide a minimal basis for deriving an MRL for humans chronically exposed to xylenes. The parallel NTP (1986) oral gavage study in B6C3F_1_ mice reported no significant treatment-related effects of mixed xylene on body weight, survival, or the incidence of neoplastic or non-neoplastic lesions in mice receiving doses as high as 1,000 mg/kg/day, 5 days/week for 104 weeks. The only effect of treatment with mixed xylenes was hyperactivity in high-dose male and female mice, consistently observed during the half-hour period following administration in weeks 4–103.

Histopathology in specific target organs was not observed in rats or mice exposed to mixed xylene for 2 years (NTP 1986). Limitations of these studies include the lack of organ weight data, and the lack of hematology, urinalysis, or clinical chemistry data that might identify target organs for xylene. The lack of neurobehavioral analysis is also a deficiency, given that neurotoxicity was the most sensitive effect following acute-, intermediate-, or chronic-duration inhalation exposure, as well as acute-duration oral exposure to xylenes (Dyer et al. 1988; Ernstgard et al. 2002; Korsak et al. 1994; Uchida et al. 1993). The sensitive neurotoxic effects in animals were revealed by specialized neurobehavioral or neurophysio-logical tests and would not be apparent in standard toxicity assays.

[underlined: Agency Contacts (Chemical Managers)]: Mike Fay, Ph.D.; John F. Risher, Ph.D.; Jewell D. Wilson, Ph.D.