# 8 REFERENCES

* Cited in text

*ACGIH. 1992. Threshold limit values for chemical substances and physical agents, 1992-1993. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 31.
*Adams CO. 1938a. Chemical composition of transverse metaphyseal bands produced in growing bones by phosphorus ingestion. Proc Soc Exp Biol Med 39:351–354.
*Adams CO. 1938b. Effect of inorganic phosphorus on bone growth and repair. Proc Soc Exp Biol Med 38:449–450.
*Adams CO, Samat BG. 1940. Effects of yellow phosphorus and arsenic trioxide on growing bones and growing teeth. Arch Pathol 30:1192–1202.
*Addison RF, Ackman RG. 1970. Direct determination of elemental phosphorus by gas-liquid chromatography. J Chromatogr 48:421–426.
*Addison RF, Ackman RG, Cowley LJ, 1972a. Elemental phosphorus levels in water samples from Long Harbour, NFLD (July, 1969 - April, 1971). Technical Report No. 254. Fisheries Research Board of Canada, Halifax, Nova Scotia.
*Addison RF, Zinck ME, A&man RG, 1972b. Results of the elemental phosphorus monitoring program, Long Barbour, NFLD (July, 1970-April, 1971). Technical Report No. 303. Fisheries Research Board of Canada, Halifax, Nova Scotia.
*Albright & Wilson. 1992a. Albright & Wilson Americas industrial hygiene survey report: Contractor employee exposure during phosphorus storage tank decommissioning, with cover letter dated 06110193. Richmond, VA. NTIS/OTS0537755.
*Albright & Wilson. 1992b. Albright & Wilson Americas industrial hygiene survey report: Contractor employee exposure during phosphorus storage tank decontamination, with cover letter dated 06/10/93. Richmond, VA. NTIS/OTS0537756.
Albright & Wilson. 1992c. Hepatic function and exposure to phosphine and white phosphorus, with cover letter dated 06/10/93. Richmond, VA. NTIS/OTS0537759.
*Appelbaum J, Ben-Hur N, Shani J. 1975. Subcellular morphological changes in the rat kidney after phosphorus burn. Pathol Eur 10: 145–154.1187193
*Ashbum LL, McQueeney AJ, Faulkner RR. 1948. Scarring and precirrhosis of the liver in chronic phosphorus poisoning of guinea pigs. Proc Sot Exp Biol Med 67:351–358.
*Atkinson HV. 1921. The treatment of acute phosphorus poisoning. J Lab Clin Med 7: 148–150.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barker EA, Smuckler EA, Benditt EP. 1963. Effects of thioacetamide and yellow phosphorus poisoning on protein synthesis in vivo. Lab Invest 12:955–960.14084844
Barone C, Cittadini A, Galeotti T, 1973. The effect of intoxication induced in rat liver by carbon tetrachloride, ethionine, and white phosphorus on the level of microsomal cytochromes b_5_ and P_450_ Experientia 29:73–74.4729461
Barton DH R, Zhu J. 1993. Elemental white phosphorus as a radical trap: A new and general route to phosphonic acids. J Am Chem Soc 115:2071–2072.
*Ben-Hur N, Appelbaum J. 1973. Biochemistry, histopathology and treatment of phosphorus burns: An experimental study. Isr J Med Sci 9:40–48.4578960
*Ben-Hur N, Giladi A, Neuman Z, 1972. Phosphorus burns: A pathophysiological study. Br J Plast Surg 25:238–244.5047149
*Bentley RE, Dean JW, Hollister TA, 1978. Laboratory evaluation of the toxicity of elemental phosphorus (P4) to aquatic organisms. EG & G, Bionomics, Wareham, MA. DAMD-17-74-C-4101 ADA061785.
*Berck B, Gunther FA. 1970. Rapid determination of sorption affinity of phosphine by fumigation within a gas chromatographic column. J Agric Food Chem 18: 148–153.5535667
*Berkowitz JB, Young GS, Anderson RC, 1981. Research and development for health and environmental hazard assessment, Task Order 5. Occupational and environmental hazards associated with the formulation and use of white phosphorus-felt and red phosphorus-butyl rubber screening smokes. Cambridge, MA: Arthur D. Little, Inc. DAMD17-79-C-9139. AD-Al 16956.
*Bio/dynamics. 1991. A one-generation reproduction study in rats with elemental phosphorus Vols. I and II (Final Report) with pathology report. Report BD-89-153. U.S. EPA Fiche #: OTS0518525-3, OTS0518525-4.
*Bird S. 1991. White phosphorus poisoning of birds at Eagle River Flats in Alaska: The role of munitions compounds. Presented at Caribbean HAZTECH International Conference and Exhibition, San Juan, PR, Nov. 13-15. 1991.
*Blanke RV. 1970. Toxicology. In: Tietz NW, ed. Fundamentals of clinical chemistry. Philadelphia: W.B. Saunders Co, 833–889.
*Bohl CD, Kaelble EF. 1973. Determination of elemental phosphorus in air by gas chromatography. Am Ind Hyg Assoc J 4:306–309.
*Bohn HL, Johnson GV, Cliff JH. 1970. Detoxification of white phosphorus in soil. J Agric Food Chem l& 1172–1173.
*Bowen TE, Whelan TJ Jr, Nelson TG. 1971. Sudden death after phosphorus burns: experimental observations of hypocalcemia, hyperphosphatemia, and electrocardiographic abnormalities following production of a standard white phosphorus burn. Ann Surg 174:779–784.5113459
*Brazell RS, Holmerg RW, Moneyhun JH. 1984. Application of high-performance liquid chromatography-flow injection analysis for the determination of polyphosphoric acids in phosphorus smokes. J Chromatogr 290:163:172.
*Brown BJ, Affleck GE, Cummings EG, 1981. The subchronic effects of repeated exposure to white phosphorus/felt screening smoke in rats. Report No. ARCSL-TR-80068, AD-B05848L.
Brown BJ, Affleck GE, Ferrand RL, . 1980. The acute effects of single exposures to white phosphorus smoke in rats and guinea pigs. Report No. ARCSL-TR-80013, AD-B051836L.
Buchanan DJ, Sigal MV Jr, Robinson CS, 1954. Studies of phosphorus intoxication. I. Changes in blood, urine, and tissues of dogs poisoned with phosphorus. American Medical Association Archives of Industrial Hygiene and Occupational Medicine 9: 1–8.13113733
*Budavari S, O’Neil MJ, Smith A, , eds. 1989. The Merck Index, 1 lth Ed. Rahway, NJ: Merck and Co., Inc., 1167.
*Bullock E, Newslands MJ. 1969. Decomposition of phosphorus in water. Proceedings of the Chemical Institute of Canada Conference on Pollution, Halifax, NS, August 24-26, pp 23–24.
*Bumell JM, Dennis MB Jr, Clayson KJ, 1976. Evaluation of dogs of cross-circulation in the treatment of acute hepatic necrosis induced by yellow phosphorus. Gastroenterology 7 1:827–83 1.
*Caley JP, Kellock IA. 1955. Acute yellow phosphorus poisoning with recovery. Lancet 268:539–541.14354923
*Cameron JM, Patrick RS. 1966. Acute phosphorus poisoning - The distribution of toxic doses of yellow phosphorus in the tissues of experimental animals. Med Sci Law 6:209–214.5977105
*C&EN. 1982. Key chemicals: Phosphorus. Chemical & Engineering News, October 25,13.
*Campbell DL. 1977. Oxidation of phossy water by ozone. Chemical Syst. Laboratory, Army Armament Res. Dev. Command, Aberdeen Proving Ground, MD. NTIS AD-A044753.
*CAS. 1993. Chemical Abstracts Service. American Chemical Society, Washington, DC. March 30,1993.
*CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta,GA: CDUATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
*CELDS. 1992. Computer Aided Environmental Legislative Data System. February 1992.
Chang S-G, Hu K, Wang Y. 1994. The use of yellow phosphorus to destroy toxic organic compounds. Journal of Environmental Sciences (China) 6( 1): 1 – 12.
*Chang SG, Lee GC. 1992. LBL PHOSNOX process for combined removal of SO_2_ and NO_x_ from flue gas. Environmental Progress 11:66–73.
*Chang SG, Liu DK. 1990. Removal of nitrogen and sulfur oxides from waste gas using a phosphorus/alkali emulsion. Nature 343:151–153.
Changqi Z, Jionghiang Z, Yuying H. 1994. Changes in CBG levels from contact with yellow phosphorus. Zhonghua Laodong Weisheng Zhiyebing Zazhi 12(3):14–17.
Chen C, Tang Z, Liang R. 1993. Effects of artesunate on the hepatic GSH content in normal and hepatotoxin-poisoned mice. Zhongguo Yaolixue Tongbao 9(1):52–54.
*CMR. 1978. Chemical profile: Phosphorus. Chemical Marketing Reporter, January 9,1978.
*CMR. 1981. Chemical profile: Phosphorus. Chemical Marketing Reporter, March 9,198l.
*CMR. 1985. Chemical profile: Phosphorus. Chemical Marketing Reporter, March 4,1985.
*CMR. 1981. Chemical profile: Phosphorus. Chemical Marketing Reporter, February 18,1991.
*Compere EL. 1930a. The effect of phosphorus in rickets. II. Chemical changes in blood in rickets following administration of phosphorus. Am J Dis Child 40: 1177-l 192.
*Compere EL. 1930b. The effect of phosphorus in rickets. I. Roentgenologic changes in rickets following administration of phosphorus. Am J Dis Child 40:941–967.
*Condray JR. 1985. Elemental yellow phosphorus one-generation reproduction study in rats. IR-82-215; IRD No. 401-189. Monsanto Company, St. Louis, MO. [This study and IRDC 1985 are the same studies.]
*Cotton FA, Wilkinson G. 1966. Advanced inorganic chemistry: A comprehensive text. New York: John Wiley & Sons, 486–518.
*Cotton FA, Wilkinson G. 1980. Advanced inorganic chemistry: A comprehensive text. 4th ed. New York: John Wiley & Sons, 453–455.
*Dathe IU, Nathan DA. 1946. Electrocardiographic changes resulting from phosphorus poisoning. Am Heart J 31:98–102. -.21010881
*Davidson KA, Hovatter PS, Sigmon CF. 1987. Water quality criteria for white phosphorus. Oak Ridge National Laboratory. Final Report ORNL-6336. DE88-000645, NTIS ADA186613.
*Dearden WF. 1899. Fragilitas ossium amongst workers in Lucifer match factories. Br Med J 2:270–271.
*Devai I, Felfoldy L, Wittner I, 1988. Detection of phosphine: New aspects of the phosphorus cycle in the hydrosphere. Nature 333:343–345.
*Diaz-Rivera RS, Collazo PH, Pons ER, 1950. Acute phosphorus poisoning in a man: A study of 56 cases. Medicine 29:269–298.14796347
*Diaz-Rivera RS, Ramos-Morales F, Garcia-Palmieri MR, 1961. The electrocardiographic changes in acute phosphorus poisoning in man. Am J Med Sci 241:101–111.758-765.
*Dillon HK, Barrett WJ, Eller PM. 1978. Solid sorbent sampler for white phosphorus in air. Am Ind Hyg Assoc J 39:608–614.696621
*Dryer RL. 1970. The lipids. In: Tietz NW, ed. Fundamentals of clinical chemistry. Philadelphia: W.B. Saunders Co, 302–359.
*Dwyer HL, Helwig FC. 1925. Phosphorus poisoning in a child, from the ingestion of fireworks. JAMA 84:1254–1256.
*Dyer WJ, Hiltz DF, A&man RG, 1970. In vivo assimilation by cod muscle and liver tissue of elemental phosphorus from polluted sea water. Journal of the Fisheries Research Board of Canada 27: 1131–1139.
*Ehrentheil OF. 1957. Acute phosphorus poisoning: A case with severe granulocytopenia and hypoprothrombinemia. Bulletin of Tufts New England Medical Center 3:201–206.13489461
*Eldad A. Simon GA. 1991. The phosphorus burn - a preliminary comparative experimental study of various forms of treatment. Burns 17:198–200.1892550
*Hv Ellis, Hodgson JR Hwang SW, 1978. Mammalian toxicity of munitions compounds. Phase I: Acute oral toxicity, primary skin and eye irritation, dermal sensitization, disposition and metabolism and Ames tests of additional compounds. NTIS/AD-A069 333. [Unpublished study to be peer-reviewed].
*EPA. 1983. Method for chemical analysis of water and wastes: Methods 365.1 to 365.4. Cincinnati, OH: Environmental Monitoring and Support Laboratory, U.S. Environmental Protection Agency. EPA-600/4-79-020.
*EPA. 1989. Summary review of health effects associated with elemental and inorganic phosphorus compounds: Health issue assessment. EPA 500/8-89/072. Washington,DC: Office of Health and Environmental Assessment, U.S. Environmental Protection Agency.
*EPA. 1990. Environmental Protection Agency. Clean Air Act of 1990. 42 USC 7412, Title I, Part A, Set 112,52–55.
*EPA. 1991. White phosphorus: Health advisory. Washington, DC: Office of Drinking Water, U.S. Environmental Protection Agency. EPA 500/8-891072. NTIS PB91-161026/AS.
EPA. 1992a. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4, 40 CFR 117.1,40 CFR 117.3.
*EPA. 1992b. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.23, 40 CFR 264.
*EPA. 1992c. Environmental Protection Agency. 49 CFR 355, Appendix A, 354–365.
EPA. 1993. Preliminary assessment information and health and safety data reporting; addition of chemicals. Washington, DC: U.S. Environmental Protection Agency, Federal Register 58(246):68311–16.
*Farr TD. 1950. Phosphorus. Properties of the element and some of its compounds. Tennessee Valley Authority, Wilson Dam, AL. Chemical Engineering Report No. 8.
*Ferraro A, Jervis GA, English WH. 1938. Pathological changes in the brain in cases of experimental phosphorus intoxication. Psychiatr Q 12:294–305.
Fleming RB L, Collings GH Jr. 1951. The chylomicron count as an indictor of phosphorus poisoning. Archives of Industrial Hygiene and Occupational Medicine 4:567–572.14877316
*Fleming RB L, Miller JW, Swayne VR Jr. 1942. Some recent observations on phosphorus toxicology. J Ind. Hyg. Tox. 24:154–158.
*Fletcher GL. 1971. Accumulation of yellow phosphorus by several marine invertebrates and seaweed. Journal of the Fisheries Research Board of Canada 28:793–795.
*Fletcher GL. 1974. The dynamics of yellow phosphorus in Atlantic cod and Atlantic salmon: Biological half-times, uptake rates and distribution in tissues. Environ Physio Biochem 4:121–138.
*Fletcher GF, Galambos JT. 1963. Phosphorus poisoning in humans. Arch Intern Med 112:846–852.14056851
*Fritz B, Lorenz K, Steinert W, 1982. Laboratory kinetic investigations of the tropospheric oxidation of selected industrial emissions. Commission of European Communities. EUR, EUR7624, 192-202.
*Frye FL, Cucuel J-P. 1969. Acute yellow phosphorus poisoning in a cat. Vet Med Small Animal Clin 64:995–996.
Gan H, Zhao X, Liu J. 1993. Spectrophotometric determination of yellow phosphorus in wastewater. Huajing Kexue 14(3):83–85.
*Ganote CE, Otis JB. 1969. Characteristic lesions of yellow phosphorus-induced liver damage. Lab Invest 21:207–213.5811075
Garrison PJ, Asplund TR. 1993. Long-term 15 years results of NPS controls in an agricultural watershed upon receiving lake’s water quality. Water Science and Technology 28(3-5):441–449.
*Garry VF, Good PF, Manivel JC, 1993. Investigation of a fatality from nonoccupatio&‘aluminum phosphide exposure: Measurement of aluminum in tissue and body fluids as a marker of exposure. J Lab Clin Med 122(6):739–747.7993395
*Garry VF, Griffith J, Danzl TJ, 1989. Human genotoxicity: Pesticide applicators and phosphine. Science 246:251–255.2799386
Geehr EC, Salluzzo RF. 1992. Dermal injuries and burns from hazardous materials. In: Sullivan JB Jr, Krieger GR., eds. Hazardous Materials Toxicology, Clinical Principles of Environmental Health. Baltimore, Maryland: Williams and Wilkins, 415424.
*Ghoshal AK, Porta EA, Hartroft WS. 1969. The role of lipoperoxidation in the pathogenesis of fatty livers induced by phosphorus poisoning in rats. Am J Pathol 54:275–291.5765566
*Ghoshal AK, Porta EA, Hartroft WS. 1971. Isotopic studies on the absorption and tissue distribution of white phosphorus in rats. Exp Mol Pathol 14:212–219.4323485
Glennon JP, Pearson JG, Barkley JJ, 1977. Munitions environmental quality standards research status report. Prepared by U.S.Army Medical Bioengineering Research and Development Laboratory, Fort Detrick. Frederick MD. AD-A9506091.
Goh LY, Wong RC S, Sinn E. 1993. Novel polycyclic phosphane-to-metal coordination. Reaction of (CpCr(C0)3)2 with elemental phosphorus and structure and paramagnetism of the odd-electron complex (CpCr(C0)2)5PlO. Organometallics 12(3):888–894.
*Goldblatt MW, Oakeshott SH. 1943. The inactivation of phosphorus on the skin. Br Med J 1:128–129.20784659
*Gorzny K. 1972. Analysis of elemental phosphorus. In: Halmann M, ed. Analytical chemistry of phosphorus compounds, Vol. 37. New York: John Wiley Interscience, 361–370.
*Greenberger NJ, Robinson WL, Isselbacher KJ. 1964. Toxic hepatitis after the ingestion of phosphorus with subsequent recovery. Gastroenterology 47:179–183.14201407
*Guyton AC. 1976. Textbook of medical physiology. Philadelphia: W.B. Saunders Co, 1052–1060.
*Guyton AC. 1981. Textbook of medical physiology. Philadelphia: W.V. Saunders Co, 977–1091.
*Harm RG and Veale RA. 1910. A fatal case of poisoning by phosphorus, with unusual subcutaneous hemorrhages. Lancet 1:163–164.
*Harper HA. 1969. Review of physiological chemistry. Los Altos: Lange Medical Publishers, 429–430.
*Hawley GG, ed. 1981. The condensed chemical dictionary, 10th ed. New York: Van Nostrand Reinhold co., 808–810.
*HazDat. 1995. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. March 9, 1995.
*Heimann H. 1946. Chronic phosphorus poisoning. Journal of Industrial Hygiene and Toxicology 28:142–150.20992674
*Henry RJ. 1967. Clinical chemistry: Principles and techniques. New York: Harper and Row, Publ., 409–416.
*Hilton HW, Robison WH. 1972. Fate of zinc phosphide and phosphine in the soil-water environment. J Agric Food Chem 20:1209–1213.5083526
*HSDB. 1993. Hazardous Substances Data Base. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. February 1993.
*Hudson RF. 1965. Structure and mechanism in organo-phosphorus chemistry. New York: Academic Press, 1-7,37–39.
*Hughes JP W, Baron R, Buckland DH, 1962. Phosphorus necrosis of the jaw: A present day study. Br J Ind Med 19:83–99.14449812
*Humphreys EM, Halpert B. 1931. Acute phosphorus poisoning. Am J Dis Child 41:354–359.
Huruya A. 1928. Studies on the phosphorus intoxication of rabbits. J Biochem (Tokyo) 10:63–95.
*Hurwitz A. 1972. Effects of microsomal enzyme inducers on animals poisoned with hepatotoxins. Toxicol Appl Pharmacol 22:339–346.5041367
Ibraev SA, KuIkybaev GA, Rys-Uly M. 1992. Morphological mechanisms of myocardial damage with chronic phosphorus intoxication. Zdravookhr Kaz 12:13–15.
*Idler DR. 1972. Coexistence of a fishery and a major industry in Placentia Bay. In: Jangaard PM, ed. 1972. Effects of elemental phosphorus on marine life. Fisheries Research Board of Canada, Halifax, Nova Scotia. Circular No. 2, 1-6.
*Idler DR, Fletcher GL, Addison RF. 1981. Effects of yellow phosphorus in the Canadian environment. National Research Council of Canada, Ottawa, Ontario. NRCC 17587.
*IRDC. 1985. One-generation reproduction study in rats with elemental phosphorus. EPA/OTS Public Files, Washington, DC. IR-82-215. Fiche #OTS0518525-1. [Unpublished study]
*IRIS. 1995. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. December 11.1995.
Jacqueson A, Thevenin M, Warnet JM, 1977. Sex influence on the experimental fatty liver induced by white phosphorus and Amanita phalloides in the rat. Acta Pharmacol Toxicol 41:322–329.
*Jacqueson A. Thevenin M, Warnet JM, 1978. Comparative study of the protective effect of an anabolic steroid. The 19-nortestosterone-phenylpropionate (19 NTPP) on liver steatosis induced by Amanita phalloides and white phosphorus in rats. Arch Toxicol 1: 193– 196.
*Jacqueson A, Thevenin M, Warnet JM, 1979. Accentuation of white phosphorus induced fatty liver by phenobarbitone in male rats compared to female rats. Arch Toxicol 2:327–331.
*Jakhi SA, Parekh BK, Gupta S. 1983. Phosphorus necrosis of the maxilla. J Oral Med 38: 174–176.6583354
*Jelenko C. 1974. Chemicals that “burn.” J Trauma 14:65–72.4809719
*Kennon R, Hallam JW. 1944. Modem phosphorus caries and necrosis. Br Dent J 76:321–330.
*Kenjoyan TR. 1983. White phosphorus burns: Case report and literature review. Mil Med 148:881–884.6419161
*Krishnan SS, Gupta RC. 1970. Determination of phosphides and white phosphorus in biological materials by neutron activation analysis. Anal Chem 42:557–560.5431517
Kulkybaev GA. 1993. Blood serum lipids in chronic phosphorus intoxication under the conditions of a varied diet. Vopr Pitan 0( 1):34–37.
Kulkybaev GA, Merkusheva NV. 1991. Effect of yellow phosphorus on the Krebs cycle in the tissue of rat testes. Gig Sanit 0(8):90.
Kulkybaev GA, Merkusheva NV. 1992a. Dynamics of the activity of NAD-dependant isocitrate dehydrogenase in rat liver homogenate under the effects of harmful substances in the phosphorus industry. Gig Tr Prof Zabol 0(1):21–23.
Kulkybaev GA, Merkusheva NV. 1992b. Effects of polyunsaturated fatty acids on Krebs cycle in the kidneys of rats under the conditions of chronic phosphorus intoxication. Vopr Pitan Mar-Apr:51–53.
Kulkybaev GA, Merkusheva NV. 1992 ~. Influence of polyunsaturated fatty acids on Krebs cycle in rat kidneys under conditions of chronic phosphorus intoxication. Vopr Pitan 0(2):51–53.
Kulkybaev GA, Merkusheva NV. 1992d. Time course of NAD-dependant isocitrate dehydrogenase activity in homogenized rat liver exposed to toxic products of the phosphorus industry. Gig Tr Prof Zabol 0(1):21–23.
*Kumar MD, Somasundar K, Rajendran A. 1985. Stability of phosphorus species in seawater. Indian Journal of Marine Sciences 14:20–23.
*Lai MG, Rosenblatt DH. 1977a. Identification of transformation products of white phosphorus in water. Naval Surface Weapons Center, Silver Spring, MD. Final Report No. NSWC/WOL/TR-76-103. ADA041068.
*Lai MG, Rosenblatt DH. 1977b. Determination of ultramicro quantities of elemental phosphorus in water by neutron activation analysis. Naval Surface Weapons Center, Silver Spring, MD. Final Technical Report NSWC/WOL TR 77-49, ADA091773.
*Latner AL. 1975. Clinical biochemistry. Philadelphia: W.B. Saunders Co., 47-49,279-315,479, 842.
*Lawrence JS, Huffman MM. 1929. An increase in the number of monocytes in the blood following subcutaneous administration of yellow phosphorus in oil. Arch Path01 7:813–819.
Lawson DE, Brockett BE. 1993. Preliminary assessment of sediment and erosion in Eagle River Flats, South-Central Alaska. Cold Regions Research and Engineering Laboratory, Hanover, NH. NTIS/ADA276 997. CRREL-93-23.
*Lee CC, Dilley JV, Hodgson JR, 1975. Mammalian toxicity of munition compounds: Phase I. Acute oral toxicity, primary skin and eye irritation, dermal sensitization and disposition and metabolism. Environmental Protection Research Division, U.S. Army Medical Research and Development Command, Washington,DC.
*Legge TM. 1920. Report of cases of phosphorus necrosis. Journal of Industrial Hygiene 2:50–52.
*Liu DK, Shen D-X, Chang S-G. 1991. Removal of NO, and SO, from flue gas using aqueous emulsions of yellow phosphorus and alkali. Environmental Science and Technology 2555–60.
Liu Q, Zhou J. 1992. Mechanisms involved in subacute liver damage caused by phosphorus and carbon tetrachloride. Zhonghua Laodong Weisheng Zhiyebing Zazhi 10(4):202–204.
Liu Y, Zhou J. 1992. Hepatic fibrosis and its biochemical changes induced by carbon tetrachloride, yellow phosphorus and trinitrotoluene. Weisheng Dulixue Zazhi 6(3):181–183, 209.
*Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Rheel WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York: McGraw-Hill Book Co., 4–9.
*Maddock BG, Taylor D. 1976. The acute toxicity of dissolved elemental phosphorus to cod (Gladus morhua). Water Research. 10:289–294.
*Mallory FB. 1933. Phosphorus and alcoholic cirrhosis. Am J Path01 9:557–567.
Maruo T. 1955. [Experimental study on poisoning due to gas of yellow phosphor. Part I: The hemogram of rabbits]. Fukuoka Acta Medica 46:604–615. (Japanese)
*Matsumoto S, Kohri Y, Tanaka K. 1972. A case of acute phosphorus poisoning with various electrocardiographic changes. Jpn Circ J 36:963–970.4678754
*McCarron MM, Gaddis GP, Trotter AT. 1981. Acute yellow phosphorus poisoning from pesticide pastes. Clinical Toxicology 18:693–711.7273676
*McIntosh R. 1927. Acute phosphorus poisoning. Am J Dis Child 34:595–602.
*Nam SI, Roebuck BD, Walsh ME. 1994. Uptake and loss of white phosphorus in American kestrels. Environmental Toxicology and Chemistry 13(4):637–641.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1991. National Air Toxics Information Clearinghouse. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Research Triangle Park, NC and State and Territorial Pollution Program Administrators/Association of Local Air Pollution Control Officials, September 1991,4–202. NTIS PB92-143700.
*Newburger RA, Beaser SB, Shwachman H. 1948. Phosphorus poisoning with recovery accompanied by electrocardiographic changes. Am J Med 4:927–930.18860413
*NIOSH. 1987. Manual of analytical methods. 3rd ed. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 7905-l to 7905-4.
NIOSH. 1992. NIOSH recommendations for occupational safety and health compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, NTIS PB92-162536.
*NOES. 1991. National Occupational Exposure Survey. National Institute of Occupational Safety and Health, Cincinnati, OH
*NSC. 1990. Phosphorus (elemental, white or yellow). Data sheet I-282 Rev. 90. National Safety Council, Chicago, IL.
*Nyunt KM. 1983. Match industry. Encyclopedia of Occupational Health and Safety 2:1286–1287.
*Obermer E. 1943. Phosphorus burns. Lancet 1:202.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-438. April 1990.
*Pani P, Gravela E, Mazzarino C, 1972. On the mechanism of fatty liver in white phosphoruspoisoned rats. Exp Mol Path01 16:201–209.
*Paradisi L, Panagini C, Negro F, 1984. Behavior of cyclic nucleotides and Ca^2+^ levels in liver tissue of rats poisoned by white phosphorus and trichlorobromomethane. Cell Biochem Funct 2: 11l-l14.6380790
*Peacock DB. 1993. Personal communication between D.B. Peacock, Office of Toxic Substances, U.S. Environmental Protection Agency and B. Ruoff, Syracuse Research Corp.
*Pearson JG, Bender ES, Taormina DH, 1976. Effects of elemental phosphorus on the biota of Yellow Lake, Pine Bluff Arsenal, Arkansas. March - January 1975. Edgewood Arsenal, Aberdeen Proving Ground, MD. Technical Report EO-TR-76077. ADA035925.
Peterson TC, Isbrucker RA, Martinka M. 1991. Collagen estimation in the yellow phosphorus induced pig model of liver disease. Clin Invest Med 14(4 suppl):A64.
*Peterson TC, Williams CN, Malatjalian DA. 1991. Monocyte aryl hydrocarbon hydroxylase (AHH) activity mimics Kupffer cell and hepatocyte AHH activity in animal model of liver disease. Can J Physiol Pharmacol69:1797-1803.
*Phemister DB. 1918. The effect of phosphorus on growing, normal, and diseased bones. JAMA 70:1737–1743.
*Pietras RJ, Stavrakos C, Gunnar RM, 1968. Phosphorus poisoning simulating acute myocardial infarction. Arch Intern Med 122:430–434.4235026
*Potter WT, Garry VF, Kelly JT, 1993. Short Communication: Radiometric assay of red cell and plasma cholinesterase in pesticide appliers from Minnesota. Toxicol Appl Pharmicol 119:150–155.
*Potter WT, Rong S, Griffith J, 1991. Phosphine-mediated Heinz body formation and hemoglobin oxidation in human erythrocytes. Toxicol Lett 57:37–45.2048160
*Rabinowitch IM. 1943. Treatment of phosphorus burns. Can Med Assoc J 48:29l-296.
*Racine CH, Walsh ME, Collins CM, 1992a. Waterfowl mortality in Eagle River Flats, Alaska: The role of munitions residues. Cold Regions Research and Engineering Laboratory, Hanover, NH. NTIS/ADA252 646/5. CRREL-92-5.
*Racine CH, Walsh ME, Collins CM, 1992b. Remedial investigation report: White phosphorus contamination of salt marsh sediments at Eagle River Flats, Alaska. Cold Regions Research and Engineering Lab, Hanover, NH. NTIS/AD-A250 5 15/4.
*Racine CH, Walsh ME,Roebuck BD, 1992c. White phosphorus poisoning of waterfowl in an Alaskan salt-marsh. J Wild1 Dis 28:669–673.
*Rao S, Brown RH. 1974. Acute yellow phosphorus rat poisoning. 111 Med J 145:128–130.
*Renwick AG. 1989. Pharmacokinetics in toxicology. In: Hayes AW, ed. Principles and methods in toxicology. 2nd ed. New York: Raven Press, 837.
*Richardson SM, Weston RF. 1992. White phosphorus contamination of wetlands: Effects and options for restoration. In: Proceedings of the Federal Environmental Restoration ‘92, Vienna, VA, Apr. 15-17, 1992, 186–189.
*Rodriguez A, Bohn HL, Johnson GV. 1972. White phosphorus as a phosphate fertilizer. Soil Science Society of America Proceedings 36:364–366.
Roebuck BD, Walsh ME, Racine CH, 1994. Predation of ducks poisoned by white phosphorus: Exposure and risk to predators. Environmental Toxicology and Chemistry 13(10): 1613–1618.
*RTECS. 1993. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, Public Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Washington, DC. February 1993.
*Rubitsky HJ, Myerson RM. 1949. Acute phosphorus poisoning. Arch Intern Med 83:164–178.
*Ruzuddinov SR, Rys-Uly M. 1986. Morphology of the oral mucosa in rats exposed to high concentrations of phosphorus. Bull Exp Biol Med 101:135–138.
*Sax NI. 1984 ed. Dangerous properties of industrial materials. 6th ed. New York: Van Nostrand Reinhold Co., 2221.
*Scherling SS, Blondis RR. 1946. The effect of chemical warfare agents on the human eye. Military Surgeon 96:70–78.
Scott WJM. 1916. Experimental mitochondrial changes in the pancreas in phosphorus poisoning. Am J Anat 20: 237–253.
*Scoville W, Springer S, Crawford J. 1989. Response and cleanup efforts associated with the white phosphorus release, Miamisburg, Ohio. Journal of Hazardous Material 21:47–64.
*Seakins A, Robinson DS. 1964. Changes associated with the production of fatty livers by white phosphorus and by ethanol in the rat. Biochem J 92:308–312.5838074
*Shinn JH, Martins SA, Cederwall PL, 1985. Smokes and obscurants: a health and environmental effects data base assessment. A first-order, environmental screening and ranking of Army smokes and obscurants. Phase I Report. Lawrence Livermore National Library, Livermore, CA ADA175956.
*Sigal MV Jr, Buchanan DJ, Robinson CS. 1954. Studies on phosphorus intoxication. II. Fate of orally administered choline in dogs with damaged liver. American Medical Association Archives of Industrial Hygiene and Occupational Medicine 9:142–147.13113746
*Simon FA, Pickering LK. 1976. Acute yellow phosphorus poisoning: Smoking stool syndrome. JAMA 235:1343–1346.946251
*Sollman T. 1925. Studies of chronic intoxications on albino rats. VIII. Yellow phosphorus. J Pharmacol Exp Ther 24:119–122.
*Song Z, Lu Y, Gu X. 1985. Treatment of yellow phosphorus skin burns with silver nitrate instead of copper sulfate. Stand J Work Environ Health 11(Suppl.4): 33.
*Sontag LW. 1938. Acute phosphorus poisoning in an infant resulting from an antirachitic preparation. Am J Dis Child 566:114–118.
*Spanggord RJ, Podoll RT, Renwick RT, 1983. Environmental fate of white phosphorus/felt and red phosphorus/butyl rubber military screening smokes: Phase I - Literature review. Final Report. SRI International, Menlo Park, CA. Contract No. DAMD17-82-C-2320. AD-Al50 754.
*Spanggord RJ, Renwick R, Chou T-W, 1985. Environmental fate of white phosphorus/felt and red phosphorus/butyl rubber military screening smokes. Final Report. SRI International, Menlo Park, CA. Contract No. DAMD17-82-C-2320. AD176922.
*SRI. 1922. 1992 Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 85 1.
SRI International. 1995. Phosphorus (elemental). 1995 Directory of Chemical Producers.
*Starke WC, Pellerin RJ, Burnett DC. 1982. White phosphorus-felt smoke: Effects on reproduction in the rat. Report No. ARCSL-TR-82002, AD-Al 18682.
*Summerlin WT, Walder AI, Moncreif JA. 1967. White phosphorus burns and massive hemolysis. J Trauma 7:476–484.6024144
*Swarm RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85: 17–28.
*Talley RC, Linhart JW, Trevino AJ, 1972. Acute elemental phosphorus poisoning in man: Cardiovascular toxicity. Am Heart J 84:139–140.4263482
Tang PT, Wang XP, Lu DS. 1992. Changes in lactate dehydrogenase isoenzymes of mitochondriaand microsomes in hepatic damage caused by phosphorus, sodium arsenite, and carbon tetrachloride. Zhongguo Yaolixue Yu Dulixue Zazhi 6(4):292–296.
Taylor S, Walsh ME. Optimization of an analytical method for determining white phosphorus in contaminated sediments. Cold Regions Research and Engineering Laboratory, Hanover, NH. NTIS/ADA261 33319.
*Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Rheel WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York: McGraw-Hill Book Co, 15–16.
*Tietz NW. 1970. Electrolytes. In: Tietz NW ed. Fundamentals of clinical chemistry. Philadelphia: W.B. Saunders Co., 636–639.
*Tolle DA, Arthur MF, Chesson J, 1988. Terrestrial microcosm evaluation of two Army smokeproducing compounds. Battelle Columbus Labs, Columbus OH. NTIS/AD-A190 797/l.
*Torrielli MV, Pani P, Gabriel L, 1974. The pathophysiological significance of the hepatic drug metabolizing enzyme system in the liver damage induced by Ccl, and white phosphorus. In: Duncan WAM, ed. Experimental model systems in toxicology and significance in man. Volume 15. Excerpta Medica International Congress Series no. 3 11. Amsterdam: Excerpta Medica.
*TRI93. 1995. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. Uchida H, Nishinaka K, Ogi K. Manufacture of high-purity phosphorus for semiconductor materials. Mitsubushi Materials Corp., Japan.
*Uhrmacher JC, Werschulz PP, Schultz DO, 1986. A health and environmental effects data base assessment of U.S.Army waste material. Final Report, Phase II Report, Carltech Associates, Inc., Columbia, MD. Contract No. DAMD17-84-C-4133.
*Van Voris P, Cataldo DA, Ligotke MW, 1987. Evaluate and characterize mechanisms controlling transport, fate and effects of Army smokes in the aersol wind tunnel. Pacific Northwest Laboratories, Richland, Washington.
*Van Wazer JR. 1982. Phosphorus and the phosphides. In: Grayson M, Eckroth D, eds. Kirth-Othmer encyclopedia of chemical technology, Vol. 17,3rd ed., New York: John Wiley and Sons, 473–490.
*Walker J Jr, Galdston M, Wexler J, 1947. WP casualties at Edgewood Arsenal, Maryland, 1945. Report 103, AD 824420. Edgewood Arsenal, MD.
*Walser M, Mudge GH. 1960. Renal excretory mechanisms. In: Comar CL, Bonner F, eds. Mineral metabolism: An advanced treatise. Vol. l(Part A): Principles, process, and systems. New York: Academic Press, 327–329.
Walsh ME. 1995. Analytical method for white phosphorus in water. Bulletin of Environmental Contamination and Toxicology 54(3):432–439.7749278
*Walsh ME, Taylor S. 1993. Analytical method for white phosphorus residues in munitions-contaminated sediments. Analytica Chimica Acta 282(N1):55–61.
Wang ZM. 1992. Oscillopolarographic determination of traces of yellow phosphorus in water. Lihua Jianyan, Huaxue Fence 28(5):304, 306.
*Ward EF. 1928. Phosphorus necrosis in the manufacture of fireworks. Journal of Industrial Hygiene and Toxicology 10:314–330.
*Warnock RE. 1972. Escape of elemental phosphorus from soil when applied as white phosphorus or the phosphorus-sulfur eutectic solution. Journal of Environmental Quality 1:31l-314.
Wasti K, Abaidoo KJ R, Villaume JE. 1978. A literature review-problem definition studies on selected toxic chemicals. Vol. 2: Occupational health and safety aspects of phosphorus smoke compounds. AD A056019.
*Weast RC ed. 1985. CRC handbook of chemistry and physics, 66th ed., Boca Raton, FL: CRC Press, B-100; B-122 to B-123.
*Wechsler L, Wechsler RL. 1951. Phosphorus poisoning: The latent period and unusual gastrointestinal lesions. Gastroenterology 17:279–283.14813415
*Wertham F. 1932. Central nervous system in acute phosphorus poisoning. Archives of Neurology and Psychiatry 28:320–330.
*Whalen JP, O’Donohue N, Krook L, 1973. Pathogenesis of abnormal remodeling of bones; Effects of yellow phosphorus in the growing rat. Anat Ret 177: 15–22.
*White SA, Armstrong GC. 1935. White phosphorus smoke: Its irritating concentration for man and its toxicity for small animals for one-hour exposures. E.A.T.P. 190, Project A 5.2-1.
Whitely HJ, Stoner HB, Threlfall CJ. 1953. The uptake of radioactive phosphorus by the skin of the rabbit. Br J Exp Pathol 34:73–80.13032334
*Williamson CS, Mann FC. 1923. Studies on the physiology of the liver. V. The hepatic factor in chloroform and phosphorus poisoning. Am J Physiol 65:267–276.
Wilms EB, van Xanten NH W, Meulenbelt J. 1990. Smoke producing and inflammable materials. Prepared for National Institute for Public Health and Environmental Protection, Bilthoven, Netherlands. NTIS PB92-104967.
*Winek CL, Collom WD, Fusia EP. 1973. Yellow phosphorus ingestion-three fatal poisonings. Clin Toxicol 6:541–545.4790679
Yimin L, Jiongliang Z. 1992. Research into the relationship of hepatic fibrosis with various biochemical indices induced by carbon tetrachloride, yellow phosphorus, and trinitrotoluene. Weisheng Dulixue Zazhi 6(3):181–183,209.
Zhu C, Zhou J, He Y. 1994. Alteration of serum corticosteroid binding-globulin level during exposure to yellow phosphorus. Zhonghua Laodong Weisheng Zhiyebing Zazhi 12(3):14–17.
Zitko V, Aiken DE, Tibbo SN, 1970. Toxicity for yellow phosphorus to herring (Clupea harengus), Atlantic salmon (Salmo salar), lobster (Homorus umericunus), and beach flea (Gammarus oceanicus). Journal of the Fisheries Research Board of Canada 27:21–29.