# 7 REGULATIONS AND ADVISORIES

International, national, and state regulations and guidelines pertinent to human exposure to white phosphorus are summarized in Table 7-1. No regulations or guidelines for white phosphorus smoke were identified.

A chronic oral reference dose (RfD) of 0.00002 mg/kg/day has been derived and verified by EPA for white phosphorus (IRIS 1993). The RfD is based on a NOAEL of 0.015 mg/kg/day for parturition mortality and forelimb hair loss in rats gavaged with 0.015 mg/kg/day in a one-generation reproduction study (Condray 1985).

TABLE 7-1 Regulations and Guidelines Applicable to White Phosphorus

Agency | | Description | Information | Reference
[underlined: NATIONAL]
Regulations:
a. | Air:
| EPA | Listed as Hazardous Air Pollutant | Yes | EPA 1990
| OSHA | PEL TWA | 0.1 mg/m^3^ | HSDB 1995
b. | Other:
| EPA OERR | Reportable quantity | 1 pound^a^ | IRIS 1995
| | Extremely Hazadous Substance TPQ | 1/100 pounds | EPA 1992c (40 CFR 355, APP A)
| EPA OPP | Intent to Cancel, Restrict or Require Reregistration of Pesticide Products Containing Phosphorus | Yes^b^ | HSDB 1995
| EPA OSW | Designation as Hazardous Substance | Yes | HSDB 1995
| | Listing as hazardous waste: (D003) | Yes^c^ | HSDB 1995
| EPA OTS | Toxic Chemical Release Reporting: Community Right To Know | Yes | HSDB 1995
Guidelines:
a. | Air:
| ACGIH | TLV TWA | 0.1 mg/m^3^ | ACGIH 1992
| NIOSH | REL TWA | 0.1 mg/m^3^ | NIOSH 1992
b. | Other:
| EPA | Oral RfD | 2×10^−5^ mg/kg/day | IRIS 1995
| | Carcinogen classification | Group D^d^ | IRIS 1995
[underlined: STATE]
Regulations and Guidelines:
a. | Air: | Acceptable ambient concentration guidelines or standards | | NATICH 1991
| Connecticut | | 2.00 μg/m^3^ 8 hour
| Florida/Fort Lauderdale | | 1.00×10^−3^ μg/m^3^ 8 hour
| Florida/Pinella | | 1.00 μg/m^3^ 8 hour
| | | 2.40×10^−1^ μg/m^3^ 24 hour
| Florida/Tampa | | 1.00×10^−3^ mg/m^3^ 8 hour
| Nevada | | 2.00×10^−3^ mg/m^3^ 8 hour
| New York | | 3.30×10^−1^ μg/m^3^ 1 year
| North Dakota | | 1.00×10^−3^ mg/m^3^ 8 hour
| Oklahoma | | 1.00×10^+1^ μg/m^3^ 24 hour
| Texas | | 1.00 μg/m^3^ 30 minutes
| | | 1.00×10^−1^ μg/m^3^ annual
| Virginia | | 1.70 μg/m^3^ 24 hour
b. | Water:
| Florida | Restriction in marine waters | ≤0.1 μg/L | CELDS 1992
| Ohio | Criteria for nuisance prevention and water supply use designation | Note 1
c. | Other:
| Connecticut | Registration & use prohibited as pesticide | Yes | CELDS 1992
| Hawaii | Restricted usage | Yes
| Iowa | Restricted usage | Yes
| Maine | Special provisions for waste managements | Yes

a Based on aquatic toxicity

b List “C” reregistration status: Case #3111, Awaiting data/data in review. Reregistration is supported.

c A solid waste containing yellow and white phosphorus may become characterized as a hazardous waste when subjected to testing for reactivity as stipulated in 40 CFR 261.23 and, if so characterized, must be managed as a hazardous waste (40 CFR 261.23 [7/1/90]).

d Group D = Not classifiable as to carcinogenicity in humans

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; NIOSH = National Institute for Occupational Safety and Health; OERR = Office of Emergency and Remedial Response; OPP = Office of Pesticide Programs; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Waste; OTS = Office of Toxic Substances; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limit; RfD = Reference Dose; TLV = Threshold Limit Value; TPQ = Threshold Planning Quantity; TWA = Time-Weighted Average

Note 1: Total phosphorus as P shall be limited to the extent necessary to prevent nuisance growth of algae, weeds, and slimes that result in a violation of the water quality criteria. Phosphorus discharges shall not exceed a daily average of one milligram per liter as total P, or stricter requirements imposed by Ohio Environmental Protection Agency.