# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of white phosphorus is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of white phosphorus and white phosphorus smoke is located in Table 3-2.

Elemental phosphorus exists in several allotropic forms (Van Wazer 1982). The best known and most important commercially is the a-white phosphorus whose properties are given in Table 3-2. Commercial white phosphorus is 99.9% pure, with a slight yellow color caused by traces of red phosphorus impurities. Hence, white phosphorus also is known as yellow phosphorus. When a-white phosphorus is cooled below -79.6^°^C, P-white phosphorus forms. Other important solid allotropes of phosphorus are red and black phosphorus (Van Wazer 1982).

The U.S. Army uses at least two phosphorus-based smoke/obscurants for training and testing activities (Shinn et al. 1985). One such agent is white phosphorus/felt (WP/F), and the other is red phosphorus/butyl rubber (Spanggord et al. 1985). WP/F consists of 75-80% white phosphorus solidified into a cellulose (felt) matrix (20-25%). When WP/F is burnt, besides unburnt white phosphorus, the smoke consists primarily of oxidation and hydrolysis products of phosphorus. For example, when white phosphorus burns in air it produces oxides of phosphorus including phosphorus pentoxide (P_4_O_10_, and phosphorus trioxide (P_4_0_6_). These oxides react with moisture present in air to form a number of phosphorus-containing acids, such as orthophosphoric acid (H_3_PO_4_), pyrophosphoric acid (H_4_P_2_O_7_), orthophosphorus acid (H_3_PO_3_), hypophosphorus acid (H_3_PO_2_), polyphosphoric acid of the general formula H_n+2_P_n_O_3n+1_, where n=2-8, and a homologous series of linear and cyclic P_6_-P_16_ polyphosphates (Spanggord et al. 1983; Tolle et al. 1988). The composition of white phosphorus smoke will change with time (Spanggord et al. 1988). In the absence of stoichiometric quantities of oxygen, phosphine (PH_3_) may form in WP/F smoke from the reaction of unreacted phosphorus with moisture in air (Spanggord et al. 1983).

TABLE 3-1 Chemical Identity of White Phosphorus

Characteristic | Information | Reference
Chemical name | White phosphorus | CAS 1995
Synonym(s) | Yellow phosphorus, phosphorus tetramer | CAS 1995
Registered trade name(s) | No data
Chemical formula | P_4_ | CAS 1995
Chemical structure | [image] | Spanggord et al. 1985
Identification numbers:
CAS registry | 7723-14-0 | CAS 1995
NIOSH RTECS | TH3500000 | RTECS 1995
EPA hazardous waste | D003 | HSDB 1995
OHM/TADS | 7216855 | RTECS 1995
DOT/UN/NA/IMCO shipping | UN1381 | RTECS 1995
HSDB | 1169 | HSDB 1995
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/ Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemicals Substances

TABLE 3-2 Physical and Chemical Properties of White Phosphorus

Property | Information | Reference
Molecular weight | 123.895 | Budavari et al. 1989
Color
Pure form | Colorless to white | Budavari et al. 1989
Technical form | Yellow | Van Wazer 1982
Physical state | Waxy solid | Budavari et al. 1989
Melting point | 44.1°C | Budavari et al. 1989
Boiling point | 280°C | Budavari et al. 1989
Density:
at 20°C | 1.82 g/cm^3^ | Weast 1985
Odor | Garlic-like | HSDB 1993
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 15°C | 3 mg/L | Weast 1985
Organic solvent(s) | Soluble in alkali, ether, chloroform, benzene, toluene | Weast 1985
Partition coefficients:
Log K_ow_ | 3.08 | Spanggord et al. 1985
Log K_oc_ | 3.05 (estimated)^a^
Vapor pressure:
at 20°C | 0.025 mmHg; 0.026 mmHg | Farr 1950; HSDB 1993
Henry’s law constant:
at 20°C | 2.11×10^−3^ atm m^3^/mol; 1.36×10^−3^ atm m^3^/mol^b^ | Spanggord et al. 1985
Autoignition temperature | 30°C (moist air); 35–46°C (dry air) | NSC 1990
Flashpoint | Spontaneous in air | Sax 1984
Flammability limits | No data
Conversion factors | 1 ppm = 5.150 mg/m^3^ at 20°C
Explosive limits | No data

a Estimated from the regression equation given by Lyman (1982). The experimental values (range 2.56–2.77) of Spanggord et al. (1985) are unreliable due to the reactivity of white phosphorus.

b Estimated from the ratio of vapor pressure at 20°C and the water solubility at 15°C.

Reactions of white phosphorus that lead to the formation of some typical products are listed below (Cotton and Wilkinson 1980; Spanggord et al. 1985).

P_4_ + 3 O_2_ → P_4_^+ 3^ O_6_ (phosphorus trioxide) P_4_ + 5 O_2_ → P_4_^+ 5^ O_10_ (phosphorus pentoxide) P_4_ O_10_ + 6 H_2_ O → 4 H_3_ P^+ 5^ O_4_ (orthophosphoric acid) P_4_ O_10_ + 2 H_2_ O → 4 H P^+ 5^ O_3_ (metaphosphoric acid) P_4_ O_10_ + 4 H_2_ O → 2 H_4_ P_2_^+ 5^ O_7_ (pyrophosphoric acid) P_4_ O_6_ + 2 H_2_ O → 4 H P^+ 3^ O_2_ (metaphosphorus acid) P_4_ O_6_ + 6 H_2_ O → 4 H_3_ P^+ 3^ O_3_ (orthophosphorus acid) P_4_ + 8 H_2_ O → 4 H_3_ P^+ 3^ O_2_ + 2 H_2_ (hypophosphorus acid) 4 H_3_ P O_3_ → H_3_ P^+ 5^ O_4_ + P^- 3^ H_3_ (phosphine by disproportionation) 3 H_3_ P O_4_ → H_5_ P_3_^+ 5^ O_10_ + 2 H_2_ O (triphosphoric acid)

Organic constituents that may be found in ppb levels in WP/F smoke include methane, ethylene, carbonyl sulfide, acetylene, 1,4-dicyanobenzene, 1,3-dicyanobenzene, 1,2-dicyanobenzene, acetonitrile, and acrylonitrile (Tolle et al. 1988). Since white phosphorus contains boron, silicon, calcium, aluminum, iron, and arsenic in excess of 10 ppm as impurities (Berkowitz et al. 1981), WP/F smoke also contains these elements and possibly their oxidation products. The physical properties of a few major compounds that may be important for determining the fate of WP/F smoke in the environment are given in Table 3-3.

Table 3-3 Physical Properties of Major Compounds in White Phosphorus Smoke^a^

Property | Phosphorus trioxide | Phosphorus pentoxide | Ortho-phosphorus acid | Ortho-phosphoric acid | Phosphine
Molecular formula | P_4_O_6_ | P_4_O_10_ | H_3_PO_3_ | H_3_PO_4_ | PH_3_
Molecular weight | 219.89 | 283.89 | 82.00 | 98.00 | 34.00
Color | White | White | Yellow | Colorless | Colorless
Physical state | Solid | Solid | Solid | Liquid or solid | Gas
Melting point | 23.8°C | 340°C^b^ | 73.6°C | 42.35°C | −133.5°C
Boiling point | 173.8°C (in N_2_) | Sublimes at 360°C^b^ | Decomposes at 200°C | Decomposes at 213°C | −87.4°C (auto-ignites 37.7°C^b^)
Density, g/cm^3^ | 2.135 at 21°C | 2.39 | 1.651 at 21.2°C | 1.834 at 15°C | 1.529 g/L
Odor | No data | No data | No data | No data | Garlic-like^b^
Solubility:
Water | Decomposes to H_3_PO_3_ at 20°C | Decomposes to H_3_PO_4_ at 20°C | 694 g/100 mL at 40°C | 548 g/100 in cold water | 0.398 g/L at 17°C; 0.381 g/L at 25°C
Organic solvent(s) | Soluble in carbon dioxide, chloroform ether | Insoluble in acetone | Soluble in ethanol | Soluble in ethanol^b^ | Soluble in ethanol, ether
Partition coefficients:
Log K_ow_ | Not relevant | Not relevant | Not relevant | Not relevant | No data
Log K_oc_ | Not relevant | Not relevant | Not relevant | Not relevant | No data
Vapor pressure | No data | No data | No data | No data | 760 mm at −87.4°C
Henry’s law
constant at 20°C | No data | No data | No data | No data | 0.09 atm m^3^/mol^c^

a All information obtained from Weast 1985 except where noted

b Hawley 1981

c Spanggord et al. 1985