# CHAPTER 8 REFERENCES

Adkins B, Van Stee EW, Simmons JE, . 1986. Oncogenic response of strain A/J mice to inhaled chemicals. J Toxicol Environ Health 17(2–3):311–322. 10.1080/15287398609530825.3083111
Ahn J, Rao G, Mamun M, . 2020. Soil–air partitioning of volatile organic compounds into soils with high water content. Environ Chem 17(8):545–557. 10.1071/en20032.
Akasaka S, Langouet S, Fink S, . 1997. Site-specific mutagenesis with two vinyl chloride-derived DNA adducts and comparison to homologs. Proc Am Assoc Cancer Res 38:124.
Albertini R, Clewell H, Himmelstein MW, . 2003. The use of non-tumor data in cancer risk assessment: reflections on butadiene, vinyl chloride, and benzene. Regul Toxicol Pharmacol 37(1):105–132. 10.1016/s0273-2300(02)00019-3.12662914
Alkhouri N, Mansoor S, Giammaria P, . 2014. The development of the pediatric NAFLD fibrosis score (PNFS) to predict the presence of advanced fibrosis in children with nonalcoholic fatty liver disease. PLoS ONE 9(8):e104558. 10.1371/journal.pone.0104558.25121514
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290. 10.1002/jat.2550030603.6376602
Anders LC, Lang AL, Anwar-Mohamed A, . 2016a. Vinyl chloride metabolites potentiate inflammatory liver injury caused by LPS in mice. Toxicol Sci 151(2):312–323. 10.1093/toxsci/kfw045.26962056
Anders LC, Yeo H, Kaelin BR, . 2016b. Role of dietary fatty acids in liver injury caused by vinyl chloride metabolites in mice. Toxicol Appl Pharmacol 311:34–41. 10.1016/j.taap.2016.09.026.27693805
Anderson D. 1999. Factors contributing to biomarker responses in exposed workers. Mutat Res 428(1–2):197–202. 10.1016/s1383-5742(99)00047-2.10517993
Anderson D. 2000. Examination of various biomarkers after occupational exposure to different chemicals. NATO ASI Ser A Life Sci 313:94–100.
Anderson D, Richardson CR. 1981. Issues relevant to the assessment of chemically induced chromosome damage in vivo and their relationship to chemical mutagenesis. Mutat Res 90:261–272. 10.1016/0165-1218(81)90006-9.6799821
Anderson D, Hodge MC, Purchase IF. 1976. Vinyl chloride: dominant lethal studies in male CD-1 mice. Mutat Res 40(4):359–370. 10.1016/0165-1218(76)90034-3.1012295
Anderson D, Richardson CR, Weight TM, . 1980. Chromosomal analyses in vinyl chloride exposed workers. Results from analysis 18 and 42 months after an initial sampling. Mutat Res 79(2):151–162. 10.1016/0165-1218(80)90083-x.7432373
Anderson D, Richardson CR, Purchase IF, . 1981. Chromosomal analysis in vinyl chloride exposed workers: comparison of the standard technique with the sister-chromatid exchange technique. Mutat Res 83(1):137–144. 10.1016/0027-5107(81)90078-6.7278872
Andrews AW, Zawistowski ES, Valentine CR. 1976. A comparison of the mutagenic properties of vinyl chloride and methyl chloride. Mutat Res 40(3):273–276. 10.1016/0165-1218(76)90054-9.785251
Asakura M, Sasaki T, Sugiyama T, . 2008. An improved system for exposure of cultured mammalian cells to gaseous compounds in the chromosomal aberration assay. Mutat Res 652(2):122–130. 10.1016/j.mrgentox.2008.01.004.18342567
Atkinson R. 1991. Kinetics and mechanisms of the gas-phase reactions of the NO3 radical with organic compounds. J Phys Chem Ref Data 20(3):459–507. 10.1063/1.555887.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
ATSDR. 2007. Interaction profile for: Chloroform, 1,1-dichloroethylene, trichloroethylene, and vinyl chloride. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/interactionprofiles/ip-13/ip13.pdf. August 26, 2021.
ATSDR. 2022. Vinyl chloride. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/spl/resources/index.html. July 19, 2023.
ATSDR. 2023. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/pha-guidance/toolbox/ATSDR_SHOWER_Model_v3_0_0.zip. July 13, 2023.
Attarchi MS, Aminian O, Dolati M, . 2007. Evaluation of liver enzyme levels in workers exposed to vinyl chloride vapors in a petrochemical complex: a cross-sectional study. J Occup Med Toxicol 2:6. 10.1186/1745-6673-2-6.17686177
Awara WM, El-Nabi SH, El-Gohary M. 1998. Assessment of vinyl chloride-induced DNA damage in lymphocytes of plastic industry workers using a single-cell gel electrophoresis technique. Toxicology 128:9–16. 10.1016/S0300-483X(98)00008-0.9704901
Azari MR, Tayefeh-Rahimian R, Jafari MJ, . 2016. Exploring a new method for the biological monitoring of plastic workers exposed to the vinyl chloride monomer. Toxicol Ind Health 32(12):1921–1926. 10.1177/0748233715596663.26319235
Baker LW, MacKay KP. 1985. Hazardous waste management. Screening models for estimating toxic air pollution near a hazardous waste landfill. J Air Pollut Control Assoc 35:1190–1195. 10.1080/00022470.1985.10466023.
Ballering LA, Nivard MJ, Vogel EW. 1996. Characterization by two-endpoint comparisons of the genetic toxicity profiles of vinyl chloride and related etheno-adduct forming carcinogens in Drosophila. Carcinogenesis 17(5):1083–1092. 10.1093/carcin/17.5.1083.8640917
Bao YS, Jiang H, Liu J. 1988. [The effects of vinyl chloride on pregnancy, parturition, and fetal development among female workers]. Zhonghua Yu Fang Yi Xue Za Zhi 22(6):343–346. (Chinese)3248460
Barbin A. 1998. Formation of DNA etheno adducts in rodents and humans and their role in carcinogenesis. Acta Biochim Pol 45(1):145–161. 10.18388/abp.1998_4329.9701507
Barbin A. 1999. Role of etheno DNA adducts in carcinogenesis induced by vinyl chloride in rats. IARC Sci Publ 150(150):303–313.
Barbin A. 2000. Etheno-adduct-forming chemicals: from mutagenicity testing to tumor mutation spectra. Mutat Res 462(2–3):55–69. 10.1016/s1383-5742(00)00014-4.10767618
Barbin A, Froment O, Boivin S, . 1997. p53 Gene mutation pattern in rat livers tumors induced by vinyl chloride. Cancer Res 57:1695–1698.9135010
Baretta ED, Stewart RD, Mutchler JE. 1969. Monitoring exposures to vinyl chloride vapor: breath analysis and continuous air sampling. Am Ind Hyg Assoc J 30(6):537–544. 10.1080/00028896909343171.5392460
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486. 10.1016/0273-2300(88)90047-5.3222488
Barrio-Lage GA, Parsons FZ, Narbaitz RM, . 1990. Enhanced anaerobic biodegradation of vinyl chloride in groundwater. Environ Toxicol Chem 9(4):403–415. 10.1002/etc.5620090402.
Barton HA, Creech JR, Godin CS, . 1995. Chloroethylene mixtures: pharmacokinetic modeling and in vitro metabolism of vinyl chloride, trichloroethylene, and trans-1,2-dichloroethylene in rat. Toxicol Appl Pharmacol 130(2):237–247. 10.1006/taap.1995.1029.7871537
Bartsch H. 1976. Predictive value of mutagenicity test in chemical carcinogenesis. Mutat Res 38:177 190. 10.1016/0165-1161(76)90189-8.934170
Bartsch H, Nair J. 2000. Ultrasensitive and specific detection methods for exocyclic DNA adducts: Markers for lipid peroxidation and oxidative stress. Toxicology 153(1–3):105–114. 10.1016/S0300-483X(00)00307-3.11090950
Bartsch H, Malaveille C, Montesano R. 1975. Human, rat and mouse liver-mediated mutagenicity of vinyl chloride in S. typhimurium strains. Int J Cancer 15(3):429–437. 10.1002/ijc.2910150309.1095499
Bartsch H, Malaveille C, Montesano R. 1976. The predictive value of tissue-mediated mutagenicity assays to assess the carcinogenic risk of chemicals. IARC Sci Publ 12:467–491.
Bartsch H, Malaveille C, Barbin A, . 1979. Mutagenic and alkylating metabolites of halo-ethylenes, chlorobutadienes and dichlorobutenes produced by rodent or human liver tissues. Evidence for oxirane formation by P450-linked microsomal mono-oxygenases. Arch Toxicol 41(4):249–277. 10.1007/BF00296896.373707
Becker R, Nikolova T, Wolff I, . 2001. Frequency of HPRT mutants in humans exposed to vinyl chloride via an environmental accident. Mutat Res 494(1–2):87–96. 10.1016/s1383-5718(01)00182-6.11423348
Belli S, Bertazzi PA, Comba P, . 1987. A cohort study on vinyl chloride manufacturers in Italy: study design and preliminary results. Cancer Lett 35(3):253–261. 10.1016/0304-3835(87)90127-3.3594422
Bencko V, Wagner V, Wagnerova M, . 1988. Immunobiochemical profiles of workers differing in the degree of occupational exposure to vinyl chloride. J Hyg Epidemiol Microbiol Immunol 32(4):375–384.
Benfenati E, Natangelo M, Davoli E, . 1991. Migration of vinyl chloride into PVC-bottled drinking-water assessed by gas chromatography-mass spectrometry. Food Chem Toxicol 29(2):131–134. 10.1016/0278-6915(91)90168-7.2010143
Berk PD, Martin JF, Waggoner JG. 1975. Persistence of vinyl chloride-induced liver injury after cessation of exposure. Ann N Y Acad Sci 246:70–77. 10.1111/j.1749-6632.1975.tb51081.x.1054971
Bexfield LM, Belitz K, Fram MS, . 2022. Volatile organic compounds in groundwater used for public supply across the United States: Occurrence, explanatory factors, and human-health context. Sci Total Environ 827:154313. 10.1016/j.scitotenv.2022.154313.35257755
Bi WF, Wang YS, Huang MY, . 1985. Effect of vinyl chloride on testis in rats. Ecotoxicol Environ Saf 10(3):281–289. 10.1016/0147-6513(85)90074-0.4092642
Black CM, Welsh KI, Walker AE, . 1983. Genetic susceptibility to scleroderma-like syndrome induced by vinyl chloride. Lancet 1(8314–5):53–55. 10.1016/s0140-6736(83)91578-7.6129382
Black C, Pereira S, McWhirter A, . 1986. Genetic susceptibility to scleroderma-like syndrome in symptomatic and asymptomatic workers exposed to vinyl chloride. J Rheumatol 13(6):1059–1062.3494121
Bloomdahl R, Abualfaraj N, Olson M, . 2014. Assessing worker exposure to inhaled volatile organic compounds from Marcellus Shale flowback pits. J Nat Gas Sci Eng 21:348–356. 10.1016/j.jngse.2014.08.018.
Boffetta P, Matisane L, Mundt KA, . 2003. Meta-analysis of studies of occupational exposure to vinyl chloride in relation to cancer mortality. Scand J Work Environ Health 29(3):220–229. 10.5271/sjweh.725.12828392
Bogdanikowa B, Zawilska J. 1984. Immune complexes in the serum of patients occupationally exposed to vinyl chloride. Przegl Lek 41:253–257.6739844
Boivin S, Pedron S, Bertrand S, . 1997. Myofibroblast-like cells exhibiting a mutated p53 gene isolated from a liver human tumor of a worker exposed to vinyl chloride. In: Wisse E, Knook DL, Balabaud C, eds. Cells of the hepatic sinusoid. Vol. 6. The Netherlands: Kupffer Cell Foundation, 449–451.
Boivin-Angele S, Lefrancois L, Froment O, . 2000. Ras gene mutations in vinyl chloride-induced liver tumours are carcinogen-specific but vary with cell type and species. Int J Cancer 85(2):223–227. 10.1002/(sici)1097-0215(20000115)85:2<223::aid-ijc12>3.0.co;2-h.10629081
Bolt HM. 1986. Metabolic activation of vinyl chloride, formation of nucleic acid adducts and relevance to carcinogenesis. IARC Sci Publ 70(70):261–268.
Bolt HM, Kappus H, Buchter A, . 1976a. Disposition of (1,2-14C) vinyl chloride in the rat. Arch Toxicol 35(3):153–162. 10.1007/BF00293562.989287
Bolt HM, Kappus H, Kaufmann R, . 1976b. Metabolism of 14C-vinyl chloride in vitro and in vivo. IARC Sci Publ 13:151–163.
Bolt HM, Laib RJ, Kappus H, . 1977. Pharmacokinetics of vinyl chloride in the rat. Toxicology 7(2):179–188. 10.1016/0300-483x(77)90063-4.857343
Bolt HM, Filser JG, Laib RJ, . 1980. Binding kinetics of vinyl chloride and vinyl bromide at very low doses. Arch Toxicol Suppl 3:129–142. 10.1007/978-3-642-67389-4_10.6930940
Bolt HM, Laib RJ, Peter H, . 1986. DNA adducts of halogenated hydrocarbons. J Cancer Res Clin Oncol 112(2):92–96. 10.1007/BF00404388.3771627
Borrelli FE, de la Cruz PL, Paradis RA. 2005. Residual vinyl chloride levels in U.S. PVC resins and products: Historical perspective and update. J Vinyl Addit Technol 11(2):65–69. 10.1002/vnl.20040.
Bosetti C, La Vecchia C, Lipworth L, . 2003. Occupational exposure to vinyl chloride and cancer risk: a review of the epidemiologic literature. Eur J Cancer Prev 12(5):427–430. 10.1097/00008469-200310000-00012.14512808
Bove FJ, Ruckart PZ, Maslia M, . 2014. Evaluation of mortality among marines and navy personnel exposed to contaminated drinking water at USMC base Camp Lejeune: a retrospective cohort study. Environ Health 13(1):10. 10.1186/1476-069x-13-10.24552493
Boyle EB, Viet SM, Wright DJ, . 2016. Assessment of exposure to VOCs among pregnant women in the National Children’s Study. Int J Environ Res Publ Health 13(4):376. 10.3390/ijerph13040376.
Bradley PM, Chapelle FH. 1996. Anaerobic mineralization of vinyl chloride in Fe(III)-reducing aquifer sediments. Environ Sci Technol 30:2084–2086. 10.1021/es950926k.
Bradley PM, Chapelle FH. 1997. Kinetics of DCE and VC mineralization under methanogenic and Fe(III)-reducing conditions. Environ Sci Technol 31(9):2692–2696. 10.1021/es970110e.
Brandt-Rauf PW, Marion MJ, DeVito I. 1995. Mutant p21 protein as a biomarker of chemical carcinogenesis in humans. In: Mendelsohn ML, Peeters JP, Normandy MJ, eds. Biomarkers and occupational health. Progress and perspectives. Washington, DC: Joseph Henry Press, 163–173.
Brandt-Rauf PW, Luo JC, Cheng TJ, . 2000a. Mutant oncoprotein biomarkers of vinyl chloride exposure: Applications to risk assessment. NATO ASI Ser A Life Sci 313:233–248.
Brandt-Rauf PW, Do TN, Weinberg MD, . 2000b. Growth signal transduction proteins as biomarkers of occupational exposures. NATO ASI Ser A Life Sci 313:208–212.
Brinker K, Lumia M, Markiewicz KV, . 2015. Assessment of emergency responders after a vinyl chloride release from a train derailment - New Jersey, 2012. MMWR Morb Mortal Wkly Rep 63(53):1233–1237.25577988
Brock WJ, Rusch GM, Trochimowicz HJ. 2003. Cardiac sensitization: methodology and interpretation in risk assessment. Regul Toxicol Pharmacol 38(1):78–90. 10.1016/s0273-2300(03)00072-2.12878057
Buchter A, Bolt HM, Kappus H, . 1977. [Tissue distribution of 1,2-^14^C–vinyl chloride in the rat]. Int Arch Occup Environ Health 39:27–32. (German)852895
Buchter A, Filser JG, Peter H, . 1980. Pharmacokinetics of vinyl chloride in the Rhesus monkey. Toxicol Lett 6(1):33–36. 10.1016/0378-4274(80)90099-5.7423542
Budavari S. 1989. An encyclopedia of chemicals, drugs, and biologicals. In: The Merck index. 11^th^ ed. Rahway, NJ: Merck & Co., Inc., 1572.
Buffler PA, Wood S, Eifler C, . 1979. Mortality experience of workers in a vinyl chloride monomer production plant. J Occup Med 21(3):195–203.438910
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: A review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Byren D, Engholm G, Englund A, . 1976. Mortality and cancer morbidity in a group of Swedish VCM and PCV production workers. Environ Health Perspect 17:167–170. 10.1289/ehp.17-1475258.1026402
Carassiti V, Chiorboli C, Bignozzi CA, . 1977. Atmospheric photo-oxidation of vinyl chloride: A generalized treatment of the relative rates of product formation. Ann Chim 67:499–512.
Carr CJ, Burgison RM, Vitcha JF, . 1949. Anesthesia; chemical constitution of hydrocarbons and cardiac automaticity. J Pharmacol Exp Ther 97(1):1–3.18140112
Carreón T, Hein MJ, Hanley KW, . 2014. Coronary artery disease and cancer mortality in a cohort of workers exposed to vinyl chloride, carbon disulfide, rotating shift work, and o-toluidine at a chemical manufacturing plant. Am J Ind Med 57(4):398–411. 10.1002/ajim.22299.24464642
Castro CE, Riebeth DM, Belser NO. 1992a. Biodehalogenation: The metabolism of vinyl chloride by Methylosinus trichosporium OB-3b. A sequential oxidative and reductive pathway through chloroethylene oxide. Environ Toxicol Chem 11(6):749–755. 10.1002/etc.5620110604.
Castro CE, Wade RS, Riebeth DM, . 1992b. Biodehalogenation: Rapid metabolism of vinyl chloride by a soil Pseudomonas sp. direct hydrolysis of a vinyl C-Cl bond. Environ Toxicol Chem 11(6):757–764. 10.1002/etc.5620110605.
Cave M, Falkner KC, Ray M, . 2010. Toxicant-associated steatohepatitis in vinyl chloride workers. Hepatology 51(2):474–481. 10.1002/hep.23321.19902480
Chappell G, Pogribny IP, Guyton KZ, . 2016. Epigenetic alterations induced by genotoxic occupational and environmental human chemical carcinogens: A systematic literature review. Mutat Res 768:27–45. 10.1016/j.mrrev.2016.03.004.
ChemView. 2023. Vinyl chloride. Chemical data reporting details. U.S. Environmental Protection Agency. https://chemview.epa.gov/chemview/. July 13, 2023.
Chen HM, Wu MT. 2017. Residential exposure to chlorinated hydrocarbons from groundwater contamination and the impairment of renal function-An ecological study. Sci Rep 7:40283. 10.1038/srep40283.28067285
Chen CW, Hsieh D, Sung FC, . 2018. Feasibility of using urinary TDGA as a biomarker for VCM exposures. Regul Toxicol Pharmacol 97:82–87. 10.1016/j.yrtph.2018.06.008.29909270
Chen L, Lang AL, Poff GD, . 2019. Vinyl chloride-induced interaction of nonalcoholic and toxicant-associated steatohepatitis: Protection by the ALDH2 activator Alda-1. Redox Biol 24:101205. 10.1016/j.redox.2019.101205.31026768
Cheng TJ, Wong RH, Du CL, . 1999a. A mortality study of vinyl chloride workers in Taiwan. Proc Am Assoc Cancer Res 40:41.
Cheng TJ, Huang ML, You NC, . 1999b. Abnormal liver function in workers exposed to low levels of ethylene dichloride and vinyl chloride monomer. J Occup Environ Med 41(12):1128–1133. 10.1097/00043764-199912000-00018.10609234
Cheng TJ, Huang YF, Ma YC. 2001. Urinary thiodiglycolic acid levels for vinyl chloride monomer-exposed polyvinyl chloride workers. J Occup Environ Med 43(11):934–938. 10.1097/00043764-200111000-00002.11725332
Cheng MH, Chiu CH, Chen CT, . 2021. Sources and components of volatile organic compounds in breast surgery operating rooms. Ecotoxicol Environ Saf 209:111855. 10.1016/j.ecoenv.2020.111855.33385676
Chiang SY, Swenberg JA, Weisman WH, . 1997. Mutagenicity of vinyl chloride and its reactive metabolites, chloroethylene oxide and chloroacetaldehyde in a metabolically competent human B-lymphoblastoid line. Carcinogenesis 18(1):31–36. 10.1093/carcin/18.1.31.9054586
Chiu WA, White P. 2006. Steady-state solutions to PBPK models and their applications to risk assessment I: Route-to-route extrapolation of volatile chemicals. Risk Anal 26(3):769–780. 10.1111/j.1539-6924.2006.00762.x.16834633
Christner PJ, Artlett CM, Conway RF, . 2000. Increased numbers of microchimeric cells of fetal origin are associated with dermal fibrosis in mice following injection of vinyl chloride. Arthritis Rheum 43(11):2598–2605. 10.1002/1529-0131(200011)43:11<2598::AID-ANR30>3.0.CO;2-8.11083286
Cicalese L, Raun L, Shirafkan A, . 2017. An ecological study of the association between air pollution and hepatocellular carcinoma incidence in Texas. Liver cancer 6(4):287–296. 10.1159/000475776.29234632
Ciroussel F, Barbin A, Eberle G, . 1990. Investigations on the relationship between DNA ethenobase adduct levels in several organs of vinyl chloride-exposed rats and cancer susceptibility. Biochem Pharmacol 39:1109–1113. 10.1016/0006-2952(90)90291-R.2322297
Clark DG, Tinston DJ. 1973. Correlation of the cardiac sensitizing potential of halogenated hydrocarbons with their physicochemical properties. Br J Pharmacol 49:355–357. 10.1111/j.1476-5381.1973.tb08382.x.4793336
Clark CJ, Xiong B, Soriano MA, . 2022. Assessing unconventional oil and gas exposure in Appalachian basin: Comparison of exposure surrogates and residential drinking water measurements. Environ Sci Technol 56(2):1091–1103. 10.1021/acs.est.1c05081.34982938
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Clewell HJ, Gentry PR, Gearhart JM, . 1995. Considering pharmacokinetic and mechanistic information in cancer risk assessments for environmental contaminants: examples with vinyl chloride and trichloroethylene. Chemosphere 31(1):2561–2578. 10.1016/0045-6535(95)00124-q.7670867
Clewell HJ, Gentry PR, Gearhart JM, . 2001. Comparison of cancer risk estimates for vinyl chloride using animal and human data with a PBPK model. Sci Total Environ 274:37–66. 10.1016/S0048-9697(01)00730-6.11453305
Clewell HJ, Gentry PR, Covington TR, . 2004. Evaluation of the potential impact of age- and gender-specific pharmacokinetic differences on tissue dosimetry. Toxicol Sci 79(2):381–393. 10.1093/toxsci/kfh109.15056818
Cogliano VJ, Parker JC. 1992. Some implications of toxicology and pharmacokinetics for exposure assessment. J Expo Anal Environ Epidemiol 2(Supp 1):189–207.
Cogliano VJ, Hiatt GF, Den A. 1996. Quantitative cancer assessment for vinyl chloride: indications of early-life sensitivity. Toxicology 111(1–3):21–28. 10.1016/0300-483x(96)03390-2.8711737
Coleman NV, Spain JC. 2003. Epoxyalkane: coenzyme M transferase in the ethene and vinyl chloride biodegradation pathways of mycobacterium strain JS60. J Bacteriol 185(18):5536–5545. 10.1128/JB.185.18.5536-5545.2003.12949106
Coleman NV, Mattes TE, Gossett JM, . 2002. Phylogenetic and kinetic diversity of aerobic vinyl chloride-assimilating bacteria from contaminated sites. Appl Environ Microbiol 68(12):6162–6171. 10.1128/AEM.68.12.6162-6171.2002.12450841
Collins JJ, Jammer B, Sladeczek FM, . 2014. Surveillance for angiosarcoma of the liver among vinyl chloride workers. J Occup Environ Med 56(11):1207–1209. 10.1097/jom.0000000000000247.25376416
Conkle JP, Camp BJ, Welch BE. 1975. Trace composition of human respiratory gas. Arch Environ Health 30(6):290–295. 10.1080/00039896.1975.10666702.1137435
Conolly RB, Jaeger RJ. 1979. Acute hepatotoxicity of vinyl chloride and ethylene: Modification by trichloropropane oxide, diethylmaleate, and cysteine. Toxicol Appl Pharmacol 50:523–531. 10.1016/0041-008X(79)90407-1.117568
Conolly RB, Jaeger RJ, Szabo S. 1978. Acute hepatotoxicity of ethylene, vinyl fluoride, vinyl chloride, and vinyl bromide after Aroclor 1254 pretreatment. Exp Mol Pathol 28(1):25–33. 10.1016/0014-4800(78)90060-6.413739
Cooper WC. 1981. Epidemiologic study of vinyl chloride workers: Mortality through December 31, 1972. Environ Health Perspect 41:101–106. 10.1289/ehp.8141101.7199425
Cowfer JA, Magistro AJ. 1985. Vinyl polymers: Vinyl chloride. In: Kirk-Othmer’s concise encyclopedia of chemical technology. New York, NY: John Wiley and Sons, Inc, 1229–1233.
Cowfer JA, Gorensek MB. 2006. Vinyl chloride. In: Kirk-Othmer’s encyclopedia of chemical technology. New York, NY: John Wiley & Sons, online. 10.1002/0471238961.2209142503152306.a01.pub2.
Cox RA, Enggleton AEJ, Sandalls FJ. 1974. Photochemical reactivity of vinyl chloride. Oxfordshire, England: AERE Harwell. AERE-R-7820.
Criscuolo M, Valerio J, Gianicolo ME, . 2014. A vinyl chloride-exposed worker with an adrenal gland angiosarcoma: a case report. Ind Health 52(1):66–70. 10.2486/indhealth.2013-0044.24292955
Cullinan D, Johnson F, Grollman AP, . 1997. Solution structure of a DNA duplex containing the exocyclic lesion 3,N4-etheno-2’-deoxycytidine opposite 2’-deoxyguanosine. Biochemistry 36(39):11933 11943. 10.1021/bi9705725.9305987
Danko AS, Saski CA, Tomkins JP, . 2006. Involvement of coenzyme M during aerobic biodegradation of vinyl chloride and ethene by Pseudomonas putida strain AJ and Ochrobactrum sp. strain TD. Appl Environ Microbiol 72(5):3756–3758. 10.1128/AEM.72.5.3756-3758.2006.16672529
Danziger H. 1960. Accidental poisoning by vinyl chloride: report of two cases. Can Med Assoc J 82:828–830.13814054
Davis JW, Carpenter CL. 1990. Aerobic biodegradation of vinyl chloride in groundwater samples. Appl Environ Microbiol 56(12):3878–3880. 10.1128/AEM.56.12.3878-3880.1990.2128014
de Jong G, van Sittert NJ, Natarajan AT. 1988. Cytogenetic monitoring of industrial populations potentially exposed to genotoxic chemicals and of control populations. Mutat Res 204(3):451–464. 10.1016/0165-1218(88)90041-9.3347216
de Meester C, Duverger-van Bogaert M, Lambotte-Vandepaer M, . 1980. Mutagenicity of vinyl chloride in the Ames test: possible artifacts related to experimental conditions. Mutat Res 77(2):175–179. 10.1016/0165-1218(80)90135-4.6990242
DeLassus PT, Schmidt DD. 1981. Solubilities of vinyl chloride and vinylidene chloride in water. J Chem Eng Data 26(3):274–276. 10.1021/je00025a015.
DeVivo I, Marion MJ, Smith SJ, . 1994. Mutant c-Ki-ras p21 protein in chemical carcinogenesis in humans exposed to vinyl chloride. Cancer Causes Control 5:273–278. 10.1007/BF01830248.8061177
Dinman BD, Cook WA, Whitehouse WM, . 1971. Occupational acroosteolysis. I. An epidemiological study. Arch Environ Health 22(1):61–73. 10.1080/00039896.1971.10665816.5539983
DOE. 2015. Vinyl chloride. PAC Database. U.S. Department of Energy. https://pacteels.pnnl.gov/. July 20, 2023.
DOE. 2023. Definition of PACs. U.S. Department of Energy. https://pacteels.pnnl.gov/#/definitions. July 20, 2023.
Dogliotti E. 2006. Molecular mechanisms of carcinogenesis by vinyl chloride. Ann Ist Super Sanita 42(2):163–169.17033136
Dosanjh MK, Chenna A, Kim E, . 1994. All four known cyclic adducts formed in DNA by the vinyl chloride metabolite chloroacetaldehyde are released by a human DNA glycosylase. Proc Natl Acad Sci U S A 91:1024–1028. 10.1073/pnas.91.3.1024.8302827
DOT. 1993. Hazardous materials regulations. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 171.2. https://www.ecfr.gov/current/title-49/subtitle-B/chapter-I/subchapter-C/part-171/subpart-A/section-171.2. August 26, 2022.
Dreher E, Beutel KK, Myers JD, . 2014. Chloroethanes and chloroethylenes. In: Ullmann’s encyclopedia of industrial chemistry. New York, NY: John Wiley & Sons, online. 10.1002/14356007.o06_o01.pub2.
Drevon C, Kuroki T, Montesano R. 1978. Microsome-mediated mutagenesis of a Chinese hamster cell line by various chemicals. Mutat Res Lett 53:181–182.
Drew RT, Boorman GA, Haseman JK, . 1983. The effect of age and exposure duration on cancer induction by a known carcinogen in rats, mice, and hamsters. Toxicol Appl Pharmacol 68(1):120–130. 10.1016/0041-008x(83)90361-7.6682580
D’Souza RW, Andersen ME. 1988. Physiologically based pharmacokinetic model for vinylidene chloride. Toxicol Appl Pharmacol 95(2):230–240. 10.1016/0041-008x(88)90159-7.3420614
Du CL, Wang JD. 1998. Increased morbidity odds ratio of primary liver cancer and cirrhosis of the liver among vinyl chloride monomer workers. Occup Environ Med 55:528–532. 10.1136/oem.55.8.528.9849539
Du JT, Sandoz JP, Tseng MT, . 1979. Biochemical alterations in livers of rats exposed to vinyl chloride. J Toxicol Environ Health 5(6):1119–1132. 10.1080/15287397909529818.231116
Du CL, Kuo ML, Chang HL, . 1995. Changes in lymphocyte single strand breakage and liver function of workers exposed to vinyl chloride monomer. Toxicol Lett 77(1–3):379–385. 10.1016/0378-4274(95)03321-1.7618165
du Pont. 1992a. Initial submission: In vitro microbial mutagenicity studies of chloroethylene with cover letter dated 050892 and attachments. E.I. du Pont de Nemours & Company. Submitted to the U.S. Environmental Protection Agency under Section 8E. OTS0539817. 88920002857. 8EHQ05924215. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0539817.xhtml. October 5, 2021.
du Pont. 1992b. Initial submission: Mutagenicity activity of ethylene, chloro- in the Salmonella/microsome assay with cover letter dated 050892 & attachments. E.I. du Pont de Nemours & Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0539547. 88920002788. 8EHQ05924146. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0539547.xhtml. October 5, 2021.
du Pont. 1992c. Initial submission: Ethylene, chloro-: Chinese hamster ovary cell assay for mutagenicity with cover letter dated 050892 and attachments. E.I. du Pont de Nemours & Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0539535. 88920002776. 8EHQ05924134 https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0539535.xhtml. October 5, 2021.
Ducatman A, Hirschhorn K, Selikoff IJ. 1975. Vinyl chloride exposure and human chromosome aberrations. Mutat Res 31(3):163–168. 10.1016/0165-1161(75)90085-0.1128548
Eberle G, Barbin A, Laib RJ, . 1989. 1,N^6^-etheno-2’-deoxyadenosine and 3,N^4^-etheno-2’-deoxycytidine detected by monoclonal antibodies in lung and liver DNA of rats exposed to vinyl chloride. Carcinogenesis 10:209–212. 10.1093/carcin/10.1.209.2783395
Eckardt F, Muliawan H, de Ruiter N, . 1981. Rat hepatic vinyl chloride metabolites induce gene conversion in the yeast strain D7RAD in vitro and in vivo. Mutat Res Lett 91(4–5):381–390. 10.1016/0165-7992(81)90019-1.
Edmonds LD, Falk H, Nissim JE. 1975. Letter: Congenital malformations and vinyl chloride. Lancet 2(7944):1098. 10.1016/s0140-6736(75)90479-1.53589
Edmonds LD, Anderson CE, Flynt JW, . 1978. Congenital central nervous system malformations and vinyl chloride monomer exposure: a community study. Teratology 17(2):137–142. 10.1002/tera.1420170205.644500
Edwards D, Voronina A, Attwood K, . 2021. Association between occupational exposures and sarcoma incidence and mortality: systematic review and meta-analysis. Syst Rev 10(1):231. 10.1186/s13643-021-01769-4.34389054
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38. 10.1021/es00083a002.
el Ghissassi F, Barbin A, Bartsch H. 1998. Metabolic activation of vinyl chloride by rat liver microsomes: low-dose kinetics and involvement of cytochrome P450 2E1. Biochem Pharmacol 55(9):1445–1452. 10.1016/s0006-2952(97)00645-x.10076537
Elliott P, Kleinschmidt I. 1997. Angiosarcoma of the liver in Great Britain in proximity to vinyl chloride sites. Occup Environ Med 54(1):14–18. 10.1136/oem.54.1.14.9072028
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
El-Metwally D, Chain K, Stefanak MP, . 2018. Urinary metabolites of volatile organic compounds of infants in the neonatal intensive care unit. Pediatr Res 83(6):1158–1164. 10.1038/pr.2018.52.29768398
Elmore JD, Wong JL, Laumbach AD, . 1976. Vinyl chloride mutagenicity via the metabolites chlorooxirane and chloroacetaldehyde monomer hydrate. Biochim Biophys Acta 442(3):405–419. 10.1016/0005-2787(76)90314-2.822875
EPA. 1975. Scientific and technical assessment report on vinyl chloride and polylinyl chloride. Washington, DC: U.S. Environmental Protection Agency. EPA600675004. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20013GER.txt. August 25, 2021.
EPA. 1976. Dynamic behavior of vinyl chloride in aquatic ecosystems. Atlanta, GA: U.S. Environmental Protection Agency. PB249302. EPA600376001. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB249302.xhtml. August 26, 2021.
EPA. 1979. Water-related environmental fate of 129 priority pollutants. Volume II. Washington, DC: U.S. Environmental Protection Agency. PB80204381. EPA4404790298. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80204381.xhtml. August 27, 2021.
EPA. 1982a. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. PB87169090. EPA440481014. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87169090.xhtml. July 10, 2021.
EPA. 1982b. Vinyl chloride occurrence in drinking water, food, and air. Washington, DC: U.S. Environmental Protection Agency. PB95183158. EPA68016388. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB95183158.xhtml. April 7, 2021.
EPA. 1985a. Drinking water criteria document for vinyl chloride. Washington, DC: U.S. Environmental Protection Agency. PB86118320. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB86118320.xhtml. August 13, 2021.
EPA. 1985b. Health and environmental effects profile for chloroethene. Cincinnati, OH: U.S. Environmental Protection Agency. PB88174529. ECAOCINP155. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88174529.xhtml. August 20, 2021.
EPA. 1987. Incorporation of biological information in cancer risk assessment: Example - vinyl chloride. Washington, DC: U.S. Environmental Protection Agency. PB87198982. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87198982.xhtml. August 13, 2021.
EPA. 1993. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 Appendix VIII. https://www.ecfr.gov/current/title-40/chapter-I/subchapter-I/part-261/appendix-Appendix%20VIII%20to%20Part%20261. October 5, 2022.
EPA. 1994. Methods of derivation of inhalation reference concentrations and application of inhalation dosimetry. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600890066F. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993. October 25, 2021.
EPA. 1999. Compendium method TO-15: Determination of volatile organic compounds (VOCs) in air collected in specially-prepared canisters and analyzed by gas chromatography/ mass spectrometry (GC/MS). Compendium of methods for the determination of toxic organic compounds in ambient air: Second edition. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010b. https://www3.epa.gov/ttnamti1/files/ambient/airtox/to-15r.pdf. August 1, 2023.
EPA. 2000. Toxicological review of vinyl chloride. Washington, DC: U.S. Environmental Protection Agency. PB2001108765. EPA635R00004. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2001108765.xhtml. August 1, 2021.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. March 25, 2021.
EPA. 2012. Benchmark dose technical guidance. Washington, DC: U.S. Environmental Protection Agency. EPA100R12001. https://www.epa.gov/sites/default/files/2015-01/documents/benchmark_dose_guidance.pdf. October 3, 2023.
EPA. 2014. 2011 National Emissions Inventory (NEI) from the Technology Transfer Network Clearinghouse for inventories and emissions factors. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2011-national-emissions-inventory-nei-data#dataq. March 24, 2021.
EPA. 2016. Six-year review 3 compliance monitoring data (2006-2011). U.S. Environmental Protection Agency. https://www.epa.gov/dwsixyearreview/six-year-review-3-compliance-monitoring-data-2006-2011. October 4, 2023.
EPA. 2018a. Method 8260D: Volatile organic compounds by gas chromatography/mass spectrometry. U.S. Environmental Protection Agency. SW-846 Update VI. https://www.epa.gov/sites/default/files/2018-06/documents/method_8260d_update_vi_final_06-11-2018.pdf. July 31, 2023.
EPA. 2018b. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. July 16, 2023.
EPA. 2018c. Acute exposure guideline levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018d. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2021. Chemical data reporting (CDR). Non-confidential 2016 chemical data reporting information on chemical production and use in the United States. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. August 26, 2021.
EPA. 2022. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023a. Updates from the East Palestine train derailment emergency response. U.S. Environmental Protection Agency. https://www.epa.gov/east-palestine-oh-train-derailment/daily-updates#feb423. July 7, 2023.
EPA. 2023b. Air sampling data: East Palestine, Ohio Train Derailment. U.S. Environmental Protection Agency. https://www.epa.gov/east-palestine-oh-train-derailment/air-sampling-data. June 12, 2023.
EPA. 2023c. Annual summary data: Vinyl chloride. Air quality system: Concentration by monitor. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. July 11, 2023.
EPA. 2023d. EPA Lab Results: through 09/27/23 - East Palestine, OH Response U.S. Environmental Protection Agency. https://www.epa.gov/system/files/other-files/2023-02/Lab_Results_Air.csv. September 28, 2023.
EPA. 2023e. East Palestine, Ohio train derailment. U.S. Environmental Protection Agency. https://www.epa.gov/east-palestine-oh-train-derailment. October 4, 2023.
EPA. 2023f. East Palestine, Ohio train derailment: Water sampling data. U.S. Environmental Protection Agency. https://www.epa.gov/east-palestine-oh-train-derailment/water-sampling-data. October 4, 2023.
EPA. 2023g. East Palestine, Ohio train derailment: Soil and sediment sampling data. U.S. Environmental Protection Agency. https://www.epa.gov/east-palestine-oh-train-derailment/soil-and-sediment-sampling-data. October 4, 2023.
Ernes DA, Griffin JP. 1996. Process emissions for vinyl pipe industry. J Vinyl Addit Technol 2(3):180–183. 10.1002/vnl.10119.
Fakkaew K, Kongkratoke S, Tantrakarnapa K, . 2022. Characteristics of gases emitted from chicken manure wastewater and potential effects on human health. Environ Sci Pollut Res Int 29(42):63227–63232. 10.1007/s11356-022-20357-0.35459987
Falk H, Creech JL, Heath CW, . 1974. Hepatic disease among workers at a vinyl chloride polymerization plant. JAMA 230:59–63. 10.1001/jama.1974.03240010027023.4547220
FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Fedeli U, Girardi P, Mastrangelo G. 2019b. Occupational exposure to vinyl chloride and liver diseases. World J Gastroenterol 25(33):4885–4891. 10.3748/wjg.v25.i33.4885.31543680
Fedeli U, Girardi P, Gardiman G, . 2019a. Mortality from liver angiosarcoma, hepatocellular carcinoma, and cirrhosis among vinyl chloride workers. Am J Ind Med 62(1):14–20. 10.1002/ajim.22922.30474170
Fedtke N, Boucheron JA, Walker VE, . 1990. Vinyl chloride-induced DNA adducts. II: Formation and persistence of 7-(2-oxoethyl)guanine and N2,3-ethenoguanine in rat tissue DNA. Carcinogenesis 11(8):1287–1292. 10.1093/carcin/11.8.1287.2387014
Feng N, Li Y, Long C, . 2014. Effects of DNA repair gene polymorphisms on DNA damage in human lymphocytes induced by a vinyl chloride metabolite in vitro. Biomarkers 19(4):281–286. 10.3109/1354750x.2014.907345.24731051
Feng N, Zheng G, Hao Y, . 2017. Mutations in apoptotic genes and micronucleus occurrence in vinyl chloride-exposed workers in China. Environ Mol Mutagen 58(1):39–45. 10.1002/em.22046.27801956
Fernandes PH, Kanuri M, Nechev LV, . 2005. Mammalian cell mutagenesis of the DNA adducts of vinyl chloride and crotonaldehyde. Environ Mol Mutagen 45(5):455–459. 10.1002/em.20117.15690339
Feron VJ, Kroes R. 1979. One-year time-sequence inhalation toxicity study of vinyl chloride in rats. II. Morphological changes in the respiratory tract, ceruminous glands, brain, kidneys, heart and spleen. Toxicology 13(2):131–141. 10.1016/S0300-483X(79)80017-7.516073
Feron VJ, Kruysse A, Til HP. 1979a. One-year time sequence inhalation toxicity study of vinyl chloride in rats. I. Growth, mortality, haematology, clinical chemistry and organ weights. Toxicology 13:25–28. 10.1016/S0300-483X(79)80006-2.516069
Feron VJ, Speek AJ, Willems MI, . 1975. Observations on the oral administration and toxicity of vinyl chloride in rats. Food Cosmet Toxicol 13(6):633–638. 10.1016/0015-6264(75)90153-4.1239404
Feron VJ, Hendriksen CF, Speek AJ, . 1981. Lifespan oral toxicity study of vinyl chloride in rats. Food Cosmet Toxicol 19(3):317–333. 10.1016/0015-6264(81)90391-6.7196371
Filippini M, Leoncini C, Luchetti L, . 2022. Detecting vinyl chloride by phytoscreening in the shallow critical zone at sites with potential human exposure. J Environ Manage 319:115776. 10.1016/j.jenvman.2022.115776.35982574
Filser JG, Bolt HM. 1979. Pharmacokinetics of halogenated ethylenes in rats. Arch Toxicol 42(2):123–136. 10.1007/BF00316492.485853
Fire FL. 1986. Vinyl chloride. Fire Eng 139:39–43.
Fleig I, Thiess AM. 1978. Mutagenicity study of workers employed in the styrene and polystyrene processing and manufacturing industry. Scand J Work Environ Health 4(2):254–258. 10.5271/sjweh.2740.734412
Fontana L, Marion MJ, Ughetto S, . 2006. Glutathione S-transferase M1 and GST T1 genetic polymorphisms and Raynaud’s phenomenon in French vinyl chloride monomer-exposed workers. J Hum Genet 51(10):879–886. 10.1007/s10038-006-0038-9.16977343
Forman D, Bennett B, Stafford J, . 1985. Exposure to vinyl chloride and angiosarcoma of the liver: a report of the register of cases. Br J Ind Med 42(11):750–753. 10.1136/oem.42.11.750.4063218
Fortwengler P, Lewis RD, Reynolds L, . 1999. Empirical evidence that angiosarcoma of the liver caused by vinyl chloride exposure has a relatively high threshold dose in humans. Hepatology 30(4 Pt 2):504A.
Fox AJ, Collier PF. 1977. Mortality experience of workers exposed to vinyl chloride monomer in the manufacture of polyvinyl chloride in Great Britain. Br J Ind Med 34(1):1–10. 10.1136/oem.34.1.1.557328
Freitag D, Ballhorn L, Geyer H, . 1985. Environmental hazard profile of organic chemicals: An experimental method for the assessment of the behavior of organic chemicals in the ecosphere by means of simple laboratory tests with 14C labelled chemicals. Chemosphere 14:1589–1616. 10.1016/0045-6535(85)90014-1.
Freudiger H, Bounameaux H, Garcia J. 1988. Acroosteolysis and Raynaud’s phenomenon after vinyl chloride exposure. Vasa 17(3):216–218.3176646
Froment O, Boivin S, Barbin A, . 1994. Mutagenesis of ras proto-oncogenes in rat liver tumors induced by vinyl chloride. Cancer Res 54(20):5340–5345.7923162
Frullanti E, La Vecchia C, Boffetta P, . 2012. Vinyl chloride exposure and cirrhosis: a systematic review and meta-analysis. Dig Liver Dis 44(9):775–779. 10.1016/j.dld.2012.02.007.22440240
Fucic A, Horvat D, Dimitrović B. 1990a. Mutagenicity of vinyl chloride in man: comparison of chromosome aberrations with micronucleus and sister-chromatid exchange frequencies. Mutat Res 242(4):265–270. 10.1016/0165-1218(90)90044-3.
Fucic A, Horvat D, Dimitrovic B. 1990b. Localization of breaks induced by vinyl chloride in the human chromosomes of lymphocytes. Mutat Res 243(2):95–99. 10.1016/0165-7992(90)90029-j.2304486
Fucic A, Garaj-Vrhovac V, Dimitrovic B, . 1992. The persistence of sister-chromatid exchange frequencies in men occupationally exposed to vinyl chloride monomer. Mutat Res 281(2):129–132. 10.1016/0165-7992(92)90047-l.1370980
Fucic A, Garaj-Vrhovac V, Barkovic D, . 1994. The sensitivity of the micronucleus assay for the detection of occupational exposure to vinyl chloride monomer. Mutat Res 325(2–3):53–56. 10.1016/0165-7992(94)90001-9.7523931
Fucic A, Hitrec V, Garaj-Vrhovac V, . 1995. Relationship between locations of chromosome breaks induced by vinyl chloride monomer and lymphocytosis. Am J Ind Med 27(4):565–571. 10.1002/ajim.4700270409.7793426
Fucic A, Barkovic D, Garaj-Vrhovac V, . 1996a. An eight-year follow-up study of a population occupationally exposed to vinyl chloride monomer. Mutat Res 360:237–238.
Fucic A, Barkovic D, Garaj-Vrhovac V, . 1996b. A nine-year follow up study of a population occupationally exposed to vinyl chloride monomer. Mutat Res 361(1):49–53. 10.1016/s0165-1161(96)90229-0.8816943
Fucic A, Hitrec V, Garaj-Vrhovac V, . 1997. Clinical cytogenetics and toxogenetics with the common aim-risk assessment of chemical mutagens. Cytogenet Cell Genet 77(1–2):69. 10.1159/000317460.
Fucic A, Spacir Z, Barkovic D, . 1998. Relative lymphocytosis-disorder caused by occupational exposure to vinyl chloride monomer. Bull Environ Contam Toxicol 61(5):583–590. 10.1007/s001289900801.9841717
Fučić A, Lasan R, Mijić A, . 2004. The frequency of micronuclei in mononucleated and binucleated lymphocytes as an indicator of acute or chronic occupational exposure. Period Biol 106(3):279–282.
Fujiwara R. 2018. Exposure to sub-parts per million levels of vinyl chloride can increase the risk of developing liver injury. Hepatol Commun 2(3):227–229. 10.1002/hep4.1169.29507897
Funes-Cravioto F, Lambert B, Lindsten J, . 1975. Letter: chromosome aberrations in workers exposed to vinyl chloride. Lancet 1(7904):459. 10.1016/s0140-6736(75)91534-2.48652
Gamble J, Liu S, McMichael AJ, . 1976. Effect of occupational and nonoccupational factors on the respiratory system of vinyl chloride and other workers. J Occup Med 18(10):659–670. 10.1097/00043764-197610000-00006.966081
Garaj-Vrhovac V, Fuãciäc A, Horvat D. 1990. Comparison of chromosome aberration and micronucleus induction in human lymphocytes after occupational exposure to vinyl chloride monomer and microwave radiation. Period Biol 92(4):411–416.30260349
Garcia E, Hurley S, Nelson DO, . 2015. Hazardous air pollutants and breast cancer risk in California teachers: a cohort study. Environ Health 14:14. 10.1186/1476-069x-14-14.25636809
Gedigke P, Muller R, Bechtelsheimer H. 1975. Morphology of liver damage among polyvinyl chloride production workers. A report on 51 cases. Ann N Y Acad Sci 246:278–285. 10.1111/j.1749-6632.1975.tb51103.x.1054962
Gehring PJ, Watanabe PG, Park CN. 1978. Resolution of dose-response toxicity data for chemicals requiring metabolic activation: example-vinyl chloride. Toxicol Appl Pharmacol 44(3):581–591. 10.1016/0041-008x(78)90266-1.567390
Gelin M, Van de Stadt J, Rickaert F, . 1989. Epithelioid hemangioendothelioma of the liver following contact with vinyl chloride. Recurrence after orthotopic liver transplantation. J Hepatol 8(1):99–106. 10.1016/0168-8278(89)90168-2.2646369
Gennaro V, Ceppi M, Crosignani P, . 2008. Reanalysis of updated mortality among vinyl and polyvinyl chloride workers: Confirmation of historical evidence and new findings. BMC Public Health 8:21. 10.1186/1471-2458-8-21.18211695
Gennissen A, Boeckx M, Sevenster A. 2018. European Council of Vinyl Manufacturers comments on Cicalese et al.: “An ecological study of the association between air pollution and hepatocellular carcinoma incidence in Texas”. Liver Cancer 7(3):297–298. 10.1159/000486528.30319988
Gentry PR, Covington TR, Clewell HJ. 2003. Evaluation of the potential impact of pharmacokinetic differences on tissue dosimetry in offspring during pregnancy and lactation. Regul Toxicol Pharmacol 38(1):1–16. 10.1016/s0273-2300(03)00047-3.12878049
Gilbert SG, Miltz J, Giacin JR. 1980. Transport considerations of potential migrants from food packaging materials. J Food Process Preserv 4:27–49. 10.1111/j.1745-4549.1980.tb00594.x.
Ginsberg GL. 2003. Assessing cancer risks from short-term exposures in children. Risk Anal 23(1):19–34. 10.1111/1539-6924.00287.12635720
Girardi P, Barbiero F, Baccini M, . 2022. Mortality for lung cancer among PVC baggers employed in the vinyl chloride industry. Int J Environ Res Public Health 19(10):6246. 10.3390/ijerph19106246.35627783
Giri AK. 1995. Genetic toxicology of vinyl chloride-a review. Mutat Res 339(1):1–14. 10.1016/0165-1110(94)00011-z.7877642
Gonzalez-Reche LM, Koch HM, Weib T, . 2002. Analysis of ethenoguanine adducts in human urine using high performance liquid chromatography- tandem mass spectrometry. Toxicol Lett 134(1 to 3):71–77. 10.1016/S0378-4274(02)00165-0.12191863
Gordon SJ, Meeks SA. 1977. A study of gaseous pollutants in the Houston, Texas area. AIChE Symposium Series 73(165):84–94.
Gossett JM. 1987. Measurement of Henry’s law constants for C1 and C2 chlorinated hydrocarbons. Environ Sci Technol 21:202–208. 10.1021/es00156a012.
Gossett JM. 2010. Sustained aerobic oxidation of vinyl chloride at low oxygen concentrations. Environ Sci Technol 44(4):1405–1411. 10.1021/es9033974.20092304
Grainger RG, Walker AE, Ward AM. 1980. Vinyl chloride monomer–induced disease: Clinical, radiological and immunological aspects. In: Preger L, ed. Induced disease, drug, irradiation, occupation. New York, NY: Grune and Stratton, 191–214.
Green T, Hathway DE. 1975. The biological fate in rats of vinyl chloride in relation to its oncogenicity. Chem Biol Interact 11(6):545–562. 10.1016/0009-2797(75)90030-7.1201617
Green T, Hathway DE. 1977. The chemistry and biogenesis of the S-containing metabolites of vinyl chloride in rats. Chem Biol Interact 17(2):137–150. 10.1016/0009-2797(77)90080-1.328181
Green T, Hathway DE. 1978. Interactions of vinyl chloride with rat-liver DNA in vivo. Chem Biol Interact 22(2–3):211–224. 10.1016/0009-2797(78)90126-6.699172
Grimsrud EP, Rasmussen RA. 1975a. The analysis of chlorofluorocarbons in the troposphere by gas chromatography-mass spectrometry. Atmos Environ 9:1010–1013. 10.1016/0004-6981(75)90021-9.
Grimsrud EP, Rasmussen RA. 1975b. Survey and analysis of halocarbons in the atmosphere by gas chromatography-mass spectrometry. Atmos Environ 9:1014–1017. 10.1016/0004-6981(75)90022-0.
Gros L, Ishchenko AA, Saparbaev M. 2003. Enzymology of repair of etheno-adducts. Mutat Res 531(1–2):219–229. 10.1016/j.mrfmmm.2003.07.008.14637257
Guardiola JJ, Beier JI, Falkner KC, . 2016. Occupational exposures at a polyvinyl chloride production facility are associated with significant changes to the plasma metabolome. Toxicol Appl Pharmacol 313:47–56. 10.1016/j.taap.2016.10.001.27765658
Guardiola JJ, Hardesty JE, Beier JI, . 2021. Plasma metabolomics analysis of polyvinyl chloride workers identifies altered processes and candidate biomarkers for hepatic hemangiosarcoma and its development. Int J Mol Sci 22(10) 10.3390/ijms22105093.
Guengerich FP, Watanabe PG. 1979. Metabolism of [14C]- and [36Cl]-labeled vinyl chloride in vivo and in vitro. Biochem Pharmacol 28:589–596. 10.1016/0006-2952(79)90140-0.444246
Guengerich FP, Ghodke PP. 2021. Etheno adducts: from tRNA modifications to DNA adducts and back to miscoding ribonucleotides. Genes Environ 43(1):24. 10.1186/s41021-021-00199-x.34130743
Guengerich FP, Crawford WM, Watanabe PG. 1979. Activation of vinyl chloride to covalently bound metabolites: roles of 2-chloroethylene oxide and 2-chloroacetaldehyde. Biochemistry 18(23):5177–5182. 10.1021/bi00590a023.497175
Guengerich FP, Mason PS, Stott WJ, . 1981. Roles of 2-haloethylene oxide and 2-haloacetaldehydes derived from vinyl bromide and vinyl chloride in irreversible binding to protein and DNA. Cancer Res 41:4391–4398.7030476
Guichard Y, el Ghissassi F, Nair J, . 1996. Formation and accumulation of DNA ethenobases in adult Sprague-Dawley rats exposed to vinyl chloride. Carcinogenesis 17(8):1553–1559. 10.1093/carcin/17.8.1553.8761409
Guido M, Sarcognato S, Pelletti G, . 2016. Sequential development of hepatocellular carcinoma and liver angiosarcoma in a vinyl chloride-exposed worker. Hum Pathol 57:193–196. 10.1016/j.humpath.2016.07.021.27544804
Gwinner LM, Laib RJ, Filser JG, . 1983. Evidence of chloroethylene oxide being the reactive metabolite of vinyl chloride towards DNA: Comparative studies with 2,2’-dichlorodiethyl ether. Carcinogenesis 4:1483–1486. 10.1093/carcin/4.11.1483.6196138
Hagmar L, Akesson B, Nielson J, . 1990. Mortality and cancer morbidity in workers exposed to low levels of vinyl chloride monomer at a polyvinyl chloride processing plant. Am J Ind Med 17:553–565. 10.1002/ajim.4700170502.2337081
Hallbourg RR, Delfino JJ, Miller WL. 1992. Organic priority pollutants in groundwater and surface water at three landfills in north central Florida. Water Air Soil Pollut 65:307–332. 10.1007/BF00479894.
Hansteen IL, Hillestad L, Thiis-Evensen E, . 1978. Effects of vinyl chloride in man: a cytogenetic follow-up study. Mutat Res 51(2):271–278. 10.1016/s0027-5107(78)80022-0.692543
Harkov R, Kebbekus B, Bozzelli JW, . 1984. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ 38:259–274. 10.1016/0048-9697(84)90220-1.
Harris DK. 1953. Health problems in the manufacture and use of plastics. Br J Ind Med 10:255–268. 10.1136/oem.10.4.255.13106232
Harris DK, Adams WG. 1967. Acro-osteolysis occurring in men engaged in the polymerization of vinyl chloride. Br Med J 3(5567):712–714. 10.1136/bmj.3.5567.712.6038365
Hartmans S, deBont JAM, Tramper J, . 1985. Bacterial degradation of vinyl chloride. Biotech Letters 7:383–388. 10.1007/BF01166208.
Hatch M, Kline J, Stein Z. 1981. Power considerations in studies of reproductive effects of vinyl chloride and some structural analogs. Environ Health Perspect 41:195–201. 10.1289/ehp.8141195.7333238
Hathway DE. 1977. Comparative mammalian metabolism of vinyl chloride and vinylidene chloride in relation to oncogenic potential. Environ Health Perspect 21:55–59. 10.1289/ehp.772155.612460
Heath CW, Fable H, Creech JL. 1975. Characteristics of cases of angiosarcoma of the liver among vinyl chloride workers in the United States. Ann N Y Acad Sci 246:231–236. 10.1111/j.1749-6632.1975.tb51097.x 1054956
Heath CW, Dumont CR, Gamble J, . 1977. Chromosomal damage in men occupationally exposed to vinyl chloride monomer and other chemicals. Environ Res 14(1):68–72. 10.1016/0013-9351(77)90067-6.891506
Hefner RE, Watanabe PG, Gehring PJ. 1975a. Percutaneous absorption of vinyl chloride. Toxicol Appl Pharmacol 34(3):529–532. 10.1016/0041-008x(75)90149-0.813333
Hefner RE, Watanabe PG, Gehring PJ. 1975b. Preliminary studies on the fate of inhaled vinyl chloride monomer (VCM) in rats. Environ Health Perspect 11:85–95. 10.1289/ehp.751185.1175571
Hehir RM, McNamara BP, McLaughlin J, . 1981. Cancer induction following single and multiple exposures to a constant amount of vinyl chloride monomer. Environ Health Perspect 41:63–72. 10.1289/ehp.814163.7333245
Heldaas SS, Langard SL, Andersen A. 1984. Incidence of cancer among vinyl chloride and polyvinyl chloride workers. Br J Ind Med 41:25–30. 10.1136/oem.41.1.25.6691932
Heldaas SS, Andersen AA, Langard S. 1987. Incidence of cancer among vinyl chloride and polyvinyl chloride workers: Further evidence for an association with malignant melanoma. Br J Ind Med 44:278–280. 10.1136/oem.44.4.278.3567104
Ho SF, Phoon WH, Gan SL, . 1991. Persistent liver dysfunction among workers at a vinyl chloride monomer polymerization plant. J Soc Occup Med 41(1):10–16. 10.1093/occmed/41.1.10.2011000
Hoffmann D, Patrianakos C, Brunnemann KD, . 1976. Chromatographic determination of vinyl chloride in tobacco smoke. Anal Chem 48(1):47–50. 10.1021/ac60365a063.1244767
Hollstein M, Marion MJ, Lehman T, . 1994. P53 mutations at A:T base pairs in angiosarcomas of vinyl chloride-exposed factory workers. Carcinogenesis 15(1):1–3. 10.1093/carcin/15.1.1.8293534
Holmberg B, Kronevi T, Winell M. 1976. The pathology of vinyl chloride exposed mice. Acta Vet Scand 17(3):328–342. 10.1186/BF03547913.988738
Holt S, Roy G, Mitra S, . 2000. Deficiency of N-methylpurine-DNA-glycosylase expression in nonparenchymal cells, the target cell for vinyl chloride and vinyl fluoride. Mutat Res 460(2):105–115. 10.1016/s0921-8777(00)00019-7.10882851
Hong CB, Winston JM, Thornburg LP, . 1981. Follow-up study on the carcinogenicity of vinyl chloride and vinylidene chloride in rats and mice: tumor incidence and mortality subsequent to exposure. J Toxicol Environ Health 7(6):909–924. 10.1080/15287398109530034.7265317
Howard CJ. 1976. Rate constants for the gas-phase reactions of hydroxyl radicals with ethylene and halogenated ethylene compounds. J Chem Phys 65:4771–4777. 10.1063/1.432932.
Hozo I, Andelinovic S, Ljutic D, . 1997. Two new classes of liver angiosarcoma: History and perspectives of liver angiosarcoma among plastic industry workers. Toxicol Ind Health 13(5):639–648. 10.1177/074823379701300505.9284534
Hozo I, Miric D, Bojic L, . 2000. Liver angiosarcoma and hemangiopericytoma after occupational exposure to vinyl chloride monomer. Environ Health Perspect 108(8):793–795. 10.1289/ehp.00108793.10964802
Hrivnak L, Rozinova Z, Korony S, . 1990. Cytogenetic analysis of peripheral blood lymphocytes in workers exposed to vinyl chloride. Mutat Res 240(2):83–85. 10.1016/0165-1218(90)90010-y.2300078
Hsiao TJ, Wang JD, Yang PM, . 2004. Liver fibrosis in asymptomatic polyvinyl chloride workers. J Occup Environ Med 46(9):962–966. 10.1097/01.jom.0000137722.66767.38.15354062
Hsieh HI, Chen PC, Wong RH, . 2007. Effect of the CYP2E1 genotype on vinyl chloride monomer-induced liver fibrosis among polyvinyl chloride workers. Toxicology 239(1–2):34–44. 10.1016/j.tox.2007.06.089.17659824
Hsieh HI, Chen PC, Wong RH, . 2011. Mortality from liver cancer and leukaemia among polyvinyl chloride workers in Taiwan: an updated study. Occup Environ Med 68(2):120–125. 10.1136/oem.2010.056978.20798004
Hsu YH, Chuang HC, Lee YH, . 2019. Induction of fibrosis and autophagy in kidney cells by vinyl chloride. Cells 8(6):601. 10.3390/cells8060601.31212930
Huang PC, Liu LH, Shie RH, . 2016. Assessment of urinary thiodiglycolic acid exposure in school-aged children in the vicinity of a petrochemical complex in central Taiwan. Environ Res 150:566–572. 10.1016/j.envres.2015.11.027.26657495
Huberman E, Bartsch H, Sachs L. 1975. Mutation induction in Chinese hamster V79 cells by two vinyl chloride metabolites, chloroethylene oxide and 2-chloroacetaldehyde. Int J Cancer 16(4):639–644. 10.1002/ijc.2910160414.1176210
Hultmark D, Sundh K, Johansson L, . 1979. Ethanol inhibition of vinyl chloride metabolism in isolated rat hepatocytes. Chem Biol Interact 25(1):1–6. 10.1016/0009-2797(79)90064-4.466722
Hussain S, Osterman-Golkar S. 1976. Comment on the mutagenic effectiveness of vinyl chloride metabolites. Chem Biol Interact 12(3–4):265–267. 10.1016/0009-2797(76)90042-9.767011
Hüttner E, Holzapfel B. 1996. HPRT mutant frequencies and detection of large deletions by multiplex-PCR in human lymphocytes of vinyl chloride exposed and non-exposed populations. Toxicol Lett 88(1–3):175–183. 10.1016/0378-4274(96)03735-6.8920734
Hüttner E, Nikolova T. 1998. Cytogenetic analysis of peripheral lymphocytes in a population exposed to vinyl chloride through an accidental release into the environment. Toxicol Lett 96–97:143–148. 10.1016/S0378-4274(98)00061-7.
Hüttner E, Nikolova T, Foth H. 1998. Genotoxic effects in humans after an accidental vinyl chloride exposure. Naunyn Schmiedebergs Arch Pharmakol 357(4):R141.
Hüttner E, Gotze A, Nikolova T. 1999. Chromosomal aberrations in humans as genetic endpoints to assess the impact of pollution. Mutat Res 45:251–257. 10.1016/S1383-5718(99)00130-8.
IARC. 2012. Vinyl chloride. In: IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 100F. Chemical agents and related occupations. Lyon, France: International Agency for Research on Cancer, 451–478. https://publications.iarc.fr/123. February 4, 2021.
ICIS. 2006. Chemical profile: Vinyl chloride. ICIS Chemical Business. https://www.icis.com/explore/resources/news/2006/10/06/2016491/chemical-profile-vinyl-chloride/. October 26, 2021.
Infante PF. 1976. Oncogenic and mutagenic risks in communities with polyvinyl chloride production facilities. Ann N Y Acad Sci 271:49–57. 10.1111/j.1749-6632.1976.tb23092.x.1069539
Infante PF, Wagoner JK, McMichael AJ, . 1976a. Genetic risks of vinyl chloride. Lancet 307(7962):734–735. 10.1016/s0140-6736(76)93103-2.
Infante PF, Wagoner JK, Waxweiler RJ. 1976b. Carcinogenic, mutagenic and teratogenic risks associated with vinyl chloride. Mutat Res 41:131–141. 10.1016/0027-5107(76)90083-x.1012297
Ivanetich KM, Aronson I, Katz ID. 1977. The interaction of vinyl chloride with rat hepatic microsomal cytochrome P-450 in vitro. Biochem Biophys Res Commun 74(4):1411–1418. 10.1016/0006-291x(77)90599-x.14640
Jacobsen JS, Perkins CP, Callahan JT, . 1989. Mechanisms of mutagenesis by chloroacetaldehyde. Genetics 121(2):213–222. 10.1093/genetics/121.2.213.2659432
Jaeger RJ, Reynolds ES, Conolly RB, . 1974. Acute hepatic injury by vinyl chloride in rats pretreated with phenobarbital. Nature 252(5485):724–726. 10.1038/252724a0.4437626
Jaeger RJ, Murphy SD, Reynolds ES, . 1977. Chemical modification of acute hepatotoxicity of vinyl chloride monomer in rats. Toxicol Appl Pharmacol 41(3):597–607. 10.1016/s0041-008x(77)80013-6.411197
Jayson MIV, Bailey AJ, Black C, . 1976. Clinical aspects of vinyl chloride disease: Collagen studies in acroosteolysis. Proc R Soc Med 69:295–297. 10.1177/003591577606900424.1265042
Jedrychowski RA, Sokal JA, Chmielnicka J. 1984. Influence of exposure mode on vinyl chloride action. Arch Toxicol 55(3):195–198. 10.1007/BF00316128.6497652
Jedrychowski RA, Sokal JA, Chmielnicka J. 1985. Comparison of the impact of continuous and intermittent exposure to vinyl chloride, including phenobarbital effect. J Hyg Epidemiol Microbiol Immunol 29(2):111–120.
Ji F, Wang W, Xia ZL, . 2010. Prevalence and persistence of chromosomal damage and susceptible genotypes of metabolic and DNA repair genes in Chinese vinyl chloride-exposed workers. Carcinogenesis 31(4):648–653. 10.1093/carcin/bgq015.20100738
Jia C, Foran J. 2013. Air toxics concentrations, source identification, and health risks: An air pollution hot spot in southwest Memphis, TN. Atmos Environ 81:112–116. 10.1016/j.atmosenv.2013.09.006.
Jia J, Chen SQ, Pan WZ, . 2022. Mechanism of subchronic vinyl chloride exposure combined with a high-fat diet on hepatic steatosis. J Appl Toxicol 42(3):490–505. 10.1002/jat.4234.34601724
Jiao J, Feng NN, Li Y, . 2012. Estimation of a safe level for occupational exposure to vinyl chloride using a benchmark dose method in central China. J Occup Health 54(4):263–270. 10.1539/joh.11-0157-oa.22672882
John JA, Smith FA, Schwetz BA. 1981. Vinyl chloride: inhalation teratology study in mice, rats and rabbits. Environ Health Perspect 41:171–177. 10.1289/ehp.8141171.7333235
John JA, Smith FA, Leong BK, . 1977. The effects of maternally inhaled vinyl chloride on embryonal and fetal development in mice, rats, and rabbits. Toxicol Appl Pharmacol 39(3):497–513. 10.1016/0041-008x(77)90141-7.854925
Jones DB, Smith PM. 1982. Progression of vinyl chloride induced hepatic fibrosis to angiosarcoma of the liver. Br J Ind Med 39(3):306–307. 10.1136/oem.39.3.306.7201322
Jones RD, Smith DM, Thomas PG. 1988. A mortality study of vinyl chloride monomer workers employed in the United Kingdom in 1940-1974. Scand J Work Environ Health 14(3):153–160. 10.5271/sjweh.1937.3393850
Jury WA, Spencer WF, Farmer WJ. 1984. Behavior assessment model for trace organics in soil: III. Application of screening model. J Environ Qual 13:573–579. 10.2134/jeq1984.00472425001300040013x.
Kaelin BR, McKenzie CM, Hempel KW, . 2020. Adipose tissue-liver crosstalk during pathologic changes caused by vinyl chloride metabolites in mice. Toxicol Appl Pharmacol 399:115068. 10.1016/j.taap.2020.115068.32445754
Kandala JC, Mrema JE, DeAngelo A, . 1990. 2-Chloroacetaldehyde and 2-chloroacetal are potent inhibitors of DNA synthesis in animal cells. Biochem Biophys Res Commun 167(2):457–463. 10.1016/0006-291x(90)92045-2.2322235
Kappus H, Bolt HM, Buchter A, . 1976. Liver microsomal uptake of [14C]vinyl chloride and transformation to protein alkylating metabolites in vitro. Toxicol Appl Pharmacol 37(3):461–471. 10.1016/0041-008x(76)90208-8.9709
Kielhorn J, Melber C, Wahnschaffe U, . 2000. Vinyl chloride: still a cause for concern. Environ Health Perspect 108(7):579–588. 10.1289/ehp.00108579.10905993
Knight KR, Gibbons R. 1987. Increased collagen synthesis and cross-link formation in the skin of rats exposed to vinyl chloride monomer. Clin Sci (Lond) 72(6):673–678. 10.1042/cs0720673.3595074
Konkle SL, Zierold KM, Taylor KC, . 2020. National secular trends in ambient air volatile organic compound levels and biomarkers of exposure in the United States. Environ Res 182:108991. 10.1016/j.envres.2019.108991.31835113
Kotseva K. 1996. Five year follow-up study of the incidence of arterial hypertension and coronary heart disease in vinyl chloride monomer and polyvinyl chloride production workers. Int Arch Occup Environ Health 68(6):377–379. 10.1007/bf00377854.8891770
Kowalczyk P, Ciesla JM, Saparbaev M, . 2006. Sequence-specific p53 gene damage by chloroacetaldehyde and its repair kinetics in Escherichia coli. Acta Biochim Pol 53(2):337–347. 10.18388/abp.2006_3347.16582987
Krajewski J, Dobecki M, Gromiec J. 1980. Retention of vinyl chloride in the human lung. Br J Ind Med 37(4):373–374. 10.1136/oem.37.4.373.7448132
Krishnan K, Andersen ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSA, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Krock R. 2018. Vinyl Institute comments on Cicalese et al.: “An ecological study of the association between air pollution and hepatocellular carcinoma incidence in Texas”. Liver Cancer 7(3):295–296. 10.1159/000486432.30319987
Kucerova M, Polivkova Z, Batora J. 1979. Comparative evaluation of the frequency of chromosomal aberrations and the SCE numbers in peripheral lymphocytes of workers occupationally exposed to vinyl chloride monomer. Mutat Res 67(1):97–100. 10.1016/0165-1218(79)90105-8.460297
Kuchenmeister F, Wang M, Klein RG, . 1996. Transport of reactive metabolites of procarcinogens between different liver cell types, as demonstrated by the single cell microgel electrophoresis assay. Toxicol Lett 88(1 to 3):29–34. 10.1016/0378-4274(96)03714-9.8920713
Kudo YY, Yamada S, Nakamura I, . 1990. On the changes in peripheral red cells in mice exposed to vinyl chloride monomer. Pol J Occup Med 3(3):301–310.2136537
Kumar AK, Balachandar V, Arun M, . 2013. A comprehensive analysis of plausible genotoxic covariates among workers of a polyvinyl chloride plant exposed to vinyl chloride monomer. Arch Environ Contam Toxicol 64(4):652–658. 10.1007/s00244-012-9857-1.23271343
Kwok ESC, Atkinson R. 1995. Estimation of hydroxyl radical reaction rate constants for gas-phase organic compounds using a structure-reactivity relationship: An update. Atmos Environ 29(14):1685–1695. 10.1016/1352-2310(95)00069-B
Laib RJ. 1982. Specific covalent binding and toxicity of aliphatic halogenated xenobiotics. Q Rev Drug Metab Drug Interact 4(1):1–48. 10.1515/dmdi.1982.4.1.1.6762624
Laib RJ. 1986. The role of cyclic base adducts in vinyl-chloride-induced carcinogenesis: studies on nucleic acid alkylation in vivo. IARC Sci Publ 70(70):101–108.
Laib RJ, Bolt HM. 1977. Alkylation of RNA by vinyl chloride metabolites in vitro and in vivo: Formation of 1-N-6-ethenoadenosine. Toxicology 8:185–195. 10.1016/0300-483X(77)90007-5.929626
Laib RJ, Stockle G, Bolt HM, . 1979. Vinyl chloride and trichloroethylene: comparison of alkylating effects of metabolites and induction of preneoplastic enzyme deficiencies in rat liver. J Cancer Res Clin Oncol 94(2):139–147. 10.1007/BF00422494.157359
Laib RJ, Gwinner LM, Bolt HM. 1981. DNA alkylation by vinyl chloride metabolites: Etheno derivatives or 7-alkylation of guanine? Chem Biol Interact 37(1–2):219–231. 10.1016/0009-2797(81)90179-4.6974609
Laib RJ, Klein KP, Bolt HM. 1985. The rat liver foci bioassay: I. Age-dependence of induction by vinyl chloride of ATPase-deficient foci. Carcinogenesis 6(1):65–68. 10.1093/carcin/6.1.65.3155670
Laib RJ, Bolt HM, Cartier R, . 1989. Increased alkylation of liver DNA and cell turnover in young versus old rats exposed to vinyl chloride correlates with cancer susceptibility. Toxicol Lett 45(2–3):231–239. 10.1016/0378-4274(89)90014-3.2919404
Lang AL, Chen L, Poff GD, . 2018. Vinyl chloride dysregulates metabolic homeostasis and enhances diet-induced liver injury in mice. Hepatol Commun 2(3):270–284. 10.1002/hep4.1151.29507902
Lang AL, Krueger AM, Schnegelberger RD, . 2019. Rapamycin attenuates liver injury caused by vinyl chloride metabolite chloroethanol and lipopolysaccharide in mice. Toxicol Appl Pharmacol 382:114745. 10.1016/j.taap.2019.114745.31499194
Lang AL, Goldsmith WT, Schnegelberger RD, . 2020. Vinyl chloride and high-fat diet as a model of environment and obesity interaction. J Vis Exp 155:e60351. 10.3791/60351.
Langard S, Rosenberg J, Andersen A, . 2000. Incidence of cancer among workers exposed to vinyl chloride in polyvinyl chloride manufacture. Occup Environ Med 57:65–68. 10.1136/oem.57.1.65.10711272
Langauer-Lewowicka H, Dudziak Z, Byczkowska Z, . 1976. Cryoglobulinemia in Raynaud’s phenomenon due to vinyl chloride. Int Arch Occup Environ Health 35:197–207. 10.1007/BF00378274.
Langauer-Lewowicka H, Kurzbauer H, Byczkowska Z, . 1983. Vinyl chloride disease-neurological disturbances. Int Arch Occup Environ Health 52(2):151–157. 10.1007/BF00405418.6629505
Laplanche A, Clavel F, Contassot JC, . 1987. Exposure to vinyl chloride monomer: report on a cohort study. Br J Ind Med 44(10):711–715. 10.1136/oem.44.10.711.3676124
Laplanche A, Clavel-Chapelon F, Contassot JC, . 1992. Exposure to vinyl chloride monomer: results of a cohort study after a seven year follow up. The French VCM Group. Br J Ind Med 49(2):134–137. 10.1136/oem.49.2.134.1536821
Laumbach AD, Lee S, Wong J, . 1977. Studies on the mutagenicity of vinyl chloride metabolites and related chemicals. Prev Detect Cancer Proc Int Symp 1976 1:155–170.
Laval J, Saparbaev M. 2001. Enzymology of the repair in human cells and in Escherichia coli K12 of mutagenic ethenoadducts. Mutat Res 483:S35.
Lee CC, Bhandari JC, Winston JM, . 1977a. Inhalation toxicity of vinyl chloride and vinylidene chloride. Environ Health Perspect 21:25–32. 10.1289/ehp.772125.565702
Lee FI, Harry DS, Adams WG, . 1977b. Screening for liver disease in vinyl chloride workers. Br J Ind Med 34(2):142–147. 10.1136/oem.34.2.142.871446
Lee CC, Bhandari JC, Winston JM, . 1978. Carcinogenicity of vinyl chloride and vinylidene chloride. J Toxicol Environ Health 4(1):15–30. 10.1080/15287397809529640.633405
Lee FI, Smith PM, Bennett B, . 1996. Occupationally related angiosarcoma of the liver in the United Kingdom 1972-1994. Gut 39(2):312–318. 10.1136/gut.39.2.312.8977349
Lee CC, Shen Y, Hsu CW, . 2020. Reduced adiponectin:leptin ratio associated with inhalation exposure to vinyl chloride monomer. Sci Total Environ 703:135488. 10.1016/j.scitotenv.2019.135488.31757555
Lei YC, Yang HT, Ma YC, . 2004. DNA single strand breaks in peripheral lymphocytes associated with urinary thiodiglycolic acid levels in polyvinyl chloride workers. Mutat Res 561(1–2):119–126. 10.1016/j.mrgentox.2004.04.002.15238236
Lelbach WK. 1996. A 25-year follow-up study of heavily exposed vinyl chloride workers in Germany. Am J Ind Med 29(5):446–458. 10.1002/(SICI)1097-0274(199605)29:5<446::AID-AJIM3>3.0.CO;2-K.8732918
Lester D, Greenberg LA, Adams WR. 1963. Effects of single and repeated exposures of humans and rats to vinyl chloride. Am Ind Hyg Assoc J 24:265–275. 10.1080/00028896309342963.13929916
Lewis RJ. 1996. Vinyl chloride. In: Sax’s dangerous properties of industrial materials. 9^th^ ed. New York, NY: Van Nostrand Reinhold, 3377–3378.
Lewis R. 2001. Use of rank-order analysis of ordinal exposure data: Application to vinyl chloride exposure. Appl Occup Environ Hyg 16:188–191. 10.1080/104732201460325.11217710
Lewis R, Rempala G. 2003. A case-cohort study of angiosarcoma of the liver and brain cancer at a polymer production plant. J Occup Environ Med 45(5):538–545.12762079
Lewis RJ, Rempala G, Dell LD, . 2003. Vinyl chloride and liver and brain cancer at a polymer production plant in Louisville, Kentucky. J Occup Environ Med 45(5):533–537. 10.1097/01.jom.0000058348.05741.1d.12762078
Li Y, Marion MJ, Asherova M, . 1998. Mutant p21ras in vinyl chloride exposed workers. Biomarkers 3(6):433–439. 10.1080/135475098231075.23899395
Li Y, Marion MJ, Rundle A, . 2003a. A common polymorphism in XRCC1 as a biomarker of susceptibility for chemically induced genetic damage. Biomarkers 8(5):408–414. 10.1080/13547500310001619301.14602524
Li Y, Marion MJ, Ho R, . 2003b. Polymorphisms for vinyl chloride metabolism in French vinyl chloride workers. Int J Occup Med Environ Health 16(1):55–59.12705718
Li Y, Lee S, Marion MJ, . 2005a. Polymorphisms of microsomal epoxide hydrolase in French vinyl chloride workers. Int J Occup Med Environ Health 18(2):133–138.16201204
Li Y, Zhou M, Marion MJ, . 2005b. Polymorphisms in glutathione S-transferases in French vinyl chloride workers. Biomarkers 10(1):72–79. 10.1080/13547500500070364.16097394
Li Y, Marion MJ, Zipprich J, . 2006. The role of XRCC1 polymorphisms in base excision repair of etheno-DNA adducts in French vinyl chloride workers. Int J Occup Med Environ Health 19(1):45–52. 10.2478/v10001-006-0006-9.16881598
Li Y, Long C, Lin G, . 2009a. Effect of the XRCC1 codon 399 polymorphism on the repair of vinyl chloride metabolite-induced DNA damage. J Carcinog 8:14. 10.4103/1477-3163.56290.19822958
Li Y, Marion MJ, Zipprich J, . 2009b. Gene-environment interactions between DNA repair polymorphisms and exposure to the carcinogen vinyl chloride. Biomarkers 14(3):148–155. 10.1080/13547500902811266.19274602
Li Y, Feng NN, Zhang GH, . 2013. Polymorphisms in the p53 pathway genes and micronucleus occurrence in Chinese vinyl chloride-exposed workers. Int J Occup Med Environ Health 26(6):825–836. 10.2478/s13382-013-0155-6.24464562
Liang Y, Lang AL, Zhang J, . 2018. Exposure to vinyl chloride and its influence on western diet-induced cardiac remodeling. Chem Res Toxicol 31(6):482–493. 10.1021/acs.chemrestox.8b00043.29727174
Liber HL, Kaufmann W, Marion M, . 1999. Exposure to vinyl chloride is associated with a persistent increase in HRPT-mutants in the peripheral blood lymphocytes. Proc Am Assoc Cancer Res 40:508.
Lilis R, Anderson H, Nicholson WJ, . 1975. Prevalence of disease among vinyl chloride and polyvinyl chloride workers. Ann NY Acad Sci 246:22–41. 10.1111/j.1749-6632.1975.tb51078.x.123720
Lilis R, Anderson H, Miller A, . 1976. Pulmonary changes among vinyl chloride polymerization workers. Chest 69:299–303. 10.1378/chest.69.2_Supplement.299.1248311
Lim GQ, John K. 2020. Impact of energy production in the Barnett Shale gas region on the measured ambient hydrocarbon concentrations in Denton, Texas. Atmos Pollut Res 11(2):409–418. 10.1016/j.apr.2019.11.013.
Liss GM, Greenberg RA, Tamburro CH. 1985. Use of serum bile acids in the identification of vinyl chloride hepatotoxicity. Am J Med 78:68–76. 10.1016/0002-9343(85)90464-4.3966491
Liu S, He L, Bannister OB, . 2023. Western diet unmasks transient low-level vinyl chloride-induced tumorigenesis; potential role of the (epi-)transcriptome. Toxicol Appl Pharmacol 468:116514. 10.1016/j.taap.2023.116514.37061008
Lloyd MH, Gauld S, Copland L, . 1984. Epidemiological study of the lung function of workers at a factory manufacturing polyvinyl chloride. Br J Ind Med 41:328–333. 10.1136/oem.41.3.328.6743579
Lopez V, Chamoux A, Tempier M, . 2013. The long-term effects of occupational exposure to vinyl chloride monomer on microcirculation: a cross-sectional study 15 years after retirement. BMJ Open 3(6) 10.1136/bmjopen-2013-002785.
Loprieno N, Barale R, Baroncelli S, . 1976. Evaluation of the genetic effects induced by vinyl chloride monomer (VCM) under mammalian metabolic activation: Studies in vitro and in vivo. Mutat Res 40(2):85–95. 10.1016/0165-1218(76)90002-1.778611
Loprieno N, Barale R, Baroncelli S, . 1977. Induction of gene mutations and gene conversions by vinyl chloride metabolites in yeast. Cancer Res 37(1):253–257.318606
Lu PY, Metcalf RL, Plummer N, . 1977. The environmental fate of three carcinogens: benzo-(α)-pyrene, benzidine, and vinyl chloride evaluated in laboratory model ecosystems. Arch Environ Contam Toxicol 6(2–3):129–142. 10.1007/BF02097756.20063
Lu C, Bjerg PL, Zhang F, . 2011. Sorption of chlorinated solvents and degradation products on natural clayey tills. Chemosphere 83(11):1467–1474. 10.1016/j.chemosphere.2011.03.007.21459403
Luo JC, Liu HT, Cheng TJ, . 1998. Plasma Asp13-Ki-ras oncoprotein expression in vinyl chloride monomer workers in Taiwan. J Occup Environ Med 40(12):1053–1058.9871881
Luo JC, Liu HT, Cheng TJ, . 1999. Plasma p53 protein and anti-p53 antibody expression in vinyl chloride monomer workers in Taiwan. J Occup Environ Med 41(6):521–526. 10.1097/00043764-199906000-00020.10390705
Luo JC, Cheng TJ, Du CL, . 2003. Molecular epidemiology of plasma oncoproteins in vinyl chloride monomer workers in Taiwan. Cancer Detect Prev 27:94–101. 10.1016/S0361-090X(03)00021-7.12670519
Luong C, Zhang K. 2017. An assessment of emission event trends within the Greater Houston area during 2003-2013. Air Qual Atmos Health 10(5):543–554. 10.1007/s11869-016-0449-5.
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Regression equations for the estimation of K_oc_. In: Handbook of chemical property estimation methods. Environmental behavior of organic compounds. New York, NY: McGraw Hill Book Co., 4–9.
Maciejewska AM, Ruszel KP, Nieminuszczy J, . 2010. Chloroacetaldehyde-induced mutagenesis in Escherichia coli: The role of AlkB protein in repair of 3,N^4^-ethenocytosine and 3,N^4^-α-hydroxyethanocytosine. Mutat Res 684(1–2):24–34. 10.1016/j.mrfmmm.2009.11.005.19941873
Magnavita N, Bergamaschi A, Garcovich A, . 1986. Vasculitic purpura in vinyl chloride disease: a case report. Angiology 37(5):382–388. 10.1177/000331978603700508.3013049
Magnusson J, Ramel C. 1978. Mutagenic effects of vinyl chloride on Drosophila melanogaster with and without pretreatment with sodium phenobarbiturate. Mutat Res 57(3):307–312. 10.1016/0027-5107(78)90215-4.97527
Malaveille C, Bartsch H, Barbin A, . 1975. Mutagenicity of vinyl chloride, chloroethyleneoxide, chloroacetaldehyde and chloroethanol. Biochem Biophys Res Commun 63(2):363–370. 10.1016/0006-291x(75)90697-x.1092301
Maltoni C, Lefemine G. 1975. Carcinogenicity bioassays of vinyl chloride: current results. Ann N Y Acad Sci 246:195–218. 10.1111/j.1749-6632.1975.tb51094.x.1054953
Maltoni C, Cotti G. 1988. Carcinogenicity of vinyl chloride in Sprague-Dawley rats after prenatal and postnatal exposure. Ann N Y Acad Sci 534:145–159. 10.1111/j.1749-6632.1988.tb30108.x.3389652
Maltoni C, Lefemine G, Ciliberti A, . 1981. Carcinogenicity bioassays of vinyl chloride monomer: a model of risk assessment on an experimental basis. Environ Health Perspect 41:3–29. 10.1289/ehp.81413.6800782
Maricq HR, Johnson MN, Whetstone CL, . 1976. Capillary abnormalities in polyvinyl chloride production workers. Examination by in vivo microscopy. JAMA 236(12):1368–1371. 10.1001/jama.1976.03270130030022.989092
Marion MJ. 1998. Critical genes as early warning signs: Example of vinyl chloride. Toxicol Lett 102–103:603–607. 10.1016/S0378-4274(98)00255-0.
Marion MJ, Boivin-Angele S. 1999. Vinyl chloride-specific mutations in humans and animals. IARC Sci Publ 150(150):315–324.
Marion MJ, Froment O, Trepo C. 1991. Activation of Ki-ras gene by point mutation in human liver angiosarcoma associated with vinyl chloride exposure. Mol Carcinog 4(6):450–454. 10.1002/mc.2940040607.1793483
Markowitz SS, McDonald CJ, Fethiere W, . 1972. Occupational acroosteolysis. Arch Dermatol 106(2):219–223. 10.1001/archderm.1972.01620110051012.4261762
Maroni M, Fanetti AC. 2006. Liver function assessment in workers exposed to vinyl chloride. Int Arch Occup Environ Health 79(1):57–65. 10.1007/s00420-005-0018-y.16091976
Maroni M, Mocci F, Visentin S, . 2003. Periportal fibrosis and other liver ultrasonography findings in vinyl chloride workers. Occup Environ Med 60(1):60–65. 10.1136/oem.60.1.60.12499459
Marsh GM, Towle KM. 2018. Methodological limitations to the analysis by Cicalese et al. Liver Cancer 7(3):299–300. 10.1159/000489022.30319989
Marsh GM, Youk AO, Buchanich JM, . 2007a. Mortality patterns among industrial workers exposed to chloroprene and other substances. I. General mortality patterns. Chem Biol Interact 166(1–3):285–300. 10.1016/j.cbi.2006.08.011.16999943
Marsh GM, Youk AO, Buchanich JM, . 2007b. Mortality patterns among industrial workers exposed to chloroprene and other substances. II. Mortality in relation to exposure. Chem Biol Interact 166(1–3):301–316. 10.1016/j.cbi.2006.08.012.17007827
Marsh GM, Kruchten A, Buchanich JM. 2021. Mortality patterns among industrial workers exposed to chloroprene and other substances: Extended follow-up. J Occup Environ Med 63(2):126–138. 10.1097/jom.0000000000002093.33234876
Marsteller HJ, Lelbach WK, Muller R, . 1975. Unusual splenomegalic liver disease as evidenced by peritoneoscopy and guided liver biopsy among polyvinyl chloride production workers. Ann NY Acad Sci 246:95–134. 10.1111/j.1749-6632.1975.tb51085.x.123722
Mastrangelo G, Manno M, Marcer G, . 1979. Polyvinyl chloride pneumoconiosis: epidemiological study of exposed workers. J Occup Med 21(8):540–542.469619
Mastrangelo G, Fedeli U, Fadda E, . 2003. Lung cancer risk in workers exposed to poly(vinyl chloride) dust: a nested case-referent study. Occup Environ Med 60(6):423–428. 10.1136/oem.60.6.423.12771394
Mastrangelo G, Fedeli U, Fadda E, . 2004. Increased risk of hepatocellular carcinoma and liver cirrhosis in vinyl chloride workers: synergistic effect of occupational exposure with alcohol intake. Environ Health Perspect 112(11):1188–1192. 10.1289/ehp.6972.15289165
Mastrangelo G, Cegolon L, Fadda E, . 2013. Comment to “Vinyl chloride exposure and cirrhosis: a systematic review and meta-analysis”. Dig Liver Dis 45(8):701–702. 10.1016/j.dld.2013.02.006.23499371
Mastromatteo E, Fisher AM, Christie H, . 1960. Acute inhalation toxicity of vinyl chloride to laboratory animals. Am Ind Hyg Assoc J 21:394–398. 10.1080/00028896009344092.13767993
Matsuda T, Yagi T, Kawanishi M, . 1995. Molecular analysis of mutations induced by 2-chloroacetaldehyde, the ultimate carcinogenic form of vinyl chloride, in human cells using shuttle vectors. Carcinogenesis 16(10):2389–2394. 10.1093/carcin/16.10.2389.7586140
McCann J, Simmon V, Streitwieser D, . 1975. Mutagenicity of chloroacetaldehyde, a possible metabolic product of 1,2-dichloroethane (ethylene dichloride), chloroethanol (ethylene chlorohydrin), vinyl chloride, and cyclophosphamide. Proc Natl Acad Sci U S A 72(8):3190–3193. 10.1073/pnas.72.8.3190.1059105
McCarthy MC, Hafner HR, Montzka SA. 2006. Background concentrations of 18 air toxics for North America. J Air Waste Manag Assoc 56(1):3–11. 10.1080/10473289.2006.10464436.16499141
McClain C, Lewis R, Reynolds L, . 2002. The serum hyaluronic concentration is a screening test for angiosarcoma in plant workers exposed to vinyl chloride. Hepatology 36(4):706A.
McMahon PB, Lindsey BD, Conlon MD, . 2019. Hydrocarbons in upland groundwater, Marcellus Shale Region, Northeastern Pennsylvania and Southern New York, U.S.A. Environ Sci Technol 53(14):8027–8035. 10.1021/acs.est.9b01440.31246428
McNeal TP, Olivo C, Begley TH. 2003. Determination of residual vinyl chloride and vinylidene chloride in food packages containing polyvinyl chloride and Saran resins. In: FDA science: Protecting America’s health: 2003 FDA Science Forum: April 24-25, 2003. Washington, DC: U.S. Food and Drug Administration., 40–41.
Meylan WM, Howard PH, Boethling RS, . 1999. Improved method for estimating bioconcentration/bioaccumulation factor from octanol/water partition coefficient. Environ Toxicol Chem 18(4):664–672. 10.1002/etc.5620180412.
Micu D, Mihailescu E, Vilau C, . 1985. The value of some cytoenzymochemical investigations of the leukocytes and platelets in estimating the effects of occupational exposure to benzene, vinyl chloride and carbon disulphide. Med Interne 23(2):115–120.4023584
Miller JJ, Beizer MB. 1985. Air quality in residences adjacent to an active hazardous waste disposal site. In: Proceedings: 78^th^ APCA Annual Meeting, June 16-21, 1985 Detroit, Michigan. Air Pollution Control Association, 2–17.
Mirkova E, Mihaylova A, Nosko M. 1978. [Embryotoxic and teratogenic effects in vinyl chloride]. Hig Zdraveopaz 21:440–443. (Bulgarian)
Monson RR, Peters JM, Johnson MN. 1975. Proportional mortality among vinyl chloride workers. Environ Health Perspect 11:75–77. 10.1016/S0140-6736(74)91771-1.17539114
Morinello EJ, Ham AJL, Ranasinghe A, . 2002a. Molecular dosimetry and repair of N2,3 ethenoguanine in rats exposed to vinyl chloride. Cancer Res 62:5189–5195.12234983
Morinello EJ, Koe H, Ranasinghe A, . 2002b. Differential induction of N2,3-ethenoguanine in rat brain and liver after exposure to vinyl chloride. Cancer Res 62:5183–5188.12234982
Müller JPH, Korte F. 1977. Beiträge zur okologischen chemie CXXXVI kurze mitteilung zur nicht sensibilisierten photooxidation von chloräthylenen. Chemosphere 6(6):341–346. 10.1016/0045-6535(77)90098-4.
Müller G, Norpoth K, Wickramasinghe RH. 1979. An analytical method using GC-MS for the quantitative determination of urinary thiodiglycolic acid. Int Arch Occup Environ Health 44:185–191. 10.1007/BF00381133.521174
Mumtaz MM, Ray M, Crowell SR, . 2012. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mundt KA, Dell LD, Austin RP, . 2000. Historical cohort study of 10,109 men in the North American vinyl chloride industry, 1942-1972: Update of cancer mortality to 31 December 1995. Occup Environ Med 57(11):774–781. 10.1136/oem.57.11.774.11024202
Mundt KA, Dell LD, Crawford L, . 2017. Quantitative estimated exposure to vinyl chloride and risk of angiosarcoma of the liver and hepatocellular cancer in the US industry-wide vinyl chloride cohort: mortality update through 2013. Occup Environ Med 74(10):709–716. 10.1136/oemed-2016-104051.28490663
Mutlu E, Collins LB, Stout MD, . 2010. Development and application of an LC-MS/MS method for the detection of the vinyl chloride-induced DNA adduct N(2),3-ethenoguanine in tissues of adult and weanling rats following exposure to [(13)C(2)]-VC. Chem Res Toxicol 23(9):1485–1491. 10.1021/tx1001767.20799743
Mutlu E, Jeong YC, Collins LB, . 2012. A new LC-MS/MS method for the quantification of endogenous and vinyl chloride-induced 7-(2-Oxoethyl)guanine in Sprague-Dawley rats. Chem Res Toxicol 25(2):391–399. 10.1021/tx200447w.22211352
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Nelson YM, Jewell WJ. 1993. Vinyl chloride biodegradation with methanotrophic attached films. J Environ Eng ASCE 119(5):890–907. 10.1061/(ASCE)0733-9372(1993)119:5(890).
NIOSH. 1977. A cross-sectional epidemiologic survey of vinyl chloride workers. Cincinnati, OH: National Institute for Occupational Safety and Health. PB274193. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB274193.xhtml. August 29, 2021.
NIOSH. 1986. Chemical review: Vinyl chloride. Dangerous properties of industrial materials report. Vol. 6. Washington, DC: National Institute for Occupational Safety and Health. 13–43. NIOSH00188891.
NIOSH. 1990. Vinyl chloride. In: NIOSH pocket guide to chemical hazards. Washington, DC: National Institute for Occupational Safety and Health, 4–5, 224–225.
NIOSH. 2019. Vinyl chloride. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0658.html. February 4, 2021.
Nivard MJ, Vogel EW. 1999. Genetic effects of exocyclic DNA adducts in vivo: heritable genetic damage in comparison with loss of heterozygosity in somatic cells. IARC Sci Publ 150(150):335–349.
NLM. 2023. PubChem: Vinyl chloride. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Vinyl-chloride. October 4, 2023.
Norpoth K, Heger M, Mueller G, . 1986. Investigations on metabolism genotoxic effects and carcinogenicity of 2,2-dichlorodiethyl ether. J Cancer Res Clin Oncol 112:125–130. 10.1007/BF00404394.3771621
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. March 24, 2021.
NTP. 2015. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program. PB2016102134. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2016102134.xhtml. October 3, 2022.
NTP. 2021. Vinyl halides (selected). In: Report on carcinogens. 15^th^ ed. National Toxicology Program, https://ntp.niehs.nih.gov/sites/default/files/ntp/roc/content/profiles/vinylhalides.pdf. July 19, 2023.
NTSB. 2023. Norfolk Southern Railway train derailment with subsequent hazardous material release and fires. National Transportation Safety Board. Preliminary Report: RRD23MR005. https://www.ntsb.gov/investigations/Pages/RRD23MR005.aspx. September 5, 2023.
Oesch F, Doerjer G. 1982. Detection of N2,3-ethanoguanine in DNA after treatment with chloroacetaldehyde in vitro. Carcinogenesis 3(6):663–665. 10.1093/carcin/3.6.663.7116560
Ojajarvi A, Partanen T, Ahlbom A, . 2001. Risk of pancreatic cancer in workers exposed to chlorinated hydrocarbon solvents and related compounds: a meta-analysis. Am J Epidemiol 153(9):841–850. 10.1093/aje/153.9.841.11323314
OSHA. 2021a. Occupational safety and health standards. Subpart Z: Vinyl chloride. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1017. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1017.pdf. July 19, 2023.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Toxic and hazardous substances. Vinyl chloride. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1017. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1017.pdf. July 19, 2023.
OSHA. 2021c. Safety and health regulations for construction. Toxic and Hazardous Substances. Vinyl chloride. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1117. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-1117.pdf. July 19, 2023.
Oster RH, Carr CJ, . 1947. Anesthesia; narcosis with vinyl chloride. Anesthesiology 8(4):359–361. 10.1097/00000542-194707000-00003.20255056
Osterman-Golkar S, Jultmark D, Segerback D, . 1977. Alkylation of DNA and proteins in mice exposed to vinyl chloride. Biochem Biophys Res Commun 76:259–266. 10.1016/0006-291X(77)90720-3.
Ostlere LS, Harris D, Buckley C, . 1992. Atypical systemic sclerosis following exposure to vinyl chloride monomer. A case report and review of the cutaneous aspects of vinyl chloride disease. Clin Exp Dermatol 17(3):208–210. 10.1111/j.1365-2230.1992.tb00210.x.1451305
Ott MG, Langer RR, Holder BB. 1975. Vinyl chloride exposure in a controlled industrial environment. A long-term mortality experience in 594 employees. Arch Environ Health 30(7):333–339. 10.1080/00039896.1975.10666716.1170818
Pan SY, Ugnat AM, Mao Y, . 2005. Occupational risk factors for brain cancer in Canada. J Occup Environ Med 47(7):704–717. 10.1097/01.jom.0000165747.95801.c5.16010197
Pan W, Yu S, Jia J, . 2021. Deregulation of the cell cycle and related microRNA expression induced by vinyl chloride monomer in the hepatocytes of rats. Toxicol Ind Health 37(6):365–376. 10.1177/07482337211015591.33973497
Pandya GA, Moriya M. 1996. 1,N6-ethenodeoxyadenosine, a DNA adduct highly mutagenic in mammalian cells. Biochemistry 35(35):11487–11492. 10.1021/bi960170h.8784204
Park KK, Liem A, Stewart BC, . 1993. Vinyl carbamate epoxide, a major strong electrophilic, mutagenic and carcinogenic metabolite of vinyl carbamate and ethyl carbamate (urethane). Carcinogenesis 14(3):441–450. 10.1093/carcin/14.3.441.8453720
Patty FA, Yapt WP, Waite CP. 1930. Acute response of guinea pigs to vapors of some new commercial organic compounds. V. Vinyl chloride. Public Health Rep 45:1963–1971. 10.2307/4581959.
Perry RA, Atkinson R, Pitts JN. 1977. Rate constants for the reaction of hydroxyl radicals with vinyl fluoride, vinyl chloride, and vinyl bromide over the temperature range 229-426 K. J Chem Phys 67:458 462.
Perticoni GF, Abbritti G, Cantisani TA, . 1986. Polyneuropathy in workers with long exposure to vinyl chloride. Electrophysiological study. Electromyogr Clin Neurophysiol 26(1):41–47.3017686
Peter S, Ungvary G. 1980. Lack of mutagenic effect of vinyl chloride monomer in the mammalian spot test. Mutat Res 77(2):193–196. 10.1016/0165-1218(80)90139-1.6990245
Pettit BR. 1986. The analysis of thiodiglycollic acid by selected ion monitoring. Clin Chim Acta 156(1):85–90. 10.1016/0009-8981(86)90182-8.3698320
Phelps TJ, Malachowsky K, Schram RM, . 1991. Aerobic mineralization of vinyl chloride by a bacterium of the order Actinomycetales. Appl Environ Microbiol 57(4):1252–1254. 10.1128/AEM.57.4.1252-1254.1991.1905522
Picciano DJ, Flake RE, Gay PC, . 1977. Vinyl chloride cytogenetics. J Occup Med 19(8):527–530.894374
Pirastu R, Comba P, Reggiani A, . 1990. Mortality from liver disease among Italian vinyl chloride monomer/polyvinyl chloride manufacturers. Am J Ind Med 17:155–161. 10.1002/ajim.4700170202.2154096
Plugge H, Safe S. 1977. Vinyl chloride metabolism - a review. Chemosphere 6:309–325.
Poncelet F, de Meester C, Duverger-van Bogaert M, . 1980. Influence of experimental factors on the mutagenicity of vinylic monomers. Arch Toxicol Suppl 4:63–66. 10.1007/978-3-642-67729-8_14.7002109
Popper H, Thomas LB. 1975. Alterations of liver and spleen among workers exposed to vinyl chloride. Ann NY Acad Sci 246:172–194. 10.1111/j.1749-6632.1975.tb51093.x 1054951
Popper H, Maltoni C, Selikoff IJ. 1981. Vinyl chloride-induced hepatic lesions in man and rodents. A comparison. Liver 1(1):7–20. 10.1111/j.1600-0676.1981.tb00018.x.6891014
Pottenger LH, Andrews LS, Bachman AN, . 2014. An organizational approach for the assessment of DNA adduct data in risk assessment: case studies for aflatoxin B1, tamoxifen and vinyl chloride. Crit Rev Toxicol 44(4):348–391. 10.3109/10408444.2013.873768.24494825
Pourquier P, Bjornsti MA, Pommier Y. 1998. Induction of topoisomerase I cleavage complexes by the vinyl chloride adduct 1,N6-ethenoadenine. J Biol Chem 273(42):27245–27249. 10.1074/jbc.273.42.27245.9765247
Poynter JN, Richardson M, Roesler M, . 2017. Chemical exposures and risk of acute myeloid leukemia and myelodysplastic syndromes in a population-based study. Int J Cancer 140(1):23–33. 10.1002/ijc.30420.27603749
Pratt GC, Palmer K, Wu CY, . 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825. 10.1289/ehp.00108815.11017885
Preston BJ, Jones KL, Grainger RG. 1976. Clinical aspects of vinyl chloride disease: Acro-osteolysis. Proc R Soc Med 69:284–306. 10.1177/003591577606900419.1265039
Prodan L, Suciu I, Pislaru V, . 1975. Experimental acute toxicity of vinyl chloride (monochloroethene). Ann N Y Acad Sci 246:154–158. 10.1111/j.1749-6632.1975.tb51090.x.1054948
Puentes Jacome LA, Wang PH, Molenda O, . 2019. Sustained dechlorination of vinyl chloride to ethene in dehalococcoides-enriched cultures grown without addition of exogenous vitamins and at low pH. Environ Sci Technol 53(19):11364–11374. 10.1021/acs.est.9b02339.31441646
Purchase IFH, Richardson CR, Anderson D. 1975. Chromosomal and dominant lethal effects of vinyl chloride. Lancet 306(7931):410–411. 10.1016/S0140-6736(75)92927-X.
Purchase IFH, Richardson CR, Anderson D, . 1978. Chromosomal analysis in vinyl chloride exposed workers. Mutat Res 57:325–334. 10.1016/0027-5107(78)90283-X.672932
Qiu YL, Wang W, Wang T, . 2008. Genetic polymorphisms, messenger RNA expression of p53, p21, and CCND1, and possible links with chromosomal aberrations in Chinese vinyl chloride-exposed workers. Cancer Epidemiol Biomarkers Prev 17(10):2578–2584. 10.1158/1055-9965.EPI-07-2925.18842998
Qiu YL, Wang W, Wang T, . 2011a. DNA repair gene polymorphisms and micronucleus frequencies in Chinese workers exposed to vinyl chloride monomer. Int J Hyg Environ Health 214(3):225–230. 10.1016/j.ijheh.2010.12.001.21216194
Qiu YL, Sun P, Wang W, . 2011b. Messenger RNA expression and genetic polymorphisms of cell cycle control genes and chromosomal aberrations in Chinese vinyl chloride monomer-exposed workers. J Occup Environ Med 53(12):1442–1446. 10.1097/JOM.0b013e3182363bfb.22076037
Qiu YL, Xu ZB, Wang Q, . 2019. Association between methylation of DNA damage response-related genes and DNA damage in hepatocytes of rats following subchronic exposure to vinyl chloride. Chemosphere 227:323–328. 10.1016/j.chemosphere.2019.04.058.30999172
Quan H, Ma T, Zhao X, . 2014. Vinyl chloride monomer (VCM) induces high occurrence of neural tube defects in embryonic mouse brain during neurulation. Cell Molec Neurobiol 34(4):619–630. 10.1007/s10571-014-0049-6.24664314
Radike MJ, Stemmer KL, Bingham E. 1981. Effect of ethanol on vinyl chloride carcinogenesis. Environ Health Perspect 41:59–62. 10.1289/ehp.814159.6277614
Rannug U, Johansson A, Ramel C, . 1974. The mutagenicity of vinyl chloride after metabolic activation. Ambio 3:194–197.
Rannug U, Gothe R, Wachtmeister CA. 1976. The mutagenicity of chloroethylene oxide, chloroacetaldehyde, 2-chloroethanol and chloroacetic acid, conceivable metabolites of vinyl chloride. Chem Biol Interact 12(3–4):251–263. 10.1016/0009-2797(76)90041-7.767010
Reitz RH, Gargas ML, Andersen ME, . 1996. Predicting cancer risk from vinyl chloride exposure with a physiologically based pharmacokinetic model. Toxicol Appl Pharmacol 137(2):253–267. 10.1006/taap.1996.0079.8661351
RePORTER. 2023. Vinyl chloride. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. March 24, 2021.
Reynolds ES, Jaeger RJ, Murphy SD. 1975a. Acute liver injury by vinyl chloride: involvement of endoplasmic reticulum in phenobarbital-pretreated rats. Environ Health Perspect 11:227–233. 10.1289/ehp.7511227.1175561
Reynolds ES, Moslen MT, Szabo S, . 1975b. Hepatotoxicity of vinyl chloride and 1,1-dichloroethylene. Role of mixed function oxidase system. Am J Pathol 81(1):219–236.241261
Richards PM, Ewald JM, Zhao W, . 2022. Natural biodegradation of vinyl chloride and cis-dichloroethene in aerobic and suboxic conditions. Environ Sci Pollut Res Int 29(37):56154–56167. 10.1007/s11356-022-19755-1.35322370
Richardson CR, Styles JA, Bennett IP. 1983. Activity of vinyl chloride monomer in the mouse micronucleus assay. Mutat Res 122(2):139–142. 10.1016/0165-7992(83)90051-9.6656803
Rinsky RA, Ott G, Ward E, . 1988. Study of mortality among chemical workers in the Kanawha Valley of West Virginia. Am J Ind Med 13:429–438. 10.1002/ajim.4700130403.3284337
Rioux KL, Delaney S. 2020. 1,N(6)-Ethenoadenine: From molecular to biological consequences. Chem Res Toxicol 33(11):2688–2698. 10.1021/acs.chemrestox.0c00326.33112144
Rodrigues EG, Herrick RF, Stewart J, . 2020. Case-control study of brain and other central nervous system cancer among workers at semiconductor and storage device manufacturing facilities. Occup Environ Med 77(4):238–248. 10.1136/oemed-2019-106120.32019845
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rosenman KD, Rizzo JE, Conomos MG, . 1989. Central nervous system malformations in relation to two polyvinyl chloride production facilities. Arch Environ Health 44(5):279–282. 10.1080/00039896.1989.9935894.2817959
Rossabi S, Choudoir M, Helmig D, . 2018. Volatile organic compound emissions from soil following wetting events. J Geophys Res Biogeosci 123(6):1988–2001. 10.1029/2018jg004514.
Ruckart PZ, Bove FJ, Maslia M. 2013. Evaluation of exposure to contaminated drinking water and specific birth defects and childhood cancers at Marine Corps Base Camp Lejeune, North Carolina: a case-control study. Environ Health 12:104. 10.1186/1476-069X-12-104.24304547
Ruiz P, Ray M, Fisher J, . 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Rusyn I, Arzuaga X, Cattley RC, . 2021. Key characteristics of human hepatotoxicants as a basis for identification and characterization of the causes of liver toxicity. Hepatology 74(6):3486–3496. 10.1002/hep.31999.34105804
Saad AAA, Mohsen MA, Kandil SM, . 2017. Predictive values of some atherogenic risk factors in young workers occupationally exposed to vinyl chloride and heavy metals. Arabian J Chem 10(1):100–108. 10.1016/j.arabjc.2014.01.003.
Sabadie N, Malaveille C, Camus AM, . 1980. Comparison of the hydroxylation of benzo(a)pyrene with the metabolism of vinyl chloride, N-nitrosomorpholine, and N-nitroso-N’methylpiperazine to mutagens by human and rat liver microsomal fractions. Cancer Res 409:119–126.
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manage Res 2:119–130. 10.1016/0734-242X(84)90135-6.
Saito T, Barbin A, Omori Y, . 1997. Connexin 37 mutations in rat hepatic angiosarcomas induced by vinyl chloride. Cancer Res 57(3):375–377.9012458
Sakabe H. 1975. Bone lesions among polyvinyl chloride production workers in Japan. Ann NY Acad Sci 246:78–79. 10.1111/j.1749-6632.1975.tb51082.x 1054972
Sakuratani Y, Kasai K, Noguchi Y, . 2007. Comparison of predictivities of Log P calculation models based on experimental data for 134 simple organic compounds. QSAR Comb Sci 26(1):109–116. 10.1002/qsar.200630019.
Salmon AG. 1976. Cytochrome P-450 and the metabolism of vinyl chloride. Cancer Lett 2(2):109–113. 10.1016/s0304-3835(76)80019-5.13927
Sal’nikova LS, Kotsovskaya IA. 1980. [Effect of vinyl chloride on embryogenesis of rats]. Gig Tr Prof Zabol 3:46–47. (Russian)
Saurin JC, Taniere P, Mion F, . 1997. Primary hepatocellular carcinoma in workers exposed to vinyl chloride: a report of two cases. Cancer 79(9):1671–1677. 10.1002/(sici)1097-0142(19970501)79:9<1671::aid-cncr6>3.0.co;2-f.9128981
Scarselli A, Corfiati M, Di Marzio D, . 2022. The impact of vinyl chloride exposure on the health of Italian workers: an evaluation from SIREP compliance data. Arch Environ Occup Health 77(5):372–381. 10.1080/19338244.2021.1900045.33739244
Scelo G, Constantinescu V, Csiki I, . 2004. Occupational exposure to vinyl chloride, acrylonitrile and styrene and lung cancer risk (Europe). Cancer Causes Control 15(5):445–452. 10.1023/B:CACO.0000036444.11655.be.15286464
Schaffner F. 1978. Effect of long-term vinyl chloride exposure in mouse liver structure. In: Remmer H, Bolt HM, Bannasch P, ., eds. Primary liver tumors: Proceedings of the 25^th^ Falk Symposium, on the occasion of the 5^th^ centennial celebrations of the Eberhard-Karls-Universität Tübingen held at the Schwartzwaldhotel Titisee, West Germany, October 3-5, 1977. Baltimore, MD: University Park Press, 189–199.
Schindler J, Li Y, Marion MJ, . 2007. The effect of genetic polymorphisms in the vinyl chloride metabolic pathway on mutagenic risk. J Hum Genet 52(5):448–455. 10.1007/s10038-007-0134-5.17384900
Schoental R, Magee PN. 1957. Chronic liver changes in rats after a single dose of lasiocarpine, a pyrrolizidine (Senecio) alkaloid. J Pathol Bacteriol 74(2):305–319. 10.1002/path.1700740208.
Schoental R, Magee PN. 1959. Further observations on the subacute and chronic liver changes in rats after a single dose of various pyrrolizidine (Senecio) alkaloids. J Pathol Bacteriol 78(2):471–482. 10.1002/path.1700780213.14443390
SERDP/ESTCP. 2012. Elucidation of the mechanisms and environmental relevance of cis-dichloroethene and vinyl chloride biodegradation. Alexandria, VA: Department of Defense Strategic Environmental Research and Development Program/Environmental Security Technology Certification Program. https://www.serdp-estcp.org/content/download/17268/193091/file/ER-1557-FR.pdf. March 24, 2021.
Serratrice J, Granel B, Pache X, . 2001. A case of polymyositis with anti-histidyl-t-RNA synthetase (Jo-1) antibody syndrome following extensive vinyl chloride exposure. Clin Rheumatol 20(5):379–382. 10.1007/s100670170032.11642524
Shahin MM. 1976. The non-mutagenicity and recombinogenicity of vinyl chloride in the absence of metabolic activation. Mutat Res 40:269–272. 10.1016/0165-1218(76)90053-7.785250
Sharma RP, Gehring PJ. 1979. Immunologic effects of vinyl chloride in mice. Ann N Y Acad Sci 320:551–563. 10.1111/j.1749-6632.1979.tb56633.x.287402
Sharma RP, Yakel HO, Gehring PJ. 1980. Immunotoxicologic studies with vinyl chloride in rabbits and mice. Int J Immunopharmacol 2(4):295–299. 10.1016/0192-0561(80)90029-6.7203747
Short RD, Minor JL, Winston JM, . 1977. A dominant lethal study in male rats after repeated exposures to vinyl chloride or vinylidene chloride. J Toxicol Environ Health 3(5–6):965–968. 10.1080/15287397709529630.599591
Shumate AM, Taylor J, McFarland E, . 2017. Medical response to a vinyl chloride release from a train derailment: New Jersey, 2012. Disaster Med Public Health Prep 11(5):538–544. 10.1017/dmp.2016.191.28260558
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. In: Scott D, Bridges BA, Sobels FH, eds. Progress in genetic toxicology: Proceedings of the second international conference on environmental mutagens; Edinburgh, July 11-15, 1977. Amsterdam, Netherlands: Elsevier/North Holland Biomedical Press, 249–258.
Simonato L, L’Abbe KA, Andersen A, . 1991. A collaborative study of cancer incidence and mortality among vinyl chloride workers. Scand J Work Environ Health 17(3):159–169.2068554
Singer B. 1996. DNA damage: chemistry, repair, and mutagenic potential. Regul Toxicol Pharmacol 23:2–13. 10.1006/rtph.1996.0002.8628915
Singer B, Hang B. 1999. Mammalian enzymatic repair of etheno- and para-benzoquinone exocyclic adducts derived from the carcinogens vinyl chloride and benzene. IARC Sci Publ 150(150):233–247.
Singer B, Spengler SJ, Chavez F, . 1987. The vinyl chloride-derived nucleoside, N2,3-ethenoguanosine, is a highly efficient mutagen in transcription. Carcinogenesis 8:745–747. 10.1093/carcin/8.5.745.3581434
Sinués B, Sanz A, Bernal ML, . 1991. Sister chromatid exchanges, proliferating rate index, and micronuclei in biomonitoring of internal exposure to vinyl chloride monomer in plastic industry workers. Toxicol Appl Pharmacol 108(1):37–45. 10.1016/0041-008x(91)90266-h.2006505
Smith LR, Dragun J. 1984. Degradation of volatile chlorinated aliphatic priority pollutants in groundwater. Environ Int 10:291–298. 10.1016/0160-4120(84)90134-X.
Smith SJ, Li Y, Whitley R, . 1998. Molecular epidemiology of p53 protein mutations in workers exposed to vinyl chloride. Am J Epidemiol 147(3):302–308. 10.1093/oxfordjournals.aje.a009450.9482505
Smits TH, Assal A, Hunkeler D, . 2011. Anaerobic degradation of vinyl chloride in aquifer microcosms. J Environ Qual 40(3):915–922. 10.2134/jeq2010.0403.21546677
Smulevich VB, Fedotova IV, Filatova VS. 1988. Increasing evidence of the rise of cancer in workers exposed to vinyl chloride. Br J Ind Med 45:93–97. 10.1136/oem.45.2.93.3342200
Soini Y, Welsh JA, Ishak KG, . 1995. p53 Mutations in primary hepatic angiosarcomas not associated with vinyl chloride exposure. Carcinogenesis 16(11):2879–2881. 10.1093/carcin/16.11.2879.7586214
Sokal JA, Baranski B, Majka J, . 1980. Experimental studies on the chronic toxic effects of vinyl chloride in rats. J Hyg Epidemiol Microbiol Immunol 24(3):285–294.
Spirtas R, McMichael AJ, Gamble J, . 1975. The association of vinyl chloride exposures with morbidity symptoms. Am Ind Hyg Assoc J 36(10):779–789. 10.1080/0002889758507339.1180211
Squillace PJ, Moran MJ, Price CV. 2004. VOCs in shallow groundwater in new residential/commercial areas of the United States. Environ Sci Technol 38(20):5327–5338. 10.1021/es0349756.15543733
SRI. 1990a. Vinyl chloride. In: 1990 Directory of chemical producers. Menlo Park, CA: SRI International, 1064.
SRI. 1990b. Vinyl chloride. In: 1990 Directory of chemical producers. Supplement. Menlo Park, CA: SRI International, 66.
SRI. 1993. Vinyl chloride. In: 1993 Directory of chemical producers. Menlo Park, CA: SRI International, 1006.
SRI. 1994. Vinyl chloride. In: 1994 Directory of chemical producers. Menlo Park, CA: SRI International, 994.
Staib F, Hussain SP, Hofseth LJ, . 2003. TP53 and liver carcinogenesis. Hum Mutat 21(3):201–216. 10.1002/humu.10176.12619106
Stallones RA. 1987. The use and abuse of subgroup analysis in epidemiological research. Prev Med 16:183–194. 10.1016/0091-7435(87)90082-X.3295858
Stephens RD, Ball NB, Mar DM. 1986. A multimedia study of hazardous waste landfill gas migration. In: Cohen Y, ed. Pollutants in a multimedia environment. New York, NY: Plenum Press, 265–287.
Suciu I, Drejman I, Valeskai M. 1963. [Investigation of the diseases caused by vinyl chloride]. Med Interna 15:967–977. (Spanish)
Suciu I, Prodan L, Ilea E, . 1975. Clinical manifestations in vinyl chloride poisoning. Ann N Y Acad Sci 246:53–69. 10.1111/j.1749-6632.1975.tb51080.x.1054970
Sugaya N, Inoue K, Tahara M, . 2023. Analysis and risk assessment of vinyl chloride emitted from aerosol products. J Environ Sci Health A Tox Hazard Subst Environ Eng 58(4):284–294. 10.1080/10934529.2023.2173925.36740968
Suzuki Y. 1978. Pulmonary tumors induced in mice by vinyl chloride monomer. Environ Res 16(1–3):285–301. 10.1016/0013-9351(78)90163-9.679916
Suzuki Y. 1980. Nonneoplastic effects of vinyl chloride in mouse lung. Environ Res 21(1):235–253. 10.1016/0013-9351(80)90026-2.7389703
Suzuki Y. 1981. Neoplastic and nonneoplastic effects of vinyl chloride in mouse lung. Environ Health Perspect 41:31–52. 10.1289/ehp.814131.7333244
Suzuki Y. 1983. Neoplastic effect of vinyl chloride in mouse lung-lower doses and short-term exposure. Environ Res 32(1):91–103. 10.1016/0013-9351(83)90195-0.6617622
Swartz MD, Cai Y, Chan W, . 2015. Air toxics and birth defects: a Bayesian hierarchical approach to evaluate multiple pollutants and spina bifida. Environ Health 14:16. 10.1186/1476-069X-14-16.25971584
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Swenberg JA, Fedtke N, Ciroussel F, . 1992. Etheno adducts formed in DNA of vinyl chloride-exposed rats are highly persistent in liver. Carcinogenesis 13(4):727–729. 10.1093/carcin/13.4.727.1576725
Swenberg JA, Bogdanffy MS, Ham A, . 1999. Formation and repair of DNA adducts in vinyl chloride- and vinyl fluoride-induced carcinogenesis. IARC Sci Publ 150(150):29–43.
Swenberg JA, Ham A, Koc H, . 2000. DNA adducts: effects of low exposure to ethylene oxide, vinyl chloride and butadiene. Mutat Res 464(1):77–86. 10.1016/s1383-5718(99)00168-0.10633179
Swenberg JA, Lu K, Moeller BC, . 2011. Endogenous versus exogenous DNA adducts: their role in carcinogenesis, epidemiology, and risk assessment. Toxicol Sci 120(Suppl 1):S130–145. 10.1093/toxsci/kfq371.21163908
Tabershaw IR, Gaffey WR. 1974. Mortality study of workers in the manufacture of vinyl chloride and its polymers. J Occup Med 16(8):509–518.4858414
Talbott EO, Marshall LP, Rager JR, . 2015. Air toxics and the risk of autism spectrum disorder: the results of a population based case-control study in southwestern Pennsylvania. Environ Health 14:80. 10.1186/s12940-015-0064-1.26444407
Tamburro CH, Makk L, Popper H. 1984. Early hepatic histologic alterations among chemical (vinyl monomer) workers. Hepatology 4:413–418. 10.1002/hep.1840040310.6539291
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
ten Berge WF. 1987. Incidence of cancer among vinylchloride and polyvinylchloride workers: Further evidence for an association with malignant melanoma. Br J Ind Med 44:718–719. 10.1136/oem.44.10.718.3676126
Teta MJ, Schnatter AR, Ott MG, . 1990. Mortality surveillance in a large chemical company: the Union Carbide Corporation experience, 1974-1983. Am J Ind Med 17(4):435–447. 10.1002/ajim.4700170403.2183596
Theriault G, Allard P. 1981. Cancer mortality of a group of Canadian workers exposed to vinyl chloride monomer. J Occup Med 23(10):671–676. 10.1097/00043764-198110000-00009.7299502
Theriault G, Iturra H, Gingras S. 1983. Evaluation of the association between birth defects and exposure to ambient vinyl chloride. Teratology 27:359–370. 10.1002/tera.1420270310.6879459
Thomas TL, Stewart PA, Stemhagen A, . 1987. Risk of astrocytic brain tumors associated with occupational chemical exposures. A case-referent study. Scand J Work Environ Health 13(5):417–423. 10.5271/sjweh.2024.2829348
Thornton SR, Schroeder RE, Robison RL, . 2002. Embryo-fetal developmental and reproductive toxicology of vinyl chloride in rats. Toxicol Sci 68(1):207–219. 10.1093/toxsci/68.1.207.12075123
Til HP, Immel HR, Feron VJ. 1983. Lifespan oral carcinogenicity study of vinyl chloride in rats. Final report. Civo Institutes; TNO. Report No. V 93.285/291099.
Til HP, Feron VJ, Immel HR. 1991. Lifetime (149-week) oral carcinogenicity study of vinyl chloride in rats. Food Chem Toxicol 29(10):713–718. 10.1016/0278-6915(91)90130-y.1959825
Torkelson TR, Oyen F, Rowe VK. 1961. The toxicity of vinyl chloride as determined by repeated exposure of laboratory animals. Am Ind Hyg Assoc J 22:354–361. 10.1080/00028896109343421.14042359
Towle KM, Benson SM, Egnot NS, . 2021. An ecological evaluation of vinyl chloride exposure and liver cancer incidence and mortality in Texas. J Clin Transl Hepatol 9(1):99–105. 10.14218/jcth.2020.00073.33604260
TRI21. 2023a. Vinyl chloride. TRI explorer: release reports. U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. July 10, 2023.
TRI21. 2023b. Vinyl chloride. TRI explorer: release trends report. U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.trends. July 10, 2023.
Trivers GE, Cawley HL, DeBenedetti VM, . 1995. Anti-p53 antibodies in sera of workers occupationally exposed to vinyl chloride. J Natl Cancer Inst 87(18):1400–1407. 10.1093/jnci/87.18.1400.7658501
U.S. Air Force. 1990. Development and validation of methods for applying pharmacokinetic data in risk assessment. Volume V of VII. Vinyl chloride. Wright-Patterson AFB, OH: U.S. Air Force. ADA237369. AAMRL-TR-90-072. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/ADA237369.xhtml. March 26, 2021.
Uche UI, Evans S, Rundquist S, . 2021. Community-level analysis of drinking water data highlights the importance of drinking water metrics for the state, federal environmental health justice priorities in the United States. Int J Environ Res Public Health 18(19):10401. 10.3390/ijerph181910401.34639699
Ungvary G, Hudak A, Tatrai E, . 1978. Effects of vinyl chloride exposure alone and in combination with trypan blue-applied systematically during all thirds of pregnancy on the fetuses of CFY rats. Toxicology 11:45–54. 10.1016/S0300-483X(78)90389-X.705803
USGS. 2006. Volatile organic compounds in the nation’s ground water and drinking-water supply wells. Reston, VA: U.S. Geological Survey. Circular 1292. https://pubs.usgs.gov/circ/circ1292/pdf/circular1292.pdf. March 24, 2021.
USGS. 2014. Anthropogenic organic compounds in source water of select community water systems in the United States, 2002-10. U.S. Geological Survey. PB2015101729. Scientific Investigations Report 2014-5139. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2015101729.xhtml. August 26, 2021.
USITC. 1994. Synthetic organic chemicals: United States production and sales; 1992. Washington, DC: United States International Trade Commission. USITC Publication 2720.
Vaglenov A, Lalchev S, Nosko M, . 1999. Chromosome aberrations and micronuclei in plastic industry workers exposed to vinyl chloride monomer. Cytogenet Cell Genet 85(1–2):103.
Veltman G, Lange CE, Juhe S, . 1975. Clinical manifestations and course of vinyl chloride disease. Ann N Y Acad Sci 246:6–17. 10.1111/j.1749-6632.1975.tb51076.x.123721
Verschueren K. 1983. Vinyl chloride. In: Handbook of environmental data on organic chemicals. 2^nd^ ed. New York, NY: Van Nostrand Reinhold Company, 1185–1186.
Victorin K, Stahlberg M. 1988. A method for studying the mutagenicity of some gaseous compounds in Salmonella typhimurium. Environ Mol Mutagen 11:65–77. 10.1002/em.2850110108.3276508
Vihko R, Vihko P, Maentausta O, . 1984. Assessment of early hepatotoxicity. In: Aitio A, Riihimaki V, Vainio J, eds. Biological monitoring and surveillance of workers exposed to chemicals. Washington, DC: Hemisphere Publishing Co., 309–313.
Viola PL. 1970. Pathology of vinyl chloride. Med Lav 61(3):147–180.5478991
Viola PL, Bigotti A, Caputo A. 1971. Oncogenic response of rat skin, lungs, and bones to vinyl chloride. Cancer Res 31(5):516–522.5582114
Voigt MD. 2005. Alcohol in hepatocellular cancer. Clin Liver Dis 9(1):151–169. 10.1016/j.cld.2004.10.003.15763234
Wackett LP, Brusseau GA, Householder SR, . 1989. Survey of microbial oxygenases: trichloroethylene degradation by propane-oxidizing bacteria. Appl Environ Microbiol 55(11):2960–2964. 10.1128/AEM.55.11.2960-2964.1989.2624467
Wagnerova M, Wagner V, Znojemska S, . 1988. Factors of humoral resistance in workers exposed to vinyl chloride with a view to smoking habits. J Hyg Epidemiol Microbiol Immunol 32(3):265–272.
Wahlang B, Hardesty JE, Head KZ, . 2020. Hepatic injury caused by the environmental toxicant vinyl chloride is sex-dependent in mice. Toxicol Sci 174(1):79–91. 10.1093/toxsci/kfz236.31774537
Walker AE. 1976. Clinical aspects of vinyl chloride disease: skin. Proc R Soc Med 69(4):286–289. 10.1177/003591577606900420.131318
Wallace LA, Pellizzari E, Hartwell T, . 1984. Personal exposure to volatile organic compounds. I. Direct measurements in breathing-zone air, drinking water, food, and exhaled breath. Environ Res 35(1):293–319. 10.1016/0013-9351(84)90137-3.6489295
Walles SA, Holmberg B, Svensson K, . 1988. Induction of single-strand breaks in liver DNA of mice after inhalation of vinyl chloride. IARC Sci Publ 89(89):227–231.
Walter RK, Lin PH, Edwards M, . 2011. Investigation of factors affecting the accumulation of vinyl chloride in polyvinyl chloride piping used in drinking water distribution systems. Water Res 45(8):2607–2615. 10.1016/j.watres.2011.02.016.21420710
Wang AH, Zhu SM, Qiu YL, . 2008. CYP2E1 mRNA expression, genetic polymorphisms in peripheral blood lymphocytes and liver abnormalities in Chinese VCM-exposed workers. Int J Occup Med Environ Health 21(2):141–146. 10.2478/v10001-008-0016-x.18715838
Wang Q, Ji F, Sun Y, . 2010a. Genetic polymorphisms of XRCC1, HOGG1 and MGMT and micronucleus occurrence in Chinese vinyl chloride-exposed workers. Carcinogenesis 31(6):1068–1073. 10.1093/carcin/bgq075.20378691
Wang W, Qiu YL, Ji F, . 2010b. Genetic polymorphisms in metabolizing enzymes and susceptibility of chromosomal damage induced by vinyl chloride monomer in a Chinese worker population. J Occup Environ Med 52(2):163–168. 10.1097/JOM.0b013e3181cac00b.20134343
Wang W, Qiu YL, Jiao J, . 2011. Genotoxicity in vinyl chloride-exposed workers and its implication for occupational exposure limit. Am J Ind Med 54(10):800–810. 10.1002/ajim.20990.21796658
Wang Q, Tan HS, Ma XM, . 2013a. Estimation of benchmark dose for micronucleus occurrence in Chinese vinyl chloride-exposed workers. Int J Hyg Environ Health 216(1):76–81. 10.1016/j.ijheh.2012.02.008.22425610
Wang Q, Tan HS, Zhang F, . 2013b. Polymorphisms in BER and NER pathway genes: effects on micronucleus frequencies among vinyl chloride-exposed workers in Northern China. Mutat Res 754(1–2):7–14. 10.1016/j.mrgentox.2013.03.007.23562908
Wang Q, Zhang L, Chen SQ, . 2019a. Role of endoplasmic reticulum stress and oxidative stress in vinyl chloride-induced hepatic steatosis in mice. Toxicol Appl Pharmacol 381:114730. 10.1016/j.taap.2019.114730.31445928
Wang CW, Liao KW, Chan CC, . 2019b. Association between urinary thiodiglycolic acid level and hepatic function or fibrosis index in school-aged children living near a petrochemical complex. Environ Pollut 244:648–656. 10.1016/j.envpol.2018.10.012.30384070
Ward AM. 1976. Clinical aspects of vinyl chloride disease: Evidence of an immune complex disorder in vinyl chloride workers. Proc R Soc Med 69:289–290. 10.1177/003591577606900421.131319
Ward E, Boffetta P, Andersen A, . 2001. Update of the follow-up of mortality and cancer incidence among European workers employed in the vinyl chloride industry. Epidemiology 12:710–718.11679801
Watanabe PG, Gehring PJ. 1976. Dose-dependent fate of vinyl chloride and its possible relationship to oncogenicity in rats. Environ Health Perspect 17:145–152. 10.1289/ehp.7617145.1026400
Watanabe PG, McGowan GR, Gehring PJ. 1976a. Fate of [14C]vinyl chloride after single oral administration in rats. Toxicol Appl Pharmacol 36(2):339–352. 10.1016/0041-008x(76)90013-2.1273852
Watanabe PG, McGowan GR, Madrid EO, . 1976b. Fate of [14C]vinyl chloride following inhalation exposure in rats. Toxicol Appl Pharmacol 37(1):49–59. 10.1016/s0041-008x(76)80007-5.968906
Watanabe PG, Zempel JA, Gehring PJ. 1978a. Comparison of the fate of vinyl chloride following single and repeated exposure in rats. Toxicol Appl Pharmacol 44(2):391–399. 10.1016/0041-008x(78)90199-0.675709
Watanabe PG, Zempel JA, Pegg DG, . 1978b. Hepatic macromolecular binding following exposure to vinyl chloride. Toxicol Appl Pharmacol 44(3):571–579. 10.1016/0041-008x(78)90265-x.684749
Watson WP, Aston JP, Barlow T, . 1999. Detection of 1,N6-etheno-2’-deoxyadenosine and 3,N4 etheno-2’-deoxycytidine occurring endogenously in DNA. IARC Sci Publ 150(150):63–73.
Waxweiler RJ, Stringer W, Wagner JK, . 1976. Neoplastic risk among workers exposed to vinyl chloride. Ann NY Acad Sci 271:40–48. 10.1111/j.1749-6632.1976.tb23091.x.1069531
Weber H, Reinl W, Greiser E. 1981. German investigations on morbidity and mortality of workers exposed to vinyl chloride. Environ Health Perspect 41:95–99. 10.1289/ehp.814195.7333247
Weihrauch M, Lehnert G, Kockerling F, . 2000. p53 Mutation pattern in hepatocellular carcinoma in workers exposed to vinyl chloride. Cancer 88(5):1030–1036. 10.1002/(SICI)1097-0142(20000301)88:5<1030::AID-CNCR12>3.0.CO;2-4.10699891
Weihrauch M, Benicke M, Lehnert G, . 2001a. Frequent K-ras-2 mutations and p16INK4A methylation in hepatocellular carcinomas in workers exposed to vinyl chloride. Br J Cancer 84(7):982 989. 10.1054/bjoc.2000.1675.11286481
Weihrauch M, Benick M, Lehner G, . 2001b. High prevalence of K-ras-2 mutations in hepatocellular carcinomas in workers exposed to vinyl chloride. Int Arch Occup Environ Health 74(6):405–410. 10.1007/s004200100244.11563603
Weihrauch M, Bader M, Lehnert G, . 2002. Mutation analysis of K-ras-2 in liver angiosarcoma and adjacent nonneoplastic liver tissue from patients occupationally exposed to vinyl chloride. Environ Mol Mutagen 40(1):36–40. 10.1002/em.10084.12211074
Wen-Bin M, Wei W, Yu-Lan Q, . 2009. Micronucleus occurrence related to base excision repair gene polymorphisms in Chinese workers occupationally exposed to vinyl chloride monomer. J Occup Environ Med 51(5):578–585. 10.1097/JOM.0b013e3181990d19.19369898
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76(5):52–59. 10.1002/j.1551-8833.1984.tb05334.x.
WHO. 1999. Environmental health criteria on vinyl chloride. Geneva, Switzerland: World Health Organization. http://www.inchem.org/pages/ehc.html. March 25, 2021.
WHO. 2000. Air quality guidelines for Europe, 2^nd^ edition. World Health Organization. https://apps.who.int/iris/handle/10665/107335. November 29, 2022.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.who.int/publications/i/item/9789289002134. July 16, 2023.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. July 16, 2023.
Whysner J, Conaway CC, Verna L, . 1996. Vinyl chloride mechanistic data and risk assessment: DNA reactivity and cross-species quantitative risk extrapolation. Pharmacol Ther 71(1–2):7–28. 10.1016/0163-7258(96)00060-5.8910947
Wilken JA, Graziano L, Vaouli E, . 2015. Exposures and symptoms among workers after an offsite train derailment and vinyl chloride release. Am J Disaster Med 10(2):153–165. 10.5055/ajdm.2015.0198.26312496
Williamson J, Kavanagh B. 1987. Vinyl chloride monomer and other contaminants in PVC welding fumes. Am Ind Hyg Assoc J 48(5):432–436. 10.1080/15298668791384995.3591663
Wilson RH, McCormick WE, Tatum CF, . 1967. Occupational acroosteolysis. Report of 31 cases. JAMA 201(8):577–581. 10.1001/jama.201.8.577.5006758
Wisniewska-Knypl JM, Klimczak J, Kolakowski J. 1980. Monooxygenase activity and ultrastructural changes of liver in the course of chronic exposure of rats to vinyl chloride. Int Arch Occup Environ Health 46(3):241–249. 10.1007/BF00380014.7450889
Withey JR. 1976. Pharmacodynamics and uptake of vinyl chloride monomer administered by various routes to rats. J Toxicol Environ Health 1:381–394. 10.1080/15287397609529338.1246084
Woldbaek T, Klaboe P. 1978. The photochemical reaction of vinyl chloride with oxygen studied by infrared spectroscopy. Spectrochim Acta 34(5):481–487. 10.1016/0584-8539(78)80043-9.
Wong O, Whorton MD. 1993. Letter to the editor. Diagnostic bias in occupational epidemiologic studies: An example based on the vinyl chloride literature. Am J Ind Med 24:251–256. 10.1002/ajim.4700240215.
Wong O, Whorton MD, Foliart DE, . 1991. An industry-wide epidemiologic study of vinyl chloride workers, 1942-1982. Am J Ind Med 20(3):317–334. 10.1002/ajim.4700200305.1928109
Wong RH, Wang JD, Hsieh LL, . 1998. Effects on sister chromatid exchange frequency of aldehyde dehydrogenase 2 genotype and smoking in vinyl chloride workers. Mutat Res 420(1–3):99–107. 10.1016/S1383-5718(98)00150-8.9838066
Wong RH, Chen PC, Du Cl, . 2002a. An increased standardized mortality ratio for liver cancer among polyvinyl chloride workers in Taiwan. Occup Environ Med 59:405–409. 10.1136/oem.59.6.405.12040117
Wong RH, Du CL, Wang JD, . 2002b. XRCC1 and CYP2E1 polymorphisms as susceptibility factors of plasma mutant p53 protein and anti-p53 antibody expression in vinyl chloride monomer-exposed polyvinyl chloride workers. Cancer Epidemiol Biomarkers Prev 11:475–482.12010862
Wong RH, Chen PC, Wang JD, . 2003a. Interaction of vinyl chloride monomer exposure and hepatitis B viral infection on liver cancer. J Occup Environ Med 45(4):379–383. 10.1097/01.jom.0000063622.37065.fd.12708141
Wong RH, Wang JD, Hsieh LL, . 2003b. XRCC1, CYP2E1 and ALDH2 genetic polymorphisms and sister chromatid exchange frequency alterations amongst vinyl chloride monomer-exposed polyvinyl chloride workers. Arch Toxicol 77(8):433–440. 10.1007/s00204-003-0467-6.12739102
WQP. 2021. Vinyl chloride. Water quality portal: 2011 to 2021 data. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. March 24, 2021.
WQP. 2023. Vinyl chloride. Water quality portal: 2022 to 2023 data. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. June 29, 2023.
Wu W, Steenland K, Brown D, . 1989. Cohort and case-control analyses of workers exposed to vinyl chloride: an update. J Occup Med 31(6):518–523. 10.1097/00043764-198906000-00007.2732815
Wu F, Liu J, Qiu YL, . 2013. Correlation of chromosome damage and promoter methylation status of the DNA repair genes MGMT and hMLH1 in Chinese vinyl chloride monomer (VCM)-exposed workers. Int J Occup Med Environ Health 26(1):173–182. 10.2478/s13382-013-0079-1.23412991
Xiao Z, Jiang W, Chen D, . 2020. Bioremediation of typical chlorinated hydrocarbons by microbial reductive dechlorination and its key players: A review. Ecotoxicol Environ Saf 202:110925. 10.1016/j.ecoenv.2020.110925.32800212
Yang X, Wang K, Xiao D, . 2000. Development of a fluorescent optode membrane for sodium ion based on the calix[4]arene and tetraphenylporphine. Talanta 52(6):1033–1039. 10.1016/s0039-9140(00)00469-0.18968064
Yoon M, Madden MC, Barton HA. 2007. Extrahepatic metabolism by CYP2E1 in PBPK modeling of lipophilic volatile organic chemicals: impacts on metabolic parameter estimation and prediction of dose metrics. J Toxicol Environ Health A 70(18):1527–1541. 10.1080/15287390701384684.17710613
Yuan TH, Chen JL, Shie RH, . 2020. Liver fibrosis associated with potential vinyl chloride and ethylene dichloride exposure from the petrochemical industry. Sci Total Environ 739:139920. 10.1016/j.scitotenv.2020.139920.32534314
Yun B, Guo J, Bellamri M, . 2020. DNA adducts: Formation, biological effects, and new biospecimens for mass spectrometric measurements in humans. Mass Spectrom Rev 39(1–2):55–82. 10.1002/mas.21570.29889312
Zalesak M, Ruzicka J, Vicha R, . 2021. Examining aerobic degradation of chloroethenes mixture in consortium composed of Comamonas testosteroni RF2 and Mycobacterium aurum L1. Chemosphere 269:128770. 10.1016/j.chemosphere.2020.128770.33139045
Zelko IN, Taylor BS, Das TP, . 2022. Effect of vinyl chloride exposure on cardiometabolic toxicity. Environ Toxicol 37(2):245–255. 10.1002/tox.23394.34717031
Zenzen V, Diekmann J, Gerstenberg B, . 2012. Reduced exposure evaluation of an electrically heated cigarette smoking system. Part 2: Smoke chemistry and in vitro toxicological evaluation using smoking regimens reflecting human puffing behavior. Regul Toxicol Pharmacol 64(2 Suppl):S11–S34. 10.1016/j.yrtph.2012.08.004.22922180
Zhang J, Hatakeyama S, Akimoto H. 1983. Rate constants of the reaction of ozone with trans-1,2-dichloroethene and vinyl chloride in air. Int J Chem Kinet 15(7):655–668. 10.1002/kin.550150707.
Zhang W, Rieger R, Iden C, . 1995. Synthesis of 3,N^4^-etheno, 3,N^4^-etheno and 3-(2-hydroxyetheyl) derivatives of 2’-deoxycytidine and their incorporation into oligomeric DNA. Chem Res Toxicol 8(1):148–156. 10.1021/tx00043a020.7703359
Zhao MY, Ying CJ, Shao N, . 1994. The study of health effects of vinyl chloride air pollution on population. Biomed Environ Sci 7(2):136–143.7946009
Zhao SF, Zhang XC, Zhang LF, . 1996. Application of the whole embryo culture system in screening industrial teratogens. Teratology 53(2):97.
Zheng GQ, Zhang GH, Xu XW, . 2017. Association of telomere length with chromosomal damage among Chinese workers exposed to vinyl chloride monomer. J Occup Environ Med 59(12):e252–e256. 10.1097/jom.0000000000001177.29215482
Zheng GQ, Zhang GH, Wu HT, . 2019. Relative telomere length and gene expression of shelterin complex proteins among vinyl chloride monomer-exposed workers in China. Environ Mol Mutagen 60(4):361–367. 10.1002/em.22270.30578676
Zhu S, Wang A, Xia Z. 2005b. Polymorphisms of DNA repair gene XPD and DNA damage of workers exposed to vinylchloride monomer. Int J Hyg Environ Health 208(5):383–390. 10.1016/j.ijheh.2005.05.002.16217922
Zhu SM, Ren XF, Wan JX, . 2005a. Evaluation in vinyl chloride monomer-exposed workers and the relationship between liver lesions and gene polymorphisms of metabolic enzymes. World J Gastroenterol 11(37):5821–5827. 10.3748/wjg.v11.i37.5821.16270392
Zhu SM, Xia ZL, Wang AH, . 2008. Polymorphisms and haplotypes of DNA repair and xenobiotic metabolism genes and risk of DNA damage in Chinese vinyl chloride monomer (VCM)-exposed workers. Toxicol Lett 178(2):88–94. 10.1016/j.toxlet.2008.02.009.18420361
Zielinski B, Hergenhahn M. 2001. 2-Chloroacetaldehyde induces εdA DNA adducts in DNA of Raji cells as demonstrated by an improved HPLC-fluorimetry method. Fresenius J Anal Chem 370(1):97–100. 10.1007/s002160100776.11393245