# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Rae T. Benedict, Ph.D. (Lead)
  Brittany Szafran, D.V.M., Ph.D.
  Kambria Haire, M.P.H., Ph.D.
  ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Julie Melia, Ph.D., D.A.B.T.
  Deborah Herber, Ph.D.
  Jenny S. Crisman, B.S.
  Parker Honey, B.S.
  Sabah Tariq, M.S.P.H.
  Christina Coley, M.S.
  Mario Citra, Ph.D.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Ivan Rusyn, MD, Ph.D.; University Professor; KC Donnelly Professor of Veterinary Integrative Biosciences; Chair, Interdisciplinary Faculty of Toxicology; Director, Superfund Research Center; Texas A&M University; College Station, Texas
2. Juliane Beier, Ph.D.; Assistant Professor; Department of Medicine; Division of Gastroenterology, Hepatology and Nutrition; Pittsburgh Liver Research Center; Department of Environmental and Occupational Health; University of Pittsburgh; Pittsburgh, Pennsylvania
3. Sa Liu, Ph.D., M.P.H., C.I.H.; Assistant Professor; School of Health Sciences; Purdue University; Fellow, Robert Wood Johnson Foundation; Interdisciplinary Research Leaders Cohort 5; Hampton Hall 1271; West Lafayette, Indiana

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.