# VERSION HISTORY

Date | Description
January 2024 | Final toxicological profile released
January 2023 | Draft for public comment toxicological profile released
July 2006 | Final toxicological profile released
September 1997 | Final toxicological profile released
April 1993 | Final toxicological profile released
August 1989 | Final toxicological profile released