# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding vinyl chloride in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1-3 and Appendix A for detailed information on the MRLs for vinyl chloride.

Table 7-1 Regulations and Guidelines Applicable to Vinyl Chloride

Agency | Description | Information | Reference
Air
EPA | RfC | 1×10^−1^ mg/m^3^ (0.04 ppm) | EPA 2000
WHO | Indoor air quality guidelines | No data | WHO 2010
WHO | Ambient air quality guidelines | | WHO 2000
WHO | 10^−6^ Cancer risk | 1 μg/m^3^
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018b
EPA | 1-Day health advisory (10-kg child) | 3 mg/L
EPA | 10-Day health advisory (10-kg child) | 3 mg/L
EPA | DWEL | 0.1 mg/L
EPA | 10^−4^ Cancer risk | 0.002 mg/L
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.002 mg/L
EPA | PHG | 0 mg/L
EPA | RfD | 3×10^−3^ mg/kg/day | EPA 2000
WHO | Drinking water quality guidelines | 0.0003 mg/L | WHO 2022
FDA | Substances Added to Food^a^ | Vinyl chloride monomer not listed | FDA 2022
FDA | Allowable level in bottled water | 0.002 mg/L | FDA 2017
Cancer
HHS | Carcinogenicity classification | Known to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification | Known human carcinogen by inhalation and oral exposure routes; highly likely human carcinogen by dermal exposure route | EPA 2000
EPA | Oral slope factor (continuous lifetime exposure during adulthood) | 7.2×10^−1^ per mg/kg/day
EPA | Oral slope factor (continuous lifetime exposure from birth) | 1.4 per mg/kg/day
IARC | Carcinogenicity classification | Group 1^b^ | IARC 2012
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 1 ppm | OSHA 2021a, 2021b, 2021c
OSHA | Ceiling PEL (15-minute TWA) for general industry, shipyards, and construction | 5 ppm
NIOSH | REL (up to 10-hour TWA) | No data^c^ | NIOSH 2019
Emergency Criteria
EPA | AEGLs-air | | EPA 2018c
EPA | AEGL 1^d^
EPA | 10-minute | 450 ppm
EPA | 30-minute | 310 ppm
EPA | 60-minute | 250 ppm
EPA | 4-hour | 140 ppm
EPA | 8-hour | 70 ppm
EPA | AEGL 2^d^
EPA | 10-minute | 2,800 ppm
EPA | 30-minute | 1,600 ppm
EPA | 60-minute | 1,200 ppm
EPA | 4-hour | 820 ppm
EPA | 8-hour | 820 ppm
EPA | AEGL 3^d^
EPA | 10-minute | 12,000 ppm^e^
EPA | 30-minute | 6,800 ppm^e^
EPA | 60-minute | 4,800 ppm^e^
EPA | 4-hour | 3,400 ppm
EPA | 8-hour | 3,400 ppm
DOE | PACs-air | | DOE 2015
DOE | PAC-1^f^ | 250 ppm
DOE | PAC-2^f^ | 1,200 ppm
DOE | PAC-3^f^ | 4,800 ppm^e^

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group 1: carcinogenic to humans.

c Potential occupational carcinogen.

d Definitions of AEGL terminology are available from EPA (2018d).

e Greater than or equal to 10% of the Lower Explosion Limit. Safety considerations against the hazard of explosion must be taken into account.

f Definitions of PAC terminology are available from DOE (2023).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; JECFA = Joint Food and Agriculture Organization/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; PHG = public health goal; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization