# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Vinyl chloride is a manmade substance. Information regarding the chemical identity of vinyl chloride is presented in Table 4-1. This information includes synonyms, chemical formula and structure, and identification numbers.

Table 4-1 Chemical Identity of Vinyl Chloride

Characteristic | Information | Reference
Chemical name | Vinyl chloride | NLM 2023
Synonym(s) and registered trade name(s) | Chloroethene; chloroethylene; 1-chloroethylene; ethylene monochloride; monovinyl chloride; monochloroethene; monochloroethylene; MVCs; Trovidur; VC; VCM; vinyl chloride monomer | Fire 1986; NLM 2023
Chemical formula | C_2_H_3_Cl | NLM 2023
SMILES | C=CCl | NLM 2023
Chemical structure | [image] | NLM 2023
CAS Registry Number | 75-01-4 | NLM 2023

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Vinyl chloride is a colorless, flammable gas with a sweet odor. It is heavier than air and will tend to accumulate at the bottom of vessels, rooms, or near ground levels. Information regarding the physical and chemical properties of vinyl chloride is in Table 4-2.

Table 4-2 Physical and Chemical Properties of Vinyl Chloride

Property | Information | Reference
Molecular weight | 62.5 | Lewis 1996
Color | Colorless | Budavari 1989
Physical state | Gas | Budavari 1989
Melting point | −153.8°C | Budavari 1989
Boiling point | −13.4°C | Cowfer and Gorensek 2006
Density:
at −14.2°C | 0.969 g/cm^3^ | Cowfer and Gorensek 2006
at 15°C | 0.9195 g/cm^3^ | Lewis 1996
at 20°C | 0.9106 g/cm^3^ | NIOSH 1986
Vapor density | 2.16 | Fire 1986
Odor | Sweet | NLM 2023
Odor threshold:
Water | 3.4 ppm | Amoore and Hautala 1983
Air | 3,000 ppm | Amoore and Hautala 1983
Taste threshold | No data
Solubility:
Water at 25°C | 2,763 mg/L | EPA 1985a
| 1,100 mg/L | Cowfer and Gorensek 2006
at 26°C | 8,800 mg/L | Delassus and Schmidt 1981
Organic solvent(s) | Soluble in hydrocarbons, oil, alcohol, chlorinated solvents, and most common organic liquids | Cowfer and Gorensek 2006
Partition coefficients:
Log K_ow_ | 1.38 | NIOSH 1986
| 1.46 | Sakuratani et al. 2007
Log K_oc_ | 2.38–2.95 | Lu et al. 2011
Vapor pressure:
at 20°C | 2,530 mmHg | Budavari 1989
at 25°C | 2,600 mmHg | Lewis 1996
Henry’s law constant:
10.3°C | 0.0147 (atm-m^3^)/mol | Gossett 1987
17.5°C | 0.0193 (atm-m^3^)/mol | Gossett 1987
24.8°C | 0.0278 (atm-m^3^)/mol | Gossett 1987
34.6°C | 0.0358 (atm-m^3^)/mol | Gossett 1987
Autoignition temperature | 472°C | Lewis 1996
Flashpoint | −78°C (closed cup) | Budavari 1989
Flammability limits | 3.6–33 volume % | NIOSH 1986
Conversion factors:
ppm to mg/m^3^ in air | 1 ppm=2.6 mg/m^3^ | NIOSH 1990
mg/m^3^ to ppm in air | 1 mg/m^3^=0.38 ppm | NIOSH 1990
Explosive limits | 4–22 volume % | Lewis 1996