# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR VINYL CHLORIDE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to vinyl chloride, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to vinyl chloride:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to vinyl chloride. The inclusion criteria used to identify relevant studies examining the health effects of vinyl chloride are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; Human; Laboratory mammals
Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data)
Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of vinyl chloride. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for vinyl chloride released for public comment in January 2023. See Appendix B for the databases searched and the search strategy.

A total of 517 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of vinyl chloride.

Title and Abstract Screen. In the Title and Abstract Screen step, 517 records were reviewed; 10 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 208 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 208 documents (234 studies), 77 documents (89 studies) were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Vinyl Chloride and overviews of the results of the inhalation and oral exposure studies (no dermal exposure studies were identified) are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1 and 2-2, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for vinyl chloride identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The available human studies evaluating noncancer effects examined a comprehensive set of endpoints for the inhalation route (no oral or dermal human studies were located). Occupational studies of inhalation exposure provide a thorough evaluation of respiratory, cardiovascular, hematological, musculoskeletal, hepatic, dermal, immunological, neurological, and developmental outcomes with health effects being observed for each outcome (except developmental). Animal inhalation studies examined a comprehensive set of endpoints, oral animal studies examined a limited number of health outcomes, and no dermal animal studies were available. Hepatic, immunological, neurological, developmental, and other noncancer (insulin resistance) effects were considered sensitive noncancer outcomes (i.e., effects were observed at low concentrations or doses). Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. Human studies that did not estimate exposure or include a comparison group (i.e., occupational health studies and case reports/series) were not included in the systematic review. Available cohort, case-control and cross-sectional studies were adequate for evaluating the sensitive health outcomes. There were 89 studies (published in 77 documents) examining these potential outcomes were carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Vinyl Chloride Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation studies
Cohort | 1 | 9 | 11 | 1 | 8 | 5 | 15 | | 5 | | 1 | 5 | 9 | 4 | 3 | | 49
Cohort | 1 | 6 | 10 | 1 | 6 | 5 | 14 | | 5 | | 1 | 5 | 9 | 4 | 0 | | 39
Case control | | 1 | 1 | | | | 5 | | | | | 4 | | | 5 | 1 | 11
Case control | | 1 | 1 | | | | 5 | | | | | 4 | | | 0 | 1 | 7
Population | | 1 | 3 | | | | 9 | 1 | | | | 6 | 3 | | 4 | 1 | 3
Population | | 0 | 3 | | | | 9 | 1 | | | | 6 | 3 | | 0 | 1 | 3
Case series | | 4 | 6 | 3 | 3 | 6 | 6 | | 8 | 4 | | 3 | 8 | | | | 12
Case series | | 4 | 6 | 3 | 2 | 6 | 6 | | 8 | 4 | | 2 | 8 | | | | 12
Oral studies
Cohort
Case control
Population
Case series
Dermal studies
Cohort
Case control
Population
Case series

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for Vinyl Chloride Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation studies
Acute-duration | 6 | 5 | 4 | 1 | 2 | 1 | 13 | 4 | | 2 | 1 | 2 | 9 | | 5 | | 1
Acute-duration | 1 | 5 | 2 | 0 | 2 | 0 | 7 | 3 | | | 0 | 0 | 7 | | 4 | | 1
Intermediate-duration | 18 | 1 | 4 | | 6 | 1 | 19 | 9 | 1 | | 1 | 6 | 2 | 5 | 2 | 4 | 11
Intermediate-duration | 3 | 1 | 1 | | 3 | 0 | 14 | 3 | 1 | | 0 | 3 | 0 | 3 | 2 | 1 | 11
Chronic-duration | 1 | 2 | 1 | | 1 | 1 | 1 | 2 | 1 | | 1 | | 3 | 1 | | | 12
Chronic-duration | 1 | 2 | 1 | | 1 | 1 | 1 | 2 | 1 | | 1 | | 2 | 1 | | | 12
Oral studies
Acute-duration
Intermediate-duration
Chronic-duration | 1 | 1 | | | 2 | | 2 | | 1 | | | | 1 | | | | 4
Chronic-duration | 0 | 1 | | | 1 | | 2 | | 1 | | | | 1 | | | | 4
Dermal studies
Acute-duration
Intermediate-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of vinyl chloride health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-8, C-9, and C-10, respectively.

Table C-8 Summary of Risk of Bias Assessment for Vinyl Chloride—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?* | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?* | Is there confidence in the outcome assessment?* | Were all measured outcomes reported? | Risk of bias tier
Outcome: Hepatic Effects
Inhalation—cohort
Fedeli et al. 2019a | + | + | + | + | ++ | ++ | Second
Mundt et al. 2017 | ++ | ++ | + | + | + | ++ | First
Hsieh et al. 2007 | + | ++ | + | + | ++ | ++ | First
Maroni and Fanetti 2006 | + | ++ | + | + | + | ++ | First
Zhu et al. 2005a | ++ | + | + | ++ | + | + | First
Hsiao et al. 2004 | + | ++ | + | + | ++ | ++ | First
Maroni et al. 2003 | + | ++ | + | + | + | ++ | First
Ward et al. 2001 | + | + | + | + | + | + | First
Inhalation—cross-sectional
Lee et al. 2020 | – | + | ++ | ++ | ++ | ++ | First
Yuan et al. 2020 | – | ++ | ++ | + | ++ | ++ | First
Wang et al. 2019b | + | ++ | + | + | ++ | ++ | First
Attarchi et al. 2007 | ++ | + | – | ++ | + | ++ | First
Cheng et al. 1999b | – | ++ | + | + | ++ | ++ | First
Du et al. 1995 | + | ++ | + | + | + | ++ | First
Tamburro et al. 1984 | + | – | + | + | + | + | Second
Vihko et al. 1984 | – – | – – | – | + | + | ++ | Second
NIOSH 1977 | + | + | – | + | + | ++ | Second
Inhalation—case-control
Cave et al. 2010 | ++ | – – | + | + | + | ++ | Second
Mastrangelo et al. 2004 | ++ | ++ | + | + | ++ | ++ | First
Du and Wang 1998 | + | – – | + | – | + | + | Second
Liss et al. 1985 | + | – – | – | – | + | + | Second
Outcome: Immunological Effects
Inhalation—cross-sectional
Saad et al. 2017 | ++ | – | + | – | + | + | Second
Fucic et al. 1998 | ++ | – | + | + | ++ | ++ | Second
Fucic et al. 1995 | ++ | – | + | + | + | – – | Second
Bencko et al. 1988 | – | – | + | – | + | + | Second
Wagnerova et al. 1988 | + | – | + | – | + | – | Second
Bogdanikowa and Zawilska 1984 | + | – | + | – | + | – | Second
Inhalation—case-control
Cave et al. 2010 | ++ | – – | + | + | ++ | ++ | Second
Black et al. 1983, 1986 | ++ | – | + | – | + | + | Second
Grainger et al. 1980 | + | – | + | – | + | + | Second
Outcome: Neurological Effects
Inhalation—cohort
Bove et al. 2014 | ++ | + | + | ++ | ++ | ++ | First
Zhu et al. 2005a | ++ | + | + | ++ | – | + | First
Inhalation—cross-sectional
Perticoni et al. 1986 | + | – | – | – | ++ | ++ | Second
NIOSH 1977 | + | + | – | – | + | ++ | Second
Spirtas et al. 1975 | + | + | – | + | + | + | First
Outcome: Developmental Effects
Inhalation—cohort
Bao et al. 1988 | + | – | + | + | + | – | Second
Inhalation—cross-sectional
Infante et al. 1976a, 1976b; NIOSH 1977 | + | + | – | – | + | ++ | Second
Inhalation—case-control
Swartz et al. 2015 | ++ | ++ | + | + | ++ | ++ | First
Talbott et al. 2015 | ++ | ++ | + | + | ++ | ++ | First
Ruckart et al. 2013 | + | + | + | + | + | ++ | First
Rosenman et al. 1989 | + | – | + | – | + | + | Second
Theriault et al. 1983 | + | – | + | – | – | + | Third
Edmonds et al. 1978 | + | – | + | – | + | + | Second
Inhalation—ecological
Infante 1976 | + | – | + | – | + | + | Second
Edmonds et al. 1975 | + | – | + | – | + | + | Second
Outcome: Other Noncancer (Insulin Resistance)
Inhalation—cross-sectional
Lee et al. 2020 | – | + | ++ | ++ | ++ | ++ | First
Inhalation—case-control
Cave et al. 2010 | ++ | – – | + | + | + | ++ | Second

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

Table C-9 Summary of Risk of Bias Assessment for Vinyl Chloride— Human-Controlled Exposure Studies

Reference | Risk of bias criteria and ratings | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance Bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were the research personnel and human subjects blinded to the study group during the study?* | Outcome data complete without attrition or exclusion from analysis? | Confidence in exposure characterization?* | Confidence in outcome assessment?* | All measured outcomes reported? | Risk of bias tier
Outcome: Neurological Effects
Inhalation
Lester et al. 1963 | ++ | | + | + | + | + | – | First
Patty et al. 1930 | – – | | – | + | + | + | – | Second

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

Table C-10 Summary of Risk of Bias Assessment for Vinyl Chloride—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Hepatic Effects
Inhalation acute-duration exposure
Jaeger et al. 1974 (rat; 1, 5 days) | – | – | + | + | – | – | + | ++ | NA | Second
John et al. 1977, 1981 (rat; 10 days) | – | – | + | + | ++ | – | + | ++ | NA | First
Mastromatteo et al. 1960 (rat; 30 minutes) | – | – | + | + | ++ | + | + | ++ | NA | First
Reynolds et al. 1975a (rat; 1, 5 days) | – | – | + | + | – | – | – | ++ | NA | Third
Reynolds et al. 1975b (rat; 1 day) | – | – | + | + | – | – | + | ++ | NA | Second
John et al. 1977, 1981 (mouse; 10 days) | – | – | + | + | ++ | – | + | ++ | NA | First
Mastromatteo et al. 1960 (mouse; 30 minutes) | – | – | + | + | ++ | + | + | ++ | NA | First
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | – | – | + | + | ++ | + | + | ++ | NA | First
John et al. 1977, 1981 (rabbit; 13 days) | – | – | + | + | ++ | – | + | ++ | NA | First
Ungvary et al. 1978 (rat; 7–9 days) | – | – | + | + | ++ | – | + | ++ | NA | First
Hehir et al. 1981 (rat; 1-hour) | – | – | + | + | + | – | + | ++ | NA | First
Inhalation intermediate-duration exposure
Bi et al. 1985 (rat; 3, 6 months) | + | + | + | + | + | ++ | + | ++ | NA | First
Jia et al. 2022 (mice; 13 weeks) | + | + | + | + | ++ | – | + | + | NA | First
Lester et al. 1963 (rat; 19 days) | – | – | ++ | + | + | ++ | + | ++ | NA | First
Lester et al. 1963 (rat; 92 days) | + | + | ++ | + | + | ++ | + | ++ | NA | First
Liu et al. 2023 (mice; 12 weeks) | – | – | + | + | ++ | – | + | + | NA | First
Sokal et al. 1980 (rat; 10 months) | – | – | ++ | + | – | ++ | + | ++ | NA | First
Thornton et al. 2002 (rat; 2-generation) | ++ | + | ++ | + | ++ | – | + | ++ | NA | First
Torkelson et al. 1961 (rat; 6 months) | – | – | ++ | + | + | + | + | ++ | NA | First
Wisniewska-Knypl et al. 1980 (rat; 10 months) | – | – | ++ | + | – | ++ | + | ++ | NA | First
Chen et al. 2019 (mouse; 12 weeks) | – | – | ++ | + | – | – | + | ++ | NA | Second
Lang et al. 2018 (mouse; 12 weeks) | – | – | ++ | + | – | – | + | ++ | NA | Second
Lang et al. 2020 (mouse; 12 weeks) | – | – | ++ | + | – | – | + | ++ | NA | Second
Schaffner 1978 (mouse; 6 months) | – | – | + | + | – | – | – | ++ | NA | Third
Sharma and Gehring 1979 (mouse; 2–8 weeks) | – | – | + | + | – | – | + | ++ | NA | Second
Wahlang et al. 2020 (mouse; 12 weeks) | – | – | ++ | + | – | – | + | ++ | NA | Second
Wang et al. 2019a (mouse; 16 weeks) | – | – | ++ | + | – | – – | + | ++ | NA | Second
Torkelson et al. 1961 (rabbit; 6 months) | – | – | ++ | + | + | + | + | ++ | NA | First
Du et al. 1979 (rat; 2–4 weeks) | + | + | ++ | + | – | – – | + | ++ | NA | First
Inhalation chronic-duration exposure
Bi et al. 1985 (rat; 12 months) | + | + | + | + | + | ++ | + | ++ | NA | First
Oral chronic-duration exposure
Til et al. 1983 (rat; 149 weeks) | ++ | + | ++ | + | ++ | ++ | + | ++ | NA | First
Feron et al. 1981 (rat; 2 years) | ++ | + | ++ | + | ++ | ++ | + | ++ | NA | First
Outcome: Immunological Effects
Inhalation acute-duration exposure
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | – | – | + | + | ++ | + | + | ++ | NA | First
Inhalation intermediate-duration exposure
Bi et al. 1985 (rat; 3, 6 months) | + | + | + | + | + | ++ | + | ++ | NA | First
Sharma and Gehring 1979 (mouse; 2–8 weeks) | – | – | + | + | – | – | + | ++ | NA | Second
Sharma et al. 1980 (rabbit; 8 weeks) | – | – | + | + | + | – | + | + | NA | First
Sokal et al. 1980 (rat; 10 months) | – | – | ++ | + | – | ++ | + | ++ | NA | Second
Outcome: Neurological Effects
Inhalation acute-duration exposure
Jaeger et al. 1974 (rat; 1, 5 days) | – | – | + | + | – | – | + | ++ | NA | Second
Lester et al. 1963 (rat; 2 hours) | – | – | ++ | + | + | ++ | – | ++ | NA | Third
Mastromatteo et al. 1960 (rat; 30 minutes) | – | – | + | + | ++ | + | + | ++ | NA | First
Hehir et al. 1981 (rat; 2 weeks) | – | – | + | + | + | – | + | ++ | NA | First
Hehir et al. 1981 (rat; 1 hour) | – | – | + | + | + | – | + | ++ | NA | First
Hehir et al. 1981 (mouse; 1 hour) | – | – | + | + | + | – | + | ++ | NA | First
Mastromatteo et al. 1960 (mouse; 30 minutes) | – | – | + | + | ++ | + | + | ++ | NA | First
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | – | – | + | + | ++ | + | + | ++ | NA | First
Patty et al. 1930 (guinea pig; up to 8 hours) | – | – | + | + | + | – | + | ++ | NA | First
Inhalation intermediate-duration exposure
Hehir et al. 1981 (rat; 20 weeks) | – | – | + | + | + | – | + | ++ | NA | First
Inhalation chronic-duration exposure
Viola 1970 (rat; 12 months) | – | – | – | + | + | – | + | ++ | NA | Second
Viola et al. 1971 (rat; 12 months) | – | – | + | + | + | + | + | ++ | NA | First
Feron and Kroes 1979 (rat; 12 months) | – | – | + | + | – | – | + | ++ | NA | Second
Outcome: Developmental Effects
Inhalation acute-duration exposure
Thornton et al. 2002 (rat; GDs 6–19) | ++ | + | ++ | + | ++ | – | + | + | NA | First
John et al. 1977, 1981 (rat; 10 days) | – | – | + | + | ++ | – | + | ++ | NA | First
John et al. 1977, 1981 (mouse; 10 days) | – | – | + | + | ++ | – | + | ++ | NA | First
John et al. 1977, 1981 (rabbit; 13 days) | – | – | + | + | ++ | – | + | ++ | NA | First
Ungvary et al. 1978 (rat; 7-9 days) | – | – | + | + | ++ | – | + | ++ | NA | First
Inhalation intermediate-duration exposure
Sal’nikova and Kotsovskaya 1980 (rat; 21 days) | – | – | + | + | – | – | + | ++ | NA | Second
Mirkova et al. 1978 | – | – | – | + | – | – | – | – | NA | Third
Outcome: Other Noncancer (Insulin Resistance)
Inhalation intermediate-duration exposure
Chen et al. 2019 (mouse; 12 weeks) | – | – | ++ | + | – | – | + | ++ | NA | Second
Lang et al. 2018 (mouse; 12 weeks) | – | – | ++ | + | – | + | + | ++ | NA | First
Wahlang et al. 2020 (mouse; 12 weeks) | – | – | ++ | + | – | – | + | ++ | NA | Second

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to vinyl chloride and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to vinyl chloride and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-11, C-12, and C-13, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-11 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-12 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-13 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining hepatic, immunological, neurological, developmental and other noncancer (insulin resistance) observed in the observational epidemiology, human controlled-exposure and animal experimental studies are presented in Tables C-14, C-15, and C-16, respectively.

Table C-14 Presence of Key Features of Study Design for Vinyl Chloride—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Hepatic effects
Inhalation—cohort
Fedeli et al. 2019a | No | Yes | Yes | Yes | Moderate
Mundt et al. 2017 | No | Yes | Yes | Yes | Moderate
Hsieh et al. 2007 | No | Yes | Yes | Yes | Moderate
Maroni and Fanetti 2006 | No | Yes | Yes | Yes | Moderate
Zhu et al. 2005a | No | Yes | Yes | Yes | Moderate
Hsiao et al. 2004 | No | Yes | Yes | Yes | Moderate
Maroni et al. 2003 | No | Yes | Yes | Yes | Moderate
Ward et al. 2001 | No | Yes | Yes | Yes | Moderate
Inhalation—cross-sectional
Lee et al. 2020 | No | No | Yes | Yes | Low
Yuan et al. 2020 | No | No | Yes | Yes | Low
Wang et al. 2019b | No | No | Yes | Yes | Low
Attarchi et al. 2007 | No | No | Yes | Yes | Low
Cheng et al. 1999b | No | No | Yes | Yes | Low
Du et al. 1995 | No | No | Yes | Yes | Low
Tamburro et al. 1984 | No | No | Yes | Yes | Low
Vihko et al. 1984 | No | No | Yes | No | Very low
NIOSH 1977 | No | No | Yes | Yes | Low
Inhalation—case-control
Cave et al. 2010 | No | Yes | Yes | Yes | Moderate
Mastrangelo et al. 2004 | No | Yes | Yes | Yes | Moderate
Du and Wang 1998 | No | Yes | Yes | Yes | Moderate
Liss et al. 1985 | No | Yes | Yes | Yes | Moderate
Outcome: Immunological effects
Inhalation—cross-sectional
Saad et al. 2017 | No | No | Yes | Yes | Moderate
Fucic et al. 1998 | No | No | Yes | Yes | Moderate
Fucic et al. 1995 | No | No | Yes | Yes | Moderate
Bencko et al. 1988 | No | No | Yes | Yes | Moderate
Wagnerova et al. 1988 | No | No | Yes | Yes | Moderate
Bogdanikowa and Zawilska 1984 | No | No | Yes | Yes | Moderate
Inhalation—case-control
Cave et al. 2010 | No | No | Yes | Yes | Low
Black et al. 1983, 1986 | No | Yes | Yes | Yes | Moderate
Grainger et al. 1980 | No | Yes | Yes | Yes | Moderate
Outcome: Neurological effects
Inhalation—cohort
Bove et al. 2014 | No | Yes | Yes | Yes | Moderate
Zhu et al. 2005a | No | Yes | Yes | Yes | Moderate
Inhalation—cross-sectional
Perticoni et al. 1986 | No | No | Yes | Yes | Low
NIOSH 1977 | No | No | Yes | Yes | Low
Spirtas et al. 1975 | No | No | Yes | Yes | Low
Outcome: Developmental effects
Inhalation—cohort
Bao et al. 1988 | No | Yes | Yes | Yes | Moderate
Inhalation—cross-sectional
Infante et al. 1976a, 1976b; NIOSH 1977 | No | No | Yes | Yes | Low
Inhalation—case-control
Swartz et al. 2015 | No | Yes | Yes | Yes | Moderate
Talbott et al. 2015 | No | Yes | Yes | Yes | Moderate
Ruckart et al. 2013 | No | Yes | Yes | Yes | Moderate
Rosenman et al. 1989 | No | Yes | Yes | Yes | Moderate
Theriault et al. 1983 | No | Yes | Yes | Yes | Moderate
Edmonds et al. 1978 | No | Yes | Yes | Yes | Moderate
Inhalation—ecological
Infante 1976 | No | Yes | Yes | Yes | Moderate
Edmonds et al. 1975 | No | Yes | Yes | Yes | Moderate
Other noncancer (insulin resistance)
Inhalation—cross-sectional
Lee et al. 2020 | No | No | Yes | Yes | Low
Inhalation—case-control
Cave et al. 2010 | No | Yes | Yes | Yes | Moderate

Table C-15 Presence of Key Features of Study Design for Vinyl Chloride—Human-Controlled Exposure Studies

Reference | Key features | | | | Initial study confidence
Reference | Comparison group | Sufficient number of subjects | Outcomes assessed with appropriate methods | Statistical analysis | Initial study confidence
Outcome: Neurological effects
Inhalation
Lester et al. 1963 | Yes | Yes | Yes | No | Moderate
Patty et al. 1930 | No | No | Yes | No | Very low

Table C-16 Presence of Key Features of Study Design for Vinyl Chloride—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Hepatic effects
Inhalation acute-duration exposure
Jaeger et al. 1974 (rat; 1, 5 days) | Yes | No | Yes | No | Low
John et al. 1977, 1981 (rat; 10 days) | Yes | Yes | Yes | Yes | High
Mastromatteo et al. 1960 (rat; 30 minutes) | Yes | Yes | Yes | No | Moderate
Reynolds et al. 1975a (rat; 1, 5 days) | No | No | Yes | No | Low
Reynolds et al. 1975b (rat; 1 day) | Yes | No | Yes | No | Low
John et al. 1977, 1981 (mouse; 10 days) | Yes | Yes | Yes | Yes | High
Mastromatteo et al. 1960 (mouse; 30 minutes) | Yes | Yes | Yes | No | Moderate
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | Yes | Yes | Yes | No | Moderate
John et al. 1977, 1981 (rabbit; 13 days) | Yes | Yes | Yes | Yes | High
Ungvary et al. 1978 (rat; 7–9 days) | Yes | Yes | Yes | Yes | High
Hehir et al. 1981 (rat; 1 hour) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate-duration exposure
Bi et al. 1985 (rat; 3, 6 months) | Yes | Yes | Yes | Yes | High
Jia et al. 2022 (mice; 13 weeks) | Yes | Yes | Yes | Yes | High
Lester et al. 1963 (rat; 19 days) | Yes | Yes | Yes | Yes | High
Lester et al. 1963 (rat; 92 days) | Yes | Yes | Yes | Yes | High
Liu et al. 2023 (mice; 12 weeks) | Yes | Yes | Yes | Yes | High
Sokal et al. 1980 (rat; 10 months) | Yes | Yes | Yes | Yes | High
Thornton et al. 2002 (rat; 2-generation) | Yes | Yes | Yes | Yes | High
Torkelson et al. 1961 (rat; 6 months) | Yes | Yes | Yes | Yes | High
Wisniewska-Knypl et al. 1980 (rat; 10 months) | Yes | Yes | Yes | Yes | High
Chen et al. 2019 (mouse; 12 weeks) | Yes | Yes | Yes | Yes | High
Lang et al. 2018 (mouse; 12 weeks) | Yes | Yes | Yes | Yes | High
Lang et al. 2020 (mouse; 12 weeks) | Yes | Yes | Yes | Yes | High
Schaffner 1978 (mouse; 6 months) | No | Yes | Yes | No | Low
Sharma and Gehring 1979 (mouse; 2–8 weeks) | Yes | No | Yes | Yes | Moderate
Wahlang et al. 2020 (mouse; 12 weeks) | Yes | No | Yes | Yes | Moderate
Wang et al. 2019a (mouse; 16 weeks) | Yes | Yes | Yes | Yes | High
Torkelson et al. 1961 (rabbit; 6 months) | Yes | No | Yes | Yes | Moderate
Du et al. 1979 (rat; 2–4 weeks) | Yes | No | Yes | Yes | Moderate
Inhalation chronic-duration exposure
Bi et al. 1985 (rat; 12 months) | Yes | Yes | Yes | Yes | High
Oral chronic-duration exposure
Til et al. 1983 (rat; 149 weeks) | Yes | Yes | Yes | Yes | High
Feron et al. 1981 (rat; 2 years) | Yes | Yes | Yes | Yes | High
Outcome: Immunological effects
Inhalation acute-duration exposure
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate-duration exposure
Bi et al. 1985 (rat; 3, 6 months) | Yes | Yes | Yes | Yes | High
Sharma and Gehring 1979 (mouse; 2–8 weeks) | Yes | No | Yes | Yes | Moderate
Sharma et al. 1980 (rabbit; 8 weeks) | Yes | Yes | Yes | Yes | High
Sokal et al. 1980 (rat; 10 months) | Yes | Yes | Yes | Yes | High
Outcome: Neurological effects
Inhalation acute-duration exposure
Jaeger et al. 1974 (rat; 1, 5 days) | Yes | No | Yes | No | Low
Lester et al. 1963 (rat; 2 hours) | No | No | Yes | No | Low
Mastromatteo et al. 1960 (rat; 30 minutes) | Yes | Yes | Yes | No | Moderate
Hehir et al. 1981 (rat; 2 weeks) | Yes | Yes | Yes | No | Moderate
Hehir et al. 1981 (rat; 1 hour) | Yes | Yes | Yes | No | Moderate
Hehir et al. 1981 (mouse; 1 hour) | Yes | Yes | Yes | No | Moderate
Mastromatteo et al. 1960 (mouse; 30 minutes) | Yes | Yes | Yes | No | Moderate
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | Yes | Yes | Yes | No | Moderate
Patty et al. 1930 (guinea pig; up to 8 hours) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate-duration exposure
Hehir et al. 1981 (rat; 20 weeks) | Yes | Yes | Yes | No | Moderate
Inhalation chronic-duration exposure
Viola 1970 (rat; 12 months) | Yes | Yes | Yes | No | Moderate
Viola et al. 1971 (rat; 12 months) | Yes | Yes | Yes | No | Moderate
Feron and Kroes 1979 (rat; 12 months) | Yes | Yes | Yes | No | Moderate
Outcome: Developmental effects
Inhalation acute-duration exposure
Thornton et al. 2002 (rat; GDs 6–19) | Yes | Yes | Yes | Yes | High
John et al. 1977, 1981 (rat; 10 days) | Yes | Yes | Yes | Yes | High
John et al. 1977, 1981 (mouse; 10 days) | Yes | Yes | Yes | Yes | High
John et al. 1977, 1981 (rabbit; 13 days) | Yes | Yes | Yes | Yes | High
Ungvary et al. 1978 (rat; 7–9 days) | Yes | Yes | Yes | Yes | High
Inhalation intermediate-duration exposure
Sal’nikova and Kotsovskaya 1980 (rat; 21 days) | Yes | Yes | Yes | Yes | High
Mirkova et al. 1978 (rat; 21 days) | Yes | Yes | Yes | Yes | High
Other noncancer (insulin resistance)
Inhalation intermediate-duration exposure
Chen et al. 2019 (mouse; 12 weeks) | Yes | Yes | Yes | Yes | High
Lang et al. 2018 (mouse; 12 weeks) | Yes | Yes | Yes | Yes | High
Wahlang et al. 2020 (mouse; 12 weeks) | Yes | No | Yes | Yes | Moderate

A summary of the initial confidence ratings for each outcome is presented in Table C-17. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-17.

Table C-17 Initial Confidence Rating for Vinyl Chloride Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Hepatic effects
Inhalation acute-duration exposure
Animal studies
Jaeger et al. 1974 (rat; 1, 5 days) | Low | High
John et al. 1977, 1981 (rat; 10 days) | High | High
Mastromatteo et al. 1960 (rat; 30 minutes) | Moderate | High
Reynolds et al. 1975a (rat; 1, 5 days) | Low | High
Reynolds et al. 1975b (rat; 1 day) | Low | High
John et al. 1977, 1981 (mouse; 10 days) | High | High
Mastromatteo et al. 1960 (mouse; 30 minutes) | Moderate | High
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | Moderate | High
John et al. 1977, 1981 (rabbit; 13 days) | High | High
Ungvary et al. 1978 (rat; 7–9 days) | High | High
Hehir et al. 1981 (rat; 1 hour) | Moderate | High
Inhalation intermediate-duration exposure
Animal studies
Bi et al. 1985 (rat; 3, 6 months) | High | High
Jia et al. 2022 (mice; 13 weeks) | High | High
Lester et al. 1963 (rat; 19 days) | High | High
Lester et al. 1963 (rat; 92 days) | High | High
Liu et al. 2023 (mice; 12 weeks) | High | High
Sokal et al. 1980 (rat; 10 months) | High | High
Thornton et al. 2002 (rat; 2-generation) | High | High
Torkelson et al. 1961 (rat; 6 months) | High | High
Wisniewska-Knypl et al. 1980 (rat; 10 months) | High | High
Chen et al. 2019 (mouse; 12 weeks) | High | High
Lang et al. 2018 (mouse; 12 weeks) | High | High
Lang et al. 2020 (mouse; 12 weeks) | High | High
Schaffner 1978 (mouse; 6 months) | Low | High
Sharma and Gehring 1979 (mouse; 2–8 weeks) | Moderate | High
Wahlang et al. 2020 (mouse; 12 weeks) | Moderate | High
Wang et al. 2019a (mouse; 16 weeks) | High | High
Torkelson et al. 1961 (rabbit; 6 months) | Moderate | High
Du et al. 1979 (rat; 2–4 weeks) | Moderate | High
Inhalation chronic-duration exposure
Human studies
NIOSH 1977 | Low | Moderate
Zhu et al. 2005a | Moderate | Moderate
Liss et al. 1985 | Moderate | Moderate
Tamburro et al. 1984 | Low | Moderate
Vihko et al. 1984 | Very low | Moderate
Du et al. 1995 | Low | Moderate
Cheng et al. 1999b | Low | Moderate
Ward et al. 2001 | Moderate | Moderate
Du and Wang 1998 | Moderate | Moderate
Mastrangelo et al. 2004 | Moderate | Moderate
Maroni et al. 2003 | Moderate | Moderate
Cave et al. 2010 | Moderate | Moderate
Hsieh et al. 2007 | Moderate | Moderate
Attarchi et al. 2007 | Low | Moderate
Maroni and Fanetti 2006 | Moderate | Moderate
Hsiao et al. 2004 | Moderate | Moderate
Mundt et al. 2017 | Moderate | Moderate
Fedeli et al. 2019a | Moderate | Moderate
Wang et al. 2019b | Low | Moderate
Lee et al. 2020 | Low | Moderate
Yuan et al. 2020
Animal studies
Bi et al. 1985 (rat; 12 months) | High | High
Oral chronic-duration exposure
Animal studies
Til et al. 1983 (rat; 149 weeks) | High | High
Feron et al. 1981 (rat; 2 years) | High | High
Outcome: Immunological effects
Inhalation acute-duration exposure
Animal studies
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | Moderate | Moderate
Inhalation intermediate-duration exposure
Animal studies
Bi et al. 1985 (rat; 3, 6 months) | High | High
Sharma and Gehring 1979 (mouse; 2–8 weeks) | Moderate | High
Sharma et al. 1980 (rabbit; 8 weeks) | High | High
Sokal et al. 1980 (rat; 10 months) | High | High
Inhalation chronic-duration exposure
Human studies
Cave et al. 2010 | Low | Moderate
Fucic et al. 1995 | Moderate | Moderate
Fucic et al. 1998 | Moderate | Moderate
Wagnerova et al. 1988 | Moderate | Moderate
Bogdanikowa and Zawilska 1984 | Moderate | Moderate
Grainger et al. 1980 | Moderate | Moderate
Black et al. 1983, 1986 | Moderate | Moderate
Saad et al. 2017 | Moderate | Moderate
Bencko et al. 1988 | Moderate | Moderate
Outcome: Neurological effects
Inhalation acute-duration exposure
Human studies
Patty et al. 1930 | Very low | Moderate
Lester et al. 1963 | Moderate | Moderate
Animal studies
Jaeger et al. 1974 (rat; 1, 5 days) | Low | Moderate
Lester et al. 1963 (rat; 2 hours) | Low | Moderate
Mastromatteo et al. 1960 (rat; 30 minutes) | Moderate | Moderate
Hehir et al. 1981 (rat; 2 weeks) | Moderate | Moderate
Hehir et al. 1981 (rat; 1 hour) | Moderate | Moderate
Hehir et al. 1981 (mouse; 1 hour) | Moderate | Moderate
Mastromatteo et al. 1960 (mouse; 30 minutes) | Moderate | Moderate
Mastromatteo et al. 1960 (guinea pig; 30 minutes) | Moderate | Moderate
Patty et al. 1930 (guinea pig; up to 8 hours) | Moderate | Moderate
Inhalation intermediate-duration exposure
Animal studies
Hehir et al. 1981 (rat; 20 weeks) | Moderate | Moderate
Inhalation chronic-duration exposure
Human studies
NIOSH 1977 | Low | Moderate
Zhu et al. 2005a | Moderate | Moderate
Spirtas et al. 1975 | Low | Moderate
Perticoni et al. 1986 | Low | Moderate
Bove et al. 2014 | Moderate | Moderate
Animal studies
Viola 1970 (rat; 12 months) | Moderate | Moderate
Viola et al. 1971 (rat; 12 months) | Moderate | Moderate
Feron and Kroes 1979 (rat; 12 months) | Moderate | Moderate
Outcome: Developmental effects
Inhalation acute-duration exposure
Animal studies
Thornton et al. 2002 (rat; GDs 6–19) | High | High
John et al. 1977, 1981 (rat; 10 days) | High | High
John et al. 1977, 1981 (mouse; 10 days) | High | High
John et al. 1977, 1981 (rabbit; 13 days) | High | High
Ungvary et al. 1978 (rat; 7–9 days) | High | High
Inhalation intermediate-duration exposure
Human studies
Swartz et al. 2015 | Moderate | Moderate
Talbott et al. 2015 | Moderate | Moderate
Ruckart et al. 2013 | Moderate | Moderate
Animal studies
Sal’nikova and Kotsovskaya 1980 (rat; 21 days) | High | High
Mirkova et al. 1978 (rat; 21 days) | High | High
Inhalation chronic-duration exposure
Human studies
NIOSH 1977 | Low | Moderate
Edmonds et al. 1975, 1978 | Moderate | Moderate
Infante 1976 | Moderate | Moderate
Rosenman et al. 1989 | Moderate | Moderate
Theriault et al. 1983 | Moderate | Moderate
Infante et al. 1976a, 1976b | Low | Moderate
Bao et al. 1988 | Moderate | Moderate
Outcome: Other noncancer (insulin resistance)
Inhalation intermediate-duration exposure
Animal studies
Chen et al. 2019 (mouse; 12 weeks) | High | High
Lang et al. 2018 (mouse; 12 weeks) | High | High
Wahlang et al. 2020 (mouse; 12 weeks) | Moderate | High
Inhalation chronic-duration exposure
Human studies
Lee et al. 2020 | Low | Moderate
Cave et al. 2010 | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for hepatic, immunological, neurological, developmental, and other noncancer (insulin resistance) effects are presented in Table C-18. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with vinyl chloride exposure is presented in Table C-19.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8, C-9, and C-10). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% confidence intervals (CIs) for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Table C-18 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Hepatic
Human studies | Moderate | +1 consistency | High
Animal studies | High | −1 inconsistency | Moderate
Outcome: Immunological
Human studies | Moderate | −1 risk of bias, +1 consistency | Moderate
Animal studies | High | −1 inconsistency, −1 indirectness | Low
Outcome: Neurological
Human Studies | Moderate | None | Moderate
Animal Studies | Moderate | None | Moderate
Outcome: Developmental
Human studies | Moderate | −1 risk of bias | Low
Animal studies | High | None | High
Outcome: Other noncancer (insulin resistance)
Human studies | Moderate | −1 indirectness | Low
Animal studies | High | −1 risk of bias | Moderate

Table C-19 Confidence in the Body of Evidence for Vinyl Chloride

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Hepatic | High | Moderate
Immunological | Moderate | Low
Neurological | Moderate | Moderate
Developmental | Low | High
Other Noncancer (Insulin resistance) | Low | Moderate

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for vinyl chloride, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for vinyl chloride is presented in Table C-20.

Table C-20 Level of Evidence of Health Effects for Vinyl Chloride

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Hepatic | High | Health effect | High
Immunological | Moderate | Health effect | Moderate
Neurological | Moderate | Health effect | Moderate
Developmental | Low | No health effect | Inadequate
Other noncancer (insulin resistance) | Low | Health effect | Low
Animal studies
Hepatic | Moderate | Health effect | Moderate
Immunological | Low | No health effect | Inadequate
Neurological | Moderate | Health effect | Moderate
Developmental | High | Health effect | High
Other noncancer (insulin resistance) | Moderate | No health effect | Inadequate

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1 description

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for vinyl chloride are listed below and summarized in Table C-21.

### Presumed Health Effects

- Hepatic
  ○ High level of evidence of hepatic effects in humans based on fibrosis, cirrhosis, and steatosis observed in vinyl chloride workers (Cave et al. 2010; Du and Wang 1998; Fedeli et al. 2019a; Hsiao et al. 2004; Hsieh et al. 2007; Maroni et al. 2003; Mastrangelo et al. 2004; Mundt et al. 2017; Ward et al. 2001; Yuan et al. 2020).
  ○ Moderate evidence level in animals including increased liver weight and histopathological liver lesions in rats and mice following inhalation (Bi et al. 1985; Jia et al. 2022; Lester et al. 1963; Sokal et al. 1980; Thornton et al. 2002; Torkelson et al. 1961; Wisniewska-Knypl et al. 1980) and oral exposure (Feron et al. 1981; Til et al. 1983, 1991).
- Neurological
  ○ Moderate level of evidence in humans based on neurological symptoms reported in human studies (Lester et al. 1963; NIOSH 1977; Patty et al. 1930; Spirtas et al. 1975; Zhu et al. 2005a) and a single report of peripheral neuropathy (Perticoni et al. 1986).
  ○ Moderate level of evidence in animals based on clinical signs in multiple acute-duration inhalation studies (Hehir et al. 1981; Jaeger et al. 1974; Lester et al. 1963; Mastromatteo et al. 1960; Patty et al. 1930)

### Suspected Health Effects

- Immunological
  ○ Moderate level of evidence in humans based on occupational worker studies demonstrating an increase in circulating immune complexes, immunoglobulins, complement factors, and levels of inflammatory cytokines (Bencko et al. 1988, Bogdanikowa and Zawilska 1984; Cave et al. 2010; Grainger et al. 1980; Saad et al. 2017; Wagnerova et al. 1988; Ward 1976).
  ○ Inadequate evidence in animals due to limited information available on increased spleen weight in rats (Bi et al. 1985; Sokal et al. 1980) and a splenic lymphocyte proliferation assay in mice and rabbits (Sharma and Gehring 1979, Sharma et al. 1980)
- Developmental
  ○ Inadequate evidence in humans due to the absence of demonstrated developmental effects in a small number of ecological and case-control studies of birth defects (Edmonds et al. 1978; Infante 1976; Infante et al. 1976a, 1976b; NIOSH 1977; Rosenman et al. 1989; Ruckart et al. 2013; Swartz et al. 2015; Talbott et al. 2015; Theriault et al. 1983).
  ○ High level of evidence in animals based on developmental effects occurring at low concentrations in inhalation studies (John et al. 1977, 1981).

### Not Classifiable

- Other noncancer (insulin resistance)
  ○ Low level of evidence level in humans based on two epidemiology studies with serum markers of increased insulin resistance (Cave et al. 2010; Lee et al. 2020).
  ○ Several intermediate-duration inhalation studies using glucose, insulin, and pyruvate tolerance tests (Chen et al. 2019; Lang et al. 2018) and measures of fasting blood glucose and glycogen storage (Wahlang et al. 2020). These studies used a single low concentration of vinyl chloride (0.85 ppm) and did not evaluate effects at higher concentrations.

Table C-21 Hazard Identification Conclusions for Vinyl Chloride

Outcome | Hazard identification
Hepatic | Presumed health effect
Immunological | Suspected health effect
Neurological | Presumed health effect
Developmental | Suspected health effect
Other noncancer (insulin resistance) | Not classifiable