# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Vinyl chloride Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl chloride
CAS Numbers: | 75-01-4
Date: | January 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.5 ppm; 1.3 mg/m^3^
Critical Effect: | Delayed ossification
References: | John et al. 1977, 1981
Point of Departure: | NOAEL of 50 ppm; NOAEL_HEC_ = 15 ppm
Uncertainty Factor: | 30
LSE Graph Key: | 14
Species: | Mouse

MRL Summary: An acute-duration inhalation MRL of 0.5 ppm (1.3 mg/m^3^) was derived for vinyl chloride based on a developmental endpoint of delayed ossification NOAEL of 50 ppm and a LOAEL of 500 ppm for mice administered vinyl chloride for 7 hours/day on GDs 6–15 (John et al. 1977, 1981). The inhalation concentration of 50 ppm was duration adjusted (NOAEL_ADJ_) to a continuous exposure of 15 ppm. The partition coefficient in mice is greater than that in humans; therefore, a default value of 1 is used for the ratio resulting in a NOAEL_HEC_ of 15 ppm. The NOAEL_HEC_ of 15 ppm was divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available data indicate that developmental effects are the most sensitive target for toxic effects following acute-duration inhalation exposure to vinyl chloride (Table A-1). Delayed ossification was observed in both mice and rabbits at 500 ppm, which is the lowest LOAEL identified for developmental effects (John et al. 1977, 1981). The mouse study included a lower concentration (50 ppm), which was a NOAEL. Exposure of pregnant rats to 2,500 ppm 7 hours/day over GDs 6–15 resulted in ureter dilatation in the offspring (John et al. 1977, 1981).

Relative kidney weight was increased by 20% in pregnant rats exposed to ≥100 ppm vinyl chloride 6 hours/day on GDs 6–19 (Thornton et al. 2002). This endpoint was not chosen as the basis of the acute-duration inhalation MRL because absolute kidney weights were similar to controls and no other parameters were available to evaluate the potential for renal toxicity (i.e., no clinical chemistry, urinalysis, or histopathology data). A number of studies in animals identified acute-duration LOAELs for frank narcosis and severe lung, liver, and kidney damage following exposures of 10,000–400,000 ppm of vinyl chloride (Table 2-1).

Table A-1 Summary of Candidate Critical Effects for Acute-Duration Inhalation MRL for Vinyl Chloride

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Developmental effects^a^
Rat (Sprague-Dawley) | GDs 6–15; 10 days; 7 hours/day | 500 | 2,500 | Ureter dilatation (developmental) | John et al. 1977, 1981
Mouse (CF-1) | GDs 6–15; 10 days; 7 hours/day | 50 | 500 | Delayed ossification | John et al. 1977, 1981
Rabbit (New Zealand) | GDs 6–18; 13 days; 7 hours/day | ND | 500 | Delayed ossification | John et al. 1977, 1981
Hepatic effects
Rat (Sprague-Dawley) | GDs 6–15; 10 days; 7 hours/day | 500 | 2,500 | 9 and 10% increase in absolute and relative liver weight, respectively | John et al. 1977, 1981
Renal effects
Rat (Sprague-Dawley) | GDs 6–19; 4–6 hours/day | 10 | 100 | 20% increase in relative kidney weight | Thornton et al. 2002

a Selected critical effect.

GD = gestational day; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no -observed-adverse-effect level

Selection of the Principal Study: The study by John et al. (1977, 1981) was selected as the principal study for the derivation of an acute-duration inhalation MRL based on the NOAEL of 50 ppm for delayed ossification. This study identified the lowest LOAEL for developmental endpoints (500 ppm).

Summary of the Principal Study:

John JA, Smith FA, Leong BKJ, . 1977. The effects of maternally inhaled vinyl chloride on embryonal and fetal development in mice, rats, and rabbits. Toxicol Appl Pharmacol 39:497–513.854925

John JA, Smith FA, Schwetz BA. 1981. Vinyl chloride: Inhalation teratology study in mice, rats, and rabbits. Environ Health Perspect 41:171–177.7333235

CF-1 mice (19–26 per group) were exposed to vinyl chloride at concentrations of 0, 50, or 500 ppm for 7 hours/day on GDs 6–15 (John et al. 1977, 1981). Concurrent control groups (47 animals total) were used, one for each dose level. Control groups were sham-exposed to filtered room air. Whole body exposure was conducted in chambers of 3.7 m^3^ volume under dynamic conditions. Animals were observed daily for clinical signs, and maternal body weights were measured several times during gestation. Animals were euthanized on GD 18 by carbon dioxide inhalation. Maternal liver weight was measured and uterine horns were examined. Fetuses were weighed, measured (crown-rump length), sexed, and subjected to gross and histopathological examinations.

No adverse maternal or fetal effects were noted at 50 ppm, with the exception of a slight increase in crown-rump length that was not observed at 500 ppm. Maternal body weight gain decreased along with food consumption at 500 ppm. At 500 ppm, delayed ossification of the skull and sternebrae was observed. The increase in resorptions at 500 ppm was considered to have been within historical control limits. Significant changes in the percentage of implantations resorbed, litter size, and fetal body weight would not have been observed at 500 ppm if comparison had been made to the other control group (the sham-exposed group for the 50-ppm concentration). There was frank maternal toxicity at 500 ppm (17% death). The data for delayed ossification are not amenable to benchmark dose (BMD) modeling, because only one of two dose groups showed a response that was different from controls. A LOAEL of 500 ppm and a NOAEL of 50 ppm were identified based on delayed ossification in fetuses.

Selection of the Point of Departure for the MRL: The NOAEL of 50 ppm was selected as the POD.

Adjustment for Intermittent Exposure: The intermittent exposure duration of 7 hours/day was duration-adjusted (NOAEL_ADJ_) to continuous exposure according to the following equation:

NOAEL_ADJ_ = NOAEL ( 50 ppm ) × 7 hours / 24 hours per day = 14.58 ppm .

Human Equivalent Concentration: Following EPA (1994) methodology, the human equivalent concentration (NOAEL_HEC_) for an extrarespiratory effect produced by a category 3 gas, such as vinyl chloride, is calculated by multiplying the duration-adjusted animal NOAEL by the ratio of the blood:gas partition coefficients in animals and humans ([H_b/g_]_A_ / [H_b/g_]_H_). Since the partition coefficient in mice is greater than that in humans a default value of 1 is used for the ratio resulting in a NOAEL_HEC_ of 14.58 ppm.

Uncertainty Factor: The NOAEL_HEC_ was divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustment
- 10 for human variability

MRL = NOAEL_HEC_ ÷ ( UF ) 14.58 ppm ÷ ( 3 × 10 ) = 0.486 ppm ≈ 0.5 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Delayed ossification (500 ppm, the lowest concentration tested) was the only developmental effect observed in a rabbit developmental study (John et al. 1977, 1981).

Agency Contacts (Chemical Managers): Rae Benedict

## Vinyl chloride Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl chloride
CAS Numbers: | 75-01-4
Date: | January 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.02 ppm; 0.05 mg/m^3^
Critical Effect: | Increased incidence of centrilobular hypertrophy
Reference: | Thornton et al. 2002
Point of Departure: | BMCL_10_: 2.05 ppm (BMCL_HEC_: 0.5 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 28
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.02 ppm (0.05 mg/m^3^) was derived for vinyl chloride based on the benchmark concentration lower confidence limit 10% (BMCL_10_) of 2.05 ppm for the increased incidence of centrilobular hypertrophy of the liver in F1 female rats exposed for 16–19 weeks, including exposure during gestation and lactation (Thornton et al. 2002). The BMCL_10_ was adjusted to continuous duration exposure and converted to a human equivalent concentration (BMCL_10HEC_) of 0.5125 ppm. A total uncertainty factor of 30 (3 for species extrapolation using a dosimetric conversion and 10 for human variability) was applied to the BMCL_10HEC_ to derive the MRL of 0.02 ppm.

Selection of the Critical Effect: No dose-response data are available for humans. Available data indicate that the liver is the most sensitive endpoint for toxic effects following intermediate-duration inhalation exposure to vinyl chloride (Table A-2). Liver effects observed at the lowest LOAEL concentration of approximately 10 ppm include increased liver weight (Bi et al. 1985; Thornton et al. 2002) and centrilobular hypertrophy (Thornton et al. 2002). Fatty liver changes were also observed in two studies of rats exposed to 50 ppm for 10 months (Sokal et al. 1980; Wisniewska-Knypl et al. 1980) and one study in mice exposed to 286.7 ppm for 16 weeks (Wang et al. 2019a). Centrilobular degeneration and necrosis was observed in rabbits exposed to 200 ppm for 6 months (Torkelson et al. 1961). Adverse histopathological changes in the liver of rats and mice exposed to 2,000–3,000 ppm were observed in several other intermediate-duration inhalation studies (Lester et al. 1963; Schaffner 1978; Torkelson et al. 1961; Wisniewska-Knypl et al. 1980).

Table A-2 Summary of Candidate Critical Effects for Intermediate-Duration Inhalation MRL for Vinyl Chloride

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Hepatic effects^a^
Rat (Wistar) | 3, 6 months; 6 days/week; 6 hours/day | ND | 11.1 | Increased relative liver weight at 6 months | Bi et al. 1985
Rat (Wistar) | 10 months; 5 days/week; 5 hours/day | ND | 50 | Fatty changes | Sokal et al. 1980
Rat (Sprague-Dawley) | 2 generations; 16 weeks (M); 19 weeks (F); 4-6 hours/day | ND | 10^a^ | Centrilobular hypertrophy in F1 female rats | Thornton et al. 2002
Rat (NS) | 6 months; 5 days/week; 0.5–7 hours/day | ND | 100 | Increased relative liver weight | Torkelson et al. 1961
Rabbit (NS) | 6 months; 5 days/week; 7 hours/day | 100 | 200 | Centrilobular degeneration and necrosis | Torkelson et al. 1961
Rat (Wistar) | 10 months; 5 days/week; 5 hours/day | ND | 50 | Fatty changes | Wisniewska-Knypl et al. 1980
Mouse (C57BL/6N) | 16 weeks; 5 days/week; 2 hours/day | 57.3 | 286.7 | Fat droplets, eosinophilic changes, nuclear condensation; at 1,433.6 ppm: Steatosis, large lipid droplets, hepatic edema, cytoplasmic loosening, and hepatocyte nuclear fragmentation | Wang et al. 2019a
Reproductive effects
Rat (Wistar) | 3, 6 months; 6 days/week; 6 hours/day | | 100 | Decreased testes weight with testicular necrosis at 6 months | Bi et al. 1985
Renal effects
Rat (Wistar) | 3, 6 months; 6 days/week; 6 hours/day | | 2,918 | Increased relative kidney weight at 3 months | Bi et al. 1985
Rat (Wistar) | 10 months; 5 days/week; 5 hours/day | 50 | 500 | Increased relative kidney weight | Sokal et al. 1980
Immunological effects
Rat (Wistar) | 10 months; 5 days/week; 5 hours/day | ND | 50 | Increased relative spleen weight | Sokal et al. 1980
Mouse (CD-1) | 2–8 weeks; 5 days/week; 6 hours/day | ND | 10 | Increased spontaneous lymphocyte proliferation | Sharma and Gehring 1979
Rabbit (New Zealand) | 8 weeks; 5 days/week; 6 hours/day | ND | 10 | Increased spontaneous lymphocyte proliferation | Sharma et al. 1980

a Selected critical effect.

F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

Testicular lesions characterized as degenerative seminiferous tubule changes or spermatogenic epithelial necrosis were observed in male rats exposed for 6–10 months to 100–500 ppm vinyl chloride (Bi et al. 1985; Sokal et al. 1980). Decreased white blood cell counts resulted from exposure of rats to 20,000 ppm for 3 months (Lester et al. 1963), while increased lymphocyte proliferation resulted in mice and immunized rabbits exposed to 10 ppm for up to 8 weeks (Sharma and Gehring 1979; Sharma et al. 1980). Exposures of 10–20,000 ppm resulted in increases and decreases in various relative organ weights (Bi et al. 1985; Sokal et al. 1980; Sharma et al. 1980), including the liver (Bi et al. 1985; Sharma and Gehring 1979; Thornton et al. 2002; Torkelson et al. 1961).

Selection of the Principal Study: Thornton et al. (2002) was chosen as the principal study for derivation of the intermediate-duration inhalation MRL. The study identified the lowest LOAEL for critical liver effects including centrilobular hypertrophy and increased liver weight in rats. The study provided data for centrilobular hypertrophy in F1 offspring, a minimally adverse effect in a sensitive subpopulation (offspring) of the target organ (liver) that is sensitive to both inhalation and oral exposures. A hematological effect was also observed at 10 ppm in mice (Sharma and Gehring 1979) and immunized rabbits (Sharma et al. 1980). However, these studies were not selected as a principal study due to the short exposure duration (2–8 weeks) and lack of other study support.

Summary of the Principal Study:

Thornton SR, Schroeder RE, Robison RL, . 2002. Embryo-fetal developmental and reproductive toxicology of vinyl chloride in rats. Toxicol Sci 68:207–219.12075123

Groups of male and female Sprague-Dawley rats (30/sex/group) were exposed to vinyl chloride vapor concentrations of 0, 10, 100, or 1,100 ppm, 6 hours/day for 10 weeks prior to mating and during a 3-week mating period. F0 males were exposed during the gestational period and sacrificed following the completion of parturition. F0 females were exposed during gestation and lactation (with the exception of a break in exposure from GD 21 through postnatal day 4 to allow for delivery of litters). All F0 rats were observed twice daily for clinical signs. Body weights and food consumption were monitored. F1 litters were examined for live and dead pups and on lactation day 4, litters were culled to eight pups (equal numbers of male and female pups where possible). All F0 female rats (including those that did not produce offspring) were sacrificed after the F1 rats had been weaned. Reproductive tissues, adrenal glands, brain, kidneys, liver, lungs, spleen, thymus, mammary glands, nasal tissues, pituitary, and trachea from each of the F0 rats were individually weighed and subjected to histopathologic examinations. At weaning, 15 male and female F1 rats/group were selected for gross and microscopic examinations. Other F1 rats were randomly selected to form groups of 30/sex/group, and these F1 rats were subjected to the same treatment as the F0 rats during the production of an F2 generation. At weaning, 15 male and female F2 rats/group were subjected to gross and microscopic examinations. Sperm parameters were assessed in 15 F0 and 15 F1 male rats of each exposure group.

Absolute and relative mean liver weights were significantly increased at all exposure levels in F0 males and in 100- and 1,100-ppm F1 males. Slight centrilobular hypertrophy, considered to be a minimal adverse effect, was noted in the livers of all 1,100-ppm male and female F0 and F1 rats, most 100-ppm male and female F0 and F1 rats, and in 2/30 and 6/30 of the 10-ppm F0 and F1 female rats, respectively. No incidences of centrilobular hypertrophy were found in any of the control rats. Compared to an incidence of 0/30 for this lesion in controls, the incidence of 6/30 in the 10-ppm F1 female rats exceeded the level of statistical significance (p<0.05 according to Fisher’s Exact Test performed by ATSDR).

Selection of the Point of Departure for the MRL: The BMCL_10_ value of 2.05 ppm for increased incidence of centrilobular hypertrophy in the liver of F1 female rats was selected as the basis of the MRL.

BMD modeling was performed for the candidate liver endpoints in Table A-3 when data were amenable to modeling. Data modeled are shown in Tables A-4 and A-5. The data were fit to all available dichotomous or continuous models in EPA’s Benchmark Dose Software (BMDS) (version 3.2) using a benchmark response (BMR) of 1 standard deviation (liver weight data) or 10% extra risk (centrilobular hypertrophy). Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMCL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL (95% lower confidence limit on the BMD) was selected as the POD when the difference between the BMCLs estimated from these models was ≥3 fold; otherwise, the BMCL from the model with the lowest Akaike Information Criterion (AIC) was chosen. ATSDR follows EPA BMD Guidance (EPA 2012) that compares the fold difference in BMCL values of acceptable models to select the most appropriate model.

Table A-3 Summary of Candidate Critical Liver Effects for Intermediate-Duration Inhalation MRL for Vinyl Chloride^a^

Effect | Sex/generation | NOAEC (ppm) | LOAEC (ppm)
Absolute liver weight | F0 males | ND | 10
Absolute liver weight | F1 males | 10 | 100
Relative liver weight | F0 males | 10 | 100
Relative liver weight | F1 males | 10 | 100
Centrilobular hypertrophy | F0 females | 10 | 100
Centrilobular hypertrophy | F1 females | ND | 10

a Thornton et al. (2002); exposure occurred 10 weeks prior to mating and during a 3-week mating period; F0 males were further exposed during the gestational period and F0 females were further exposed during gestation and lactation.

LOAEC = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NOAEC = no-observed-adverse-effect level; ND = not determined

Table A-4 Absolute and Relative Liver Weight in F0 And F1 Male Rats Following Inhalation Exposure to Vinyl Chloride^a^

Endpoint | Exposure concentration (ppm)
Endpoint | 0 | 10 | 100 | 1,100
Number of animals | 15 | 15 | 15 | 15
Absolute liver weight (g)
F0 males | 14.32±2.13^b^ | 16.20±2.19^c^ | 16.22±1.59^d^ | 16.72±0.86^d^
F1 males | 14.13±2.36 | 15.07±2.74 | 16.62±2.27^c^ | 17.01±1.49^d^
Relative liver weight
F0 males | 2.83±0.26 | 3.05±0.29^c^ | 3.09±0.20^c^ | 3.26±0.19^d^
F1 males | 2.98±0.33 | 3.01±0.19 | 3.32±0.36^d^ | 3.38±0.19^d^

a Exposure for 6 hours/day for 10 weeks prior to mating and during mating and gestation (males and females) and lactation (females).

b Mean±standard deviation.

c Statistically significantly (p<0.05) different from controls.

d Statistically significantly (p<0.01) different from controls.

Source: Thornton et al. 2002

Table A-5 Incidences of Centrilobular Hypertrophy in the Liver for F0 And F1 Female Rats Following Inhalation Exposure to Vinyl Chloride^a^

| Exposure concentration (ppm)
| 0 | 10 | 100 | 1,100
F0 females | 0/30 | 2/30 | 26/30^b^ | 30/30^b^
F1 females | 0/30 | 6/30^b^ | 30/30^b^ | 30/30^b^

a Exposure for 6 hours/day for 10 weeks prior to mating and during mating and gestation (males and females) and lactation (females).

b Statistically significantly (p<0.05) different from controls according to Fisher’s Exact Test performed by ATSDR.

Source: Thornton et al. 2002

None of the BMD models (with constant variance or nonconstant variance) provided adequate fit to the data for increased absolute liver weight in F0 males or to relative liver weight in F1 males. Therefore, a NOAEL/LOAEL approach was used for these endpoints.

For absolute liver weight in F1 males, the BMD software (BMDS) could not adequately fit the full dataset, but it was able to provide an adequate fit after dropping the highest dose (1,100 ppm). Dropping the highest dose (or doses) is a valid technique in this case. First, the dataset had enough non-zero dose groups with significant responses to remove the highest dosage without loss of BMD trend. Second, the POD for this dataset would visually be in the lower dose groups, but the high dose group is very far away from these lower groups. This situation can lead to models straining to fit the high group (because of leverage) at the cost of losing adequate fit of lower groups. With the highest dose dropped, five frequentist, constant variance models provided adequate fit to the data. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the simplest model with the lowest AIC was selected (Linear). The restricted linear model estimated a BMC_1SD_ and BMCL_1SD_ of 110 and 68 ppm, respectively. BMDS states a warning when fitting the reduced dataset, as the estimated BMD was higher than the new highest dose (100 ppm), which normally raises extrapolation error concerns. However, the estimated BMD (109.8) was still less than the removed high dose, so the estimate would not be much of an extrapolation. Since BMD falls well below the dropped dose of 1,100 ppm, the extrapolation warning (BMD>higher dose) may not be a concern. The results of the BMD modeling are summarized in Table A-6.

Table A-6 Model Predictions (Constant Variance) for Absolute Liver Weight in F1 Male Rats Following Inhalation Exposure to Vinyl Chloride^a^

Model | BMC_1SD_^b^ (ppm) | BMCL_1SD_^b^ (ppm) | p-Value^c^ | | Scaled residuals^d^
Model | BMC_1SD_^b^ (ppm) | BMCL_1SD_^b^ (ppm) | p-Value^c^ | AIC | Dose near BMC | Dose near control
Highest dose dropped from dataset
Exponential (model 2)^e^ | 109.69 | 70.36 | 0.40 | 212.52 | −0.06 | −0.57
Exponential (model 3)^e^ | 109.72 | 70.36 | 0.40 | 212.52 | −0.05 | −0.57
Exponential (model 4)^e^ | | | NA | 213.80 | −3.3×10^−6^ | −4.1×10^−6^
Exponential (model 5)^e^ | | | NA | 213.80 | −5.8×10^−8^ | −2.7×10^−7^
Hill^e^ | | | <0.0001 | 215.80 | −0.00023 | −9.7×10^−5^
Polynomial (2-degree)^e^ | 109.77 | 67.61 | 0.41 | 212.49 | −0.06 | −0.55
Power^f^ | 109.77 | 67.61 | 0.41 | 212.49 | −0.06 | −0.55
Linear ^e^ ^,^ ^g^ | 109.77 | 67.61 | 0.41 | 212.49 | −0.06 | −0.55

a Exposure for 6 hours/day for 10 weeks prior to mating and during mating and gestation (males and females) and lactation (females).

b BMC and BMCL values for models that do not provide adequate fit are not included in the table.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at concentrations immediately below and above the BMC.

e Power restricted to ≥1.

f Coefficients restricted to be positive.

g Selected model. For the full dataset, none of the models provided adequate fit to the variance data (constant or nonconstant). With the highest dose dropped, constant variance models provided adequate fit to the variance data. With constant variance model applied, all models provided adequate fit to the means except for the Hill and Exponential 4 and 5 models. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the simplest model with the lowest AIC is selected (Linear).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the exposure concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response); NA = not applicable (Goodness of fit test cannot be calculated); SD = standard deviation

Source: Thornton et al. 2002

For relative liver weight in F0 males, no constant variance models provided an adequate fit to the dataset with the nonconstant variance model applied, only the Hill and Exponential 4 and 5 models provided adequate fit to the data. The BMD computation failed for the Hill model; the lower limit included zero and the BMDL was not estimated. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential 4). The Exponential 4 model estimated a BMC_1SD_ and BMCL_1SD_ of 216 and 72 ppm, respectively. The results of the BMD modeling are summarized in Table A-7.

Table A-7 Model Predictions (Nonconstant Variance) for Relative Liver Weight in F0 Male Rats Following Inhalation Exposure to Vinyl Chloride^a^

Model | BMC_1SD_^b^ (ppm) | BMCL_1SD_^b^ (ppm) | p-Value^c^ | | Scaled residuals^d^
Model | BMC_1SD_^b^ (ppm) | BMCL_1SD_^b^ (ppm) | p-Value^c^ | AIC | Dose near BMC | Dose near control
Exponential (model 2)^e^ | | | 0.02 | 8.08 | −0.07 | −2.16
Exponential (model 3)^e^ | | | 0.02 | 8.08 | −0.08 | −2.16
Exponential (model 4) ^e^ ^,^ ^f^ | 216.31 | 71.99 | 0.11 | 5.08 | −0.40 | −1.20
Exponential (model 5)^e^ | 225.86 | 70.96 | 0.11 | 5.09 | −0.38 | −1.22
Hill^d^ | 246.14 | 0 | 0.14 | 4.72 | −0.57 | −1.04
Polynomial (3-degree)^e^ | | | 0.02 | 8.03 | −0.09 | −2.15
Polynomial (2-degree)^e^ | | | 0.02 | 8.03 | −0.09 | −2.15
Power^e^ | | | 0.02 | 8.03 | −0.09 | −2.15
Linear^g^ | | | 0.02 | 8.03 | −0.09 | −2.15

a Exposure for 6 hours/day for 10 weeks prior to mating and during mating and gestation (males and females) and lactation (females).

b BMC and BMCL values for models that do not provide adequate fit are not included in the table.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at concentrations immediately below and above the BMC.

e Power restricted to ≥1.

f Selected model. None of the constant variance models provided adequate fit to the data. With the nonconstant variance model applied, only the Hill and Exponential 4 and 5 models provided adequate fit to the data. The BMC computation failed for the Hill model; the lower limit included zero and the BMCL was not estimated; therefore, the Hill model was unusable. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential 4).

g Coefficients restricted to be positive.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the exposure concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response); SD = standard deviation

Source: Thornton et al. 2002

For the incidence of centrilobular hypertrophy in the liver in F0 females, all models provided an adequate fit to the data except for the Probit model. BMCLs for models providing an adequate fit were not sufficiently close (differed by ≥3-fold), so the model with the lowest BMCL was selected (1-degree multistage). The 1-degree multistage model estimated a BMC_10_ and BMCL_10_ of 6.16 and 4.4 ppm, respectively. The results of the BMD modeling are summarized in Table A-8.

Table A-8 Results from BMD Analysis of Incidences of Centrilobular Hypertrophy in the Liver in F0 Female Rats Following Inhalation Exposure to Vinyl Chloride^a^

Model | BMC_10_^b^ (ppm) | BMCL_10_^b^ (ppm) | p-Value^c^ | | Scaled residuals^d^
Model | BMC_10_^b^ (ppm) | BMCL_10_^b^ (ppm) | p-Value^c^ | AIC | Dose near BMC | Dose near control
Gamma^e^ | 13.01 | 5.89 | 1.00 | 44.26 | 0.0006 | −0.0032
Logistic | 31.04 | 20.79 | 0.54 | 44.13 | 0.7257 | −0.8500
Log-Logistic^f^ | 12.64 | 6.89 | 0.98 | 42.34 | 0.0301 | −0.0007
Log-Probit | 12.14 | 7.58 | 0.97 | 44.26 | 0.0028 | −0.0007
Multistage (1-degree) ^g^ ^,^ ^h^ | 6.16 | 4.40 | 0.31 | 45.03 | −1.3638 | −0.0007
Multistage (2-degree)^h^ | 14.06 | 5.78 | 1.00 | 44.26 | 1.71×10^−5^ | −0.0007
Multistage (3-degree)^h^ | 14.92 | 5.76 | 1.00 | 42.26 | 2.16×10^−6^ | −0.0007
Probit | | | 0.01 | 55.73 | −1.1734 | −1.9041
Weibull^e^ | 12.79 | 5.85 | 0.90 | 44.27 | −0.1025 | −0.0017
Dichotomous Hill | 12.64 | 6.89 | 0.98 | 42.34 | 0.0301 | −0.0007

a Exposure for 6 hours/day for 10 weeks prior to mating and during mating and gestation (males and females) and lactation (females).

b BMC and BMCL values for models that do not provide adequate fit are not included in the table.

c Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the BMC.

e Power restricted to ≥1.

f Slope restricted to ≥1.

g Selected model. All models provided adequate fit to the data except for the Probit model. BMCLs for models providing adequate fit differed by ≥3-fold; therefore, the model with the lowest BMCL was selected (1-degree Multistage).

h Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the dose associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Source: Thornton et al. 2002

For the incidence of centrilobular hypertrophy in the liver in F1 females, all models provided an adequate fit to the data except for the Probit model. The BMD computation failed for the Weibull model and a BMCL was not estimated; this model was deemed unusable. BMCLs for models providing an adequate fit were not sufficiently close (differed by ≥3-fold), so the model with the lowest BMCL was selected (1-degree multistage). The 1-degree multistage model estimated a BMC_10_ and BMCL_10_ of 3.03 and 2.05 ppm, respectively. The results of the BMD modeling are summarized in Table A-9.

Table A-9 Results from BMD Analysis of Incidences of Centrilobular Hypertrophy in the Liver in F1 Female Rats Following Inhalation Exposure to Vinyl Chloride^a^

Model | BMC_10_^b^ (ppm) | BMCL_10_^b^ (ppm) | p-Value^c^ | | Scaled residuals^d^
Model | BMC_10_^b^ (ppm) | BMCL_10_^b^ (ppm) | p-Value^c^ | AIC | Dose near BMC | Dose near control
Gamma^e^ | 6.53 | 3.10 | 0.98 | 34.11 | −0.0241 | −0.0007
Logistic | 11.34 | 7.58 | 0.41 | 36.75 | 0.9450 | −1.4034
Log-Logistic^f^ | 8.21 | 5.21 | 1.00 | 32.04 | −0.0021 | −0.0007
Log-Probit | 8.59 | 5.09 | 1.00 | 34.02 | 7.296×10^−11^ | −0.0007
Multistage (1-degree) ^g^ ^,^ ^h^ | 3.03 | 2.05 | 0.33 | 37.28 | −0.0007 | −0.0007
Multistage (2-degree)^h^ | 6.75 | 2.72 | 1.00 | 34.02 | −2.32×10^−8^ | −0.0007
Multistage (3-degree)^h^ | 6.76 | 2.61 | 1.00 | 36.02 | 3.527×10^−8^ | −0.0007
Probit | | | 0.001 | 60.13 | −0.4459 | −2.6297
Weibull^e^ | 5.11 | 0.00 | 0.84 | 34.65 | −0.2606 | −0.0007
Dichotomous Hill | 8.21 | 5.21 | 1.00 | 34.04 | −0.0021 | −0.0007

a Exposure for 6 hours/day for 10 weeks prior to mating and during mating and gestation (males and females) and lactation (females).

b BMC and BMCL values for models that do not provide adequate fit are not included in the table.

c Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the BMC.

e Power restricted to ≥1.

f Slope restricted to ≥1.

g Selected model. All models provided adequate fit to the data except for the Probit model and the Weibull model did not estimate a BMCL. BMCLs for models providing adequate fit differed by ≥3-fold; therefore, the model with the lowest BMCL was selected (1-degree Multistage).

h Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the dose associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Source: Thornton et al. 2002

Table A-10 summarizes the potential candidate PODs for the intermediate-duration inhalation MRL for vinyl chloride. Based on the lowest available critical values (BMC, NOAEL), centrilobular hypertrophy (in F1 females) was identified as the critical effect following intermediate-duration inhalation exposure to vinyl chloride. The 1-degree multistage model fit to the centrilobular hypertrophy data in F1 female rats is presented in Figure A-1. The corresponding BMCL_10_ of 2.05 is used as the POD in further calculations.

Table A-10 Candidate Points of Departure for the Intermediate-Duration Inhalation MRL

Endpoint | NOAEC (ppm) | LOAEC (ppm) | BMC_10_ (ppm) | BMCL_10_ (ppm)
Increased absolute liver weight; F0 males | ND | 10
Increased absolute liver weight; F1 males | | | 110 | 68
Increased relative liver weight; F0 males | | | 216 | 72
Increased relative liver weight; F1 males | 10 | 100
Centrilobular hypertrophy; F0 females | | | 6.16 | 4.4
Centrilobular hypertrophy; F1 females | | | 3.03 | 2.05

BMC = benchmark concentration; BMCL = 95% lower confidence limit on the BMC; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level

Figure A-1 Fit of 1-Degree Multistage Model to Data for Incidences of Centrilobular Hypertrophy in the Liver in F1 Female Rats Following Inhalation Exposure to Vinyl Chloride (Thornton et al. 2002)

Figure A-1 description

Calculations

Adjustment for Intermittent Exposure: The intermittent exposure duration of 6 hours/day was duration-adjusted (BMCL_10ADJ_) to continuous exposure according to the following equation:

BMCL_10 ADJ_ = BMCL_10_ ( 2.05 ppm ) × 6 hours / 24 hours per day = 0.5125 ppm

Human Equivalent Concentration: Following EPA (1994) methodology, the human equivalent concentration (BMCL_10HEC_) for an extrarespiratory effect produced by a category 3 gas, such as vinyl chloride, is calculated by multiplying the animal BMCL_10ADJ_ by the ratio of the blood:gas partition coefficients in animals and humans [(H_b/g_)_A_ / H_b/g_)_H_]. Since the partition coefficient in rats is greater than that in humans, a default value of 1 is used for the ratio and the animal BMCL_10ADJ_ is equivalent to the BMCL_10HEC_. Several PBPK models are available for vinyl chloride; however, none of these models included an evaluation of exposure during mating, gestation, or lactation. Therefore, PBPK models could not be used to calculate a BMCL_10HEC_ from the Thornton et al. (2002) study. The intermediate-duration inhalation MRL of 0.02 ppm was derived by dividing the BMCL_10HEC_ of 0.5125 ppm for centrilobular hypertrophy in female Sprague-Dawley rats by a factor of 30 (3 for species extrapolation using a dosimetric conversion and 10 for human variability).

Uncertainty Factor: The BMCL_10_ was divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustment
- 10 for human variability

MRL = BMCL_10 HEC_ ÷ ( UF ) 0.5125 ppm ÷ ( 3 × 10 ) = 0.017 ≈ 0.02 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Liver enlargement and/or histopathological changes have been noted in a number of intermediate-duration inhalation studies in animals (Bi et al. 1985; Lester et al. 1963; Schaffner 1978; Sokal et al. 1980; Torkelson et al. 1961; Wisniewska-Knypl et al. 1980). The studies by Thornton et al. (2002) and Bi et al. (1985) show these effects at a somewhat lower dosage. In support of using an effect level of 10 ppm, there was also a finding of immunostimulation in mice and immunized rabbits at 10 ppm (Sharma and Gehring 1979; Sharma et al. 1980).

Agency Contacts (Chemical Managers): Rae Benedict

## Vinyl chloride Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl chloride
CAS Numbers: | 75-01-4
Date: | January 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for vinyl chloride.

Rationale for Not Deriving an MRL: In the absence of exposure level data, the human database did not provide a suitable LOAEL or NOAEL for derivation of a chronic-duration inhalation MRL. The animal database mostly reported cancer and death. One study (Bi et al. 1985) reported body weight, organ weight, reproductive (histological), and cancer effects. A NOAEL (11.1 ppm) and a LOAEL (105.6 ppm) were identified for testicular effects (increases in the number of degenerative seminiferous tubule changes) in a chronic-duration inhalation study (Bi et al. 1985). However, the results of the Thornton et al. (2002) study for intermediate-duration exposure suggest that liver effects (increased liver weight, centrilobular hypertrophy) would occur at lower concentrations (10 ppm) than the reported testicular effects. Bi et al. (1985) did not report noncancer liver histopathology; therefore, this study cannot be used to derive a chronic-duration inhalation MRL. Though several other chronic-duration studies did report carcinogenicity in rats chronically exposed to 5–250 ppm vinyl chloride (Drew et al. 1983; Lee et al. 1977a, 1978; Maltoni et al. 1981), they did not report the incidence of noncancerous or precancerous histopathological lesions in any tissue. Therefore, no chronic-duration inhalation MRL was derived for vinyl chloride.

Agency Contacts (Chemical Managers): Rae Benedict

## Vinyl chloride Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl chloride
CAS Numbers: | 75-01-4
Date: | January 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for vinyl chloride.

Rationale for Not Deriving an MRL: No acute-duration oral MRLs was derived for vinyl chloride because of an absence of data on the effects of oral exposure to vinyl chloride for this duration category.

Agency Contacts (Chemical Managers): Rae Benedict

## Vinyl chloride Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl chloride
CAS Numbers: | 75-01-4
Date: | January 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for vinyl chloride.

Rationale for Not Deriving an MRL: No intermediate-duration oral MRLs was derived for vinyl chloride because of an absence of data on the effects of oral exposure to vinyl chloride for this duration category.

Agency Contacts (Chemical Managers): Rae Benedict

## Vinyl chloride Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl chloride
CAS Numbers: | 75-01-4
Date: | January 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.003 mg/kg/day (3 µg/kg/day)
Critical Effect: | Liver cell polymorphisms
References: | Til et al. 1983, 1991
Point of Departure: | NOAEL of 0.17 mg/kg/day (NOAEL_HED_ of 0.09 mg/kg/day)
Uncertainty Factor: | 30
LSE Graph Key: | 5
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.003 mg/kg/day (3 µg/kg/day) is proposed for vinyl chloride based on a NOAEL of 0.17 mg/kg/day and a LOAEL of 1.7 mg/kg/day for liver cell polymorphisms in rats administered vinyl chloride for 149 weeks (Til et al. 1983,1991). The PBPK-modeled equivalent human NOAEL associated with the rat NOAEL (NOAEL_HED_) of 0.17 mg/kg/day was 0.09 mg/kg/day. The NOAEL_HED_ was divided by a total uncertainty factor of 30 (3 for species extrapolation using a dosimetric conversion and 10 for human variability) to arrive at an MRL of 0.003 mg/kg/day.

Selection of the Critical Effect: No dose-response data are available for humans. Available data indicate that the liver is the most sensitive endpoint for toxic effects following chronic-duration oral exposure to vinyl chloride (Table A-11). A number of effects were observed in rats given 1.7 mg/kg/day, including hepatocellular alterations (Feron et al. 1981), liver cell polymorphisms, and increased mortality (Til et al. 1983, 1991). Liver cell polymorphism is related to cytotoxicity and is considered a nonneoplastic lesion (Schoental and Magee 1957, 1959). The LOAEL of 1.7 mg/kg/day for liver cell polymorphism (in both sexes) and hepatic cysts in female rats was the lowest identified LOAEL and was associated with the lowest identified NOAEL (0.17 mg/kg/day) for any chronic effect. Chronic gavage doses of 3 mg/kg/day vinyl chloride in rats resulted in increased mottled appearance and hemorrhagic liver patches (Knight and Gibbons 1987). Doses of 14.1 mg/kg/day in female rats resulted in extensive hepatic necrosis, 100% early mortality, humpback position, lethargy, and emaciation (Feron et al. 1981). Decreased blood clotting time was also observed in rats given 14.1 mg/kg/day (Feron et al. 1981). Increased collagen deposition and skin thickness were seen in rats chronically gavaged with 30 mg/kg/day (Knight and Gibbons 1987).

Table A-11 Summary of Candidate Critical Effects for Chronic-Duration Oral MRL for Vinyl Chloride

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
Rat (Wistar) | 84 weeks–2.7 years; 5 days/week; 4 hours/day (F), (GO) | ND | 1.7 | Cellular alteration | Feron et al. 1981
Rat (Wistar) | 149 weeks; 4 hours/day (F) | 0.17 | 1.7 | Liver cell polymorphism | Til et al. 1983, 1991
Rat (Wistar) | 2 years; 1 time/day (GO) | | 3 | Mottled appearance and hemorrhagic patches | Knight and Gibbons 1987
Hematological
Rat (Wistar) | 84 weeks–2.7 years; 5 days/week; 4 hours/day (F), (GO) | 5 | 14.1 | Decreased clotting time | Feron et al. 1981
Neurological
Rat (Wistar) | 84 weeks–2.7 years; 5 days/week; 4 hours/day (F), (GO) | 5 | 14.1 | Humpback position, lethargy, emaciation | Feron et al. 1981
Dermal effects
Rat (Wistar) | 2 years; 1 time/day (GO) | | 30 | Increased skin thickness, collagen | Knight and Gibbons 1987

F = female(s); G = gavage (no vehicle); GO = gavage (oil vehicle); LOAEL = lowest-observed-adverse-effect level; M = male(s); MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; ND = not determined

Selection of the Principal Study: The study by Til et al. (1983,1991) was selected as the principal study for the derivation of a chronic-duration oral MRL based on the NOAEL of 0.17 mg/kg/day for liver cell polymorphisms. This study identified the lowest LOAEL (1.7 mg/kg/day) for the critical effect.

Summary of the Principal Study:

Til HP, Immel HR, Feron VJ. 1983. Lifespan oral carcinogenicity study of vinyl chloride in rats. Final report. Civo Institutes, TNO. Report No. V 93.285/291099.

Til HP, Feron VJ, Immel HR. 1991. Lifetime (149-week) oral carcinogenicity study of vinyl chloride in rats. Food Chem Toxicol 29:713–718.1959825

Groups of Wistar rats (100/sex/group in controls and the two lowest exposure groups; 50/sex at the highest exposure level) were administered vinyl chloride in the daily diet at intended initial dietary concentrations of 0, 0.46, 4.6, or 46 ppm for 149 weeks. Due to rapid evaporative loss of vinyl chloride from the food, liquid vinyl chloride was mixed with PVC granules to produce a mixture in which vinyl chloride was effectively encapsulated in PVC granules (Feron et al. 1975). The study authors trained the rats to a feeding schedule of 4 hours/day prior to the initiation of exposure to vinyl chloride in the diet. The authors noted that food consumption per hour was fairly constant during the 4-hour feeding period. Loss of vinyl chloride from food during the first hour, the second hour, and the final 2 hours was calculated. Periodic food intake measurements were made for the first hour, the second hour, and the final 2 hours. Based on these measurements, the study authors calculated the average oral intake of the combined sexes during the daily 4-hour feeding periods to be 0, 0.018, 0.17, and 1.7 mg/kg/day for the 0-, 0.49-, 4.49-, and 44.1-ppm groups, respectively. Measurements of vinyl chloride in the feces were made periodically at 1 hour prior to the feeding period, the end of the 4-hour feeding period, and 4 and 9 hours later. The study authors considered the vinyl chloride content in the feces to have remained encapsulated in the PVC granules and thus not to have been available for absorption from the gastrointestinal tract. The amount of vinyl chloride in the feces was subtracted from the calculated daily oral intake of vinyl chloride to arrive at what the study authors termed “actual oral exposure levels” of 0, 0.014, 0.13, and 1.3 mg/kg/day for the 0-, 0.49-, 4.49-, and 44.1-ppm groups, respectively. The incidence of cell polymorphism was recorded by sex and estimated absorbed dose group (Table A-12). Results of toxicokinetic assessments for vinyl chloride indicate that, following absorption, vinyl chloride and its metabolites are not excreted in appreciable amounts in the feces. Types and incidences of neoplastic and nonneoplastic liver lesions were determined at the end of the study.

Effects noted in study and corresponding doses: The critical nonneoplastic effect was determined to be liver cell polymorphism, which was classified by severity (slight, moderate, severe). The incidences of this lesion are listed in Table A-12.

Table A-12 Incidences of Male and Female Wistar Rats Exhibiting Slight, Moderate, or Severe Liver Cell Polymorphism Following Daily Oral Exposure to Vinyl Chloride in the Diet for 149 Weeks

| Estimated oral intake, absorbed (mg/kg/day)
| Males | | | | Females
| 0 | 0.014 | 0.13 | 1.3 | 0 | 0.014 | 0.13 | 1.3
Number of rats examined | 99 | 99 | 99 | 49 | 98 | 100 | 96 | 49
Slight | 27 | 23 | 26 | 19 | 46 | 41 | 49 | 23
Moderate | 4 | 4 | 7 | 10^a^ | 14 | 13 | 8 | 15^b^
Severe | 1 | 1 | 1 | 3 | 2 | 3 | 4 | 9^c^

a Significantly different from controls according to Fisher’s exact test (p<0.001).

b Significantly different from controls according to Fisher’s exact test (p<0.05).

c Significantly different from controls according to Fisher’s exact test (p<0.0001).

Source: Til et al. 1983, 1991

Selection of the Point of Departure for the MRL: A LOAEL of 1.7 mg/kg/day was identified for statistically significantly increased incidences of liver cell polymorphism in male and female rats. The NOAEL for nonneoplastic liver effects is 0.17 mg/kg/day. An increase in the incidence of female rats with many hepatic cysts was also observed at the highest dose (1.7 mg/kg/day). Other histopathologic lesions, described as hepatic foci of cellular alteration, were observed at all dose levels in female rats and in high-dose male rats, but were not used to derive an MRL because they are considered to be preneoplastic lesions. MRLs are protective only for non-neoplastic effects and do not reflect cancer risk.

EPA (2000) applied the Clewell et al. (1995) PBPK model for vinyl chloride to the low-, mid-, and high-dose groups (estimated absorbed doses of 0.014, 0.13, and 1.3 mg/kg/day, respectively) to generate dose metrics of 0.3, 3, and 30 mg vinyl chloride metabolites/L liver, respectively. The EPA approach was reviewed and was considered appropriate for deriving the chronic-duration oral MRL.

The dose metric, “number of rats examined,” and the “moderate” and “severe” polymorphism categories (Table A-12) were used in modeling. The “number of rats examined” were summed, regardless of sex, for each dose group, resulting in a low-dose, mid-dose, and high-dose groups. For example, the low-dose group males numbered 99 and the low-dose females numbered 100 to result in 199 rats that were examined in that group (Tables A-12 and A-13). Likewise, the “moderate” and “severe” cell polymorphism incidence data were combined (i.e., summed) for each group, regardless of sex, resulting in one data category of moderate+severe (Table A-13). The moderate+severe polymorphism data had one control group and three exposure groups (low-dose, mid-dose, and high-dose). These combinations resulted in the following cell polymorphism data that were used for modeling: 21/197 controls, 21/199 low-dose, 20/196 mid-dose, and 37/98 high-dose rats) (Til et al. 1983, 1991).

Table A-13 Incidences of Male and Female Wistar Rats Exhibiting Moderate or Severe Liver Cell Polymorphism Following Daily Oral Exposure to Vinyl Chloride in the Diet for 149 Weeks

| Estimated oral intake, absorbed (mg/kg/day)
| 0 | 0.014 | 0.13 | 1.3
| Dose metric (mg metabolite/L liver)
| 0 | 0.3 | 3 | 30
Number of rats examined | 197 (99, 98)^a^ | 199 (99, 100) | 195 (99, 96) | 98 (49, 49)
Moderate+severe cell polymorphism | 21 (4, 1, 14, 2)^b^ | 21 (4, 1, 13, 3) | 20 (7, 1, 8, 4) | 37 (10, 3, 15, 9)

a Data in parentheses are the incidence numbers for males and females taken from Table A-12.

b Data in parentheses are moderate and severe cell polymorphism incidence numbers for males and females.

Source: Til et al. 1983, 1991

The resulting incidence data for each dose metric (0.3, 3, and 30 mg metabolite/L liver) were subjected to BMD modeling in order to statistically identify a threshold response for vinyl chloride-induced effects. The resulting dose metric values are shown in Table A-14.

Table A-14 LED_10_ Values Generated from Various Models to Liver Cell Polymorphism Incidence Data from Oral Exposure of Male and Female Rats to Vinyl Chloride in the Diet for 149 Weeks in the Study of Til et al. (1991)

Model | LED_10_ (mg/L liver)^a^ | p-Value
Weibull (power ≥1) | 24.0 | 0.88
Gammahit | 21.4 | 0.88
Quantal quadratic | 13.8 | 0.96
Logistic | 12.9 | 0.47
Multistage | 11.8 | 0.79
Probit | 11.6 | 0.44
Quantal linear | 6.5 | 0.46
NOAEL | 3.00 (0.13 mg/kg/day)
LOAEL | 29.9 (1.3 mg/kg/day)

a LED_10_ is the lower 95% confidence limit of a 10% change in numbers exhibiting polymorphism evaluated as either moderate or severe. The NOAEL and LOAEL are shown for comparison.

Source: EPA 2000

Although all models provided adequate fit to the data, the LED_10_ values ranged from 6.5 to 24.01 mg/L liver (nearly a 4-fold range) and all modeled LED_10_ values were higher than the NOAEL of the study. Because there was no biological reason to choose the results of one model over another and the dose-response characteristics present additional uncertainty due to the large gaps between dose levels, the BMD modeling results were not used to derive the POD. Assuming that all dietary vinyl chloride was absorbed, the human equivalent dose of 0.09 mg/kg/day, calculated from the rat NOAEL of 0.17 mg/kg/day (Til et al. 1983, 1991), served as the basis for the chronic-duration oral MRL for vinyl chloride. The chronic-duration oral MRL of 0.003 mg/kg/day was derived by dividing the PBPK-modeled equivalent human NOAEL of 0.09 mg/kg/day for liver cell polymorphisms by a factor of 30 (3 for species extrapolation using a dosimetric conversion and 10 for human variability).

Human Equivalent Concentration: In deriving the MRL, the rat NOAEL of 0.17 mg/kg/day was converted to a human equivalent dose using the PBPK models described in Clewell et al. (2001) and EPA (2000) to extrapolate from rats to humans. Source code and parameter values for running the rat and human models in ACSL were transcribed from Appendix C of EPA (2000). Parameter values used in the interspecies extrapolation are presented in Table A-15. Accuracy of the implementation of the model in ACSL (v. 11.8.4) was checked against observations reported in Gehring et al. (1978), also reported in Clewell et al. (2001) (results shown in Figure A-2). The visual fit of the observed and predicted values appears adequately good at low doses. The total amount of vinyl chloride metabolized in 24 hours per L of liver volume was the rat internal dose metric that was used in determining the human dose that would result in an equivalent human dose metric. One kilogram of liver was assumed to have an approximate volume of 1 L. Exposures in the Til et al. (1983, 1991) rat dietary study were simulated as 4-hour oral exposures, for which the average daily dose (ADD) was equivalent to the NOAEL dose for liver effects (ADD=0.17 mg/kg/day). This dose was uniformly distributed over a 4-hour period (i.e., 0.0425 mg/kg/hour for 4 hours, followed by 16 hours at 0 mg/kg/hour). Dose metrics reflect the cumulative amount of vinyl chloride metabolized over the 24-hour period.

Table A-15 Parameter Values for Rat and Human Models

Parameter | Definition | Model
Parameter | Definition | Rat | Human
BW | Body weight (kg) | 0.377 (M); 0.204 (F) | 70
VLC | Liver volume (fraction of body) | 0.05 | 0.026
VFC | Fat volume (fraction of body) | 0.12 | 0.19
VSC | Slowly-perfused tissue volume (fraction of body) | 0.75 | 0.63
VRC | Rapidly-perfused tissue volume (fraction of body) | 0.05 | 0.064
QCC | Cardiac output (L/hour-kg body weight) | 18.0 | 16.5
QPC | Alveolar ventilation rate (L/hour-kg body weight) | 21.0 | 24.0
QLC | Liver blood flow (fraction of cardiac output) | 0.25 | 0.26
QFC | Fat blood flow (fraction of cardiac output) | 0.09 | 0.05
QSC | Slowly-perfused blood flow (fraction of cardiac output) | 0.15 | 0.19
QRC | Rapidly-perfused blood flow (fraction of cardiac output) | 0.51 | 0.5
PB | Blood:air partition coefficient | 2.4 | 1.16
PL | Liver:blood partition coefficient | 0.7 | 1.45
PF | Fat:blood partition coefficient | 10.0 | 20.7
PS | Slowly-perfused partition coefficient | 4.0 | 0.83
PR | Rapidly-perfused partition coefficient | 0.7 | 1.45
VMAX1C | Maximum rate of oxidative metabolism; (mg/hour-kg body weight) | 4.0 | 4.0
VMAX2C | Maximum rate of oxidative metabolism; (mg/hour-kg body weight) | 2.0 | 0.1
KM1 | Michaelis-Menten coefficient for oxidative metabolism (mg/L) | 0.1 | 0.1
KM2 | Michaelis-Menten coefficient for oxidative metabolism (mg/L) | 10.0 | 10.0
KCO2C | Rate constant for formation of CO_2_ from oxidative metabolite (hour^−1^) | 1.6 | 1.6
KGSMC | Rate constant for conjugation with GSH (hour^−1^) | 0.13 | 0.13
KFEEC | Rate constant for conjugation, not with GSH (hour^−1^) | 35.0 | 35.0
CGSZ | Initial GSH concentration in liver (µmol/L) | 5,800 | 5,800
KBC | Rate constant for GSH catabolism (hour^−1^) | 0.12 | 0.12
KS | Coefficient controlling resynthesis of GSH (µmol/L) | 2,000 | 2,000
KZC | Zero-order rate constant for resynthesis of GSH (µmol/hour) | 28.5 | 28.5
Ka | Gastrointestinal absorption rate constant (hour^−1^) | 3.0

F= female; GSH = glutathione; M = male

Source: EPA 2000

Figure A-2 Predicted and Observed Relationship Between Air Exposure Concentration and Rate Metabolism of Vinyl Chloride in Rats^*^ * Measurements of metabolites (non-volatile ^14^C in carcass) were made immediately following a 6-hour exposure to [^14^C]vinyl chloride in air. Circles represent observations (±standard deviation); the line shows the corresponding simulations.

Figure A-2 description

The human model was run iteratively, varying the ADD, until the model converged with the internal dose estimate shown in row 1 in Table A-7 (rat, male). The value for the Km1 for oxidative metabolism in humans was assumed to be equal to the Km1 value for rats (0.1 mg/L) (EPA 2000). The human ADD was assumed to be uniformly distributed over a 24-hour period. The resulting HED was 0.09 mg/kg/day (Table A-16). Additional simulations were performed assuming that the ADD was distributed over a 12-hour period (to simulate exposure from drinking water or food during the day only). The resulting dose metrics were very similar to the 24-hour estimates (data not shown).

Table A-16 Summary of Internal Dose Predictions and Corresponding Human and Rat Equivalent Doses

Species | BW | Km1 | ED | EF1 | EF2 | ADD | DM
Species | (kg) | mg/L | (week) | (day/week) | (hour/day) | (mg/kg/day) | (mg/L)
Wistar rat
Male | 0.377 | 0.1 | 149 | 7 | 4 | 0.17 | 3.16
Female | 0.204 | 0.1 | 149 | 7 | 4 | 0.17 | 3.16
Human | 70 | 0.1 | 3,640 | 7 | 24 | 0.09 | 3.16

ADD = average daily administered dose; BW = body weight; DM = dose metric equals the total amount of metabolite formed in 24 hours per L of liver; ED = exposure duration; EF = exposure frequency; Km1 = Michaelis-Menten constant for oxidative metabolism

The NOAEL_HED_ of 0.09 mg/kg/day, associated with the rat NOAEL of 0.17 mg/kg/day (Til et al. 1983, 1991), served as the basis for the chronic-duration oral MRL for vinyl chloride; the LOAEL_HED_ is 1.07 mg/kg/day.

Uncertainty Factor: The PBPK-modeled equivalent human NOAEL of 0.09 mg/kg/day was divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustment
- 10 for human variability

MRL = NOAEL_HED_ ÷ ( UF ) 0.09 mg / kg / day ÷ ( 3 × 10 ) = 0.003 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: This MRL is reinforced by a study by Feron et al. (1981) in which rats were fed diets containing PVC powder. Increased areas of cellular alteration (consisting of clear foci, basophilic foci, and eosinophilic foci) were observed in the liver of rats at an oral intake of vinyl chloride monomer of 1.8 mg/kg/day.

Agency Contacts (Chemical Managers): Rae Benedict