# CHAPTER 8 REFERENCES

Albertini RJ. 2013. Vinyl acetate monomer (VAM) genotoxicity profile: relevance for carcinogenicity. Crit Rev Toxicol 43(8):671–706. 10.3109/10408444.2013.827151.23985073
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290. 10.1002/jat.2550030603.6376602
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Sarangapani R. 1999. Clearance concepts applied to the metabolism of inhaled vapors in tissues lining the nasal cavity. Inhal Toxicol 11(10):873–897. 10.1080/089583799196691.10509025
Andersen ME, Green T, Frederick CB, . 2002. Physiologically based pharmacokinetic (PBPK) models for nasal tissue dosimetry of organic esters: assessing the state-of-knowledge and risk assessment applications with methyl methacrylate and vinyl acetate. Regul Toxicol Pharmacol 36(3):234–245. 10.1006/rtph.2002.1576.12473408
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Reg 54(174):37618–37634.
ATSDR. 2005a. Health consultation: Bagley Bank City of Bagley, Clearwater County, Minnesota. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/PHA/Bagley%20Bank/BagleyBankHC071305.pdf. May 4, 2023.
ATSDR. 2005b. Health consultation: Evaluation of potential soil gas migration in residences adjacent to the Pemaco Superfund Site, Maywood, Los Angeles County, California. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/PemacoSuperfundSite042905/PemacoHC042505.pdf. May 4, 2023.
ATSDR. 2005c. Health consultation: State of Arizona Silver Creek subdivision Tucson, Pima County, Arizona. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/hac/PHA/StateOfArizona-SilverCreekSudv/SilverCreekHCFinal060305.pdf. May 4, 2023.
ATSDR. 2007. Health consultation: Laugh and Learn Daycare Ashville, Pickaway County, Ohio. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/LaughandLearnDaycare/LaughAndLearnDaycareHC061807.pdf. May 4, 2023.
ATSDR. 2009. Public health assessment: Final release *REVISED: Evaluation of exposure to contaminants from the Zeneca/Campus Bay site: 1200 South 47th Street, Richmond, Contra Costa County, California. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/Zeneca-CampusBaySite/REVISED_%20Zeneca_Campus_%20Bay_Site%20PHA%207-22-2009.pdf. May 4, 2023.
ATSDR. 2016. Evaluating vapor intrusion pathways guidance for ATSDR’s division of community health investigations. Agency for Toxic Substances and Disease Registry. https://stacks.cdc.gov/view/cdc/79266. June 29, 2022.
ATSDR. 2022a. Vinyl acetate. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/spl/resources/index.html. June 7, 2023.
ATSDR. 2022b. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/phaguidance/toolbox/ATSDR_SHOWER_Model_v3_0_0.zip. April 5, 2023.
Barbin A, Planche G, Croisy A, . 1978. Detection of electrophilic metabolites of halogenated olefins with 4-(4-nitrobenzyl) pyridine (NBP) or with Salmonella-typhimurium [abstract]. Mutat Res 53:150.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Bartsch H, Malaveille C, Montesano R. 1976. The predictive value of tissue-mediated mutagenicity assays to assess the carcinogenic risk of chemicals. IARC Sci Publ 12:467–491.
Bartsch H, Malaveille C, Barbin A, . 1979. Mutagenic and alkylating metabolites of halo-ethylenes, chlorobutadienes and dichlorobutenes produced by rodent or human liver tissues: Evidence for oxirane formation by P450-linked microsomal mono-oxygenases. Arch Toxicol 41:249–277. 10.1007/BF00296896.373707
Battista SP. 1976. Cilia toxic components of cigarette smoke. In: Proceedings of the 3^rd^ World Conference on smoking and health held in New York, NY, 2-5 Jun 1975. Bethesda, MD: U.S. Department of Health, Education, and Welfare. DHEW(NIH) Publication No. 76-1221, 517–534.
Belpoggi F, Soffritti M, Minardi F, . 2002. Results of a long-term carcinogenicity bioassay on vinyl acetate monomer in Wistar rats. Eur J Oncol 7(4):279–293. 10.1111/j.1749-6632.2002.tb04927.x.
Bogdanffy MS. 2002. Vinyl acetate-induced intracellular acidification: implications for risk assessment. Toxicol Sci 66(2):320–326. 10.1093/toxsci/66.2.320.11896299
Bogdanffy MS, Taylor ML. 1993. Kinetics of nasal carboxylesterase-mediated metabolism of vinyl acetate. Drug Metab Dispos 21(6):1107–1111.7905391
Bogdanffy MS, Valentine R. 2003. Differentiating between local cytotoxicity, mitogenesis, and genotoxicity in carcinogen risk assessments: the case of vinyl acetate. Toxicol Lett 140–141:83–98. 10.1016/s0378-4274(02)00504-0.
Bogdanffy MS, Dreef-van der Meulen HC, Beems RB, . 1994a. Chronic toxicity and oncogenicity inhalation study with vinyl acetate in the rat and mouse. Fundam Appl Toxicol 23(2):215–229. 10.1006/faat.1994.1100.7982530
Bogdanffy MS, Tyler TR, Vinegar MB, . 1994b. Chronic toxicity and oncogenicity study with vinyl acetate in the rat: in utero exposure in drinking water. Fundam Appl Toxicol 23(2):206–214. 10.1006/faat.1994.1099.7982529
Bogdanffy MS, Gladnick NL, Kegelman T, . 1997. Four-week inhalation cell proliferation study of the effects of vinyl acetate on rat nasal epithelium. Inhal Toxicol 9(4):331–350. 10.1080/089583797198178.
Bogdanffy MS, Sarangapani R, Kimbell JS, . 1998. Analysis of vinyl acetate metabolism in rat and human nasal tissues by an in vitro gas uptake technique. Toxicol Sci 46(2):235–246. 10.1006/toxs.1998.2542.10048126
Bogdanffy MS, Sarangapani R, Plowchalk DR, . 1999. A biologically based risk assessment for vinyl acetate-induced cancer and noncancer inhalation toxicity. Toxicol Sci 51(1):19–35. 10.1093/toxsci/51.1.19.10496674
Bogdanffy MS, Plowchalk DR, Sarangapani R, . 2001. Mode-of-action-based dosimeters for interspecies extrapolation of vinyl acetate inhalation risk. Inhal Toxicol 13(5):377–396. 10.1080/08958370119592.11295869
Bogdanffy MS, Clark Lantz R, Melvin JE, . 2004. Mechanism of carcinogenicity of vinyl acetate. Toxicol Pathol 32(1):154–155. 10.1080/714592182.
Boyland E, Chasseaud LF. 1967. Enzyme-catalysed conjugations of glutathione with unsaturated compounds. Biochem J 104:95–102. 10.1042/bj1040095.6035529
Boyland E, Chasseaud LF. 1970. The effect of some carbonyl compounds on rat liver glutathione levels. Biochem Pharmacol 19:1526–1528. 10.1016/0006-2952(70)90075-4.5513938
Brams A, Buchet JP, Crutzen-Fayt MC, . 1987. A comparative study, with 40 chemicals, of the efficiency of the Salmonella assay and the SOS chromotest (kit procedure). Toxicol Lett 38:123–133. 10.1016/0378-4274(87)90120-2.3307023
Brandl B, Eder S, Hirtler A, . 2024. An alternative filament fabrication method as the basis for 3D-printing personalized implants from elastic ethylene vinyl acetate copolymer. Sci Rep 14(1):22773. 10.1038/s41598-024-73424-6.39354037
Budinsky R, Gollapudi B, Albertini RJ, . 2013. Nonlinear responses for chromosome and gene level effects induced by vinyl acetate monomer and its metabolite, acetaldehyde in TK6 cells. Environ Mol Mutagen 54(9):755–768. 10.1002/em.21809.24038327
Carpenter CP, Smyth HF, Pozzani UC. 1949. The assay of acute vapor toxicity, and the grading and interpretation of results on 96 chemical compounds. J Ind Hyg Toxicol 31(6):343–346.15407114
Casto BC. 1980. Detection of chemical carcinogens and mutagens in hamster cells by enhancement of adenovirus transformation. Adv Mod Environ Toxicol 1:241–271.
Casto BC. 1981. Effect of chemical carcinogens and mutagens on the transformation of mammalian cells by DNA viruses. In: Antiviral chemotherapy: Design of inhibitors of viral function. New York, NY: Academic Press, 261–278.
Celanese Chemical. 1972. Primary skin irritation tests with eighteen materials in albino rabbits (with cover letter). Celanese Chemical Corporation Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206028. 878212151. OTS84003A. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206028.xhtml. June 22, 2022.
Chou WL, Speece RE, Siddiqi RH. 1979. Acclimation and degradation of petrochemical wastewater components by methane fermentation. Biotechnol Bioeng Symp 8:391–414.
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Daniels W. 1983. Poly(vinyl acetate). In: Grayson M, ed. Kirk-Othmer encyclopedia of chemical technology. Vol. 23. 3^rd^ ed. New York, NY: John Wiley and Sons, 817–847.
Datta RK, Rao KN. 1979. Kinetics of reactions of singlet molecular oxygen (^1^Δ_g_) with organic compounds. Indian J Chem 18A:102–105.
Deese DE, Joyner RE. 1969. Vinyl acetate: A study of chronic human exposure. Am Ind Hyg Assoc J 30:449–457. 10.1080/00028896909343154.5823425
DOE. 2024a. Protective action criteria (PAC) based on AEGLs, ERPGs, or TEELs. U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDocs. September 13, 2024.
DOE. 2024b. Definition of PACs (AEGLs, ERPGs or TEELs). U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDef. September 13, 2024.
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
EPA. 1981. Engineering handbook for hazardous waste incineration. Washington, DC: U.S. Environmental Protection Agency. PB81248163. SW-889. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB81248163.xhtml. June 22, 2022.
EPA. 1988. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874. EPA600687008. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88179874.xhtml. June 22, 2022.
EPA. 1991. Criteria for municipal solid waste landfills. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 258. https://www.ecfr.gov/current/title-40/chapterI/subchapter-I/part-258. May 23, 2022.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. PB2000100284. EPA600890066F. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2000100284.xhtml. June 22, 2022.
EPA. 1996. Method 8260B: Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). U.S. Environmental Protection Agency. https://19january2017snapshot.epa.gov/sites/production/files/2015-12/documents/8260b.pdf. June 22, 2022.
EPA. 2012. Acetic acid ethenyl ester. Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11. U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screeningtools/download-epi-suitetm-estimation-program-interface-v411. October 26, 2022.
EPA. 2016. Vapor intrusion screening level calculator. U.S. Environmental Protection Agency. https://www.epa.gov/vaporintrusion. June 29, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2020. National emission inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2020-nei-supporting-data-and-summaries. September 10, 2024.
EPA. 2022a. Vinyl acetate. Chemical Data Reporting. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. May 17, 2022.
EPA. 2022b. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023a. Annual summary data. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html#Annual. September 10, 2024.
EPA. 2023b. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141. https://www.govinfo.gov/content/pkg/CFR-2023-title40-vol25/pdf/CFR-2023-title40-vol25-part141.pdf. May 3, 2024.
European Chemicals Bureau. 2008. Vinyl acetate (CAS No. 108-05-4). Summary risk assessment report. Dortmund, Germany: European Chemicals Bureau. https://echa.europa.eu/documents/10162/a3c24f78-4c8d-44e9-a424-24ac30c9c8aa. September 24, 2024.
FDA. 2022a. Vinyl acetate. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=VINYLAC ETATE. June 22, 2022.
FDA. 2022b. Ethylene-vinyl acetate copolymers. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1350. https://www.govinfo.gov/content/pkg/CFR-2022-title21-vol3/pdf/CFR-2022-title21-vol3-sec177-1350.pdf. September 13, 2024.
FDA. 2024. Vinyl acetate. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=VINYLAC ETATE. September 23, 2024.
Fedtke N, Wiegand HJ. 1990. Hydrolysis of vinyl acetate in human blood. Arch Toxicol 64(5):428–429. 10.1007/BF01973471.2403294
Florin I, Rutberg L, Curvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames’ test. Toxicology 18:219–232. 10.1016/0300-483x(80)90055-4.
Frelin C, Vigne P, Ladoux A, . 1988. The regulation of the intracellular pH in cells from vertebrates. Eur J Biochem 174(1):3–14. 10.1111/j.1432-1033.1988.tb14055.x.2836200
Fujisawa S, Masuhara E. 1981. Determination of partition coefficients of acrylates, methacrylates, and vinyl monomers using high performance liquid chromatography (HPLC). J Biomed Mater Res 15:787–793. 10.1002/jbm.820150603.7309762
Fukami T, Nakajima M, Maruichi T, . 2008. Structure and characterization of human carboxylesterase 1A1, 1A2, and 1A3 genes. Pharmacogenet Genom 18(10):911–920. 10.1097/FPC.0b013e32830b0c5e.
Gage JC. 1970. The subacute inhalation toxicity of 109 industrial chemicals. Br J Ind Med 27:1–18. 10.1136/oem.27.1.1.5418916
Garcia TA. 1988. Fungal degradation of polyvinyl acetate. Ecotoxicol Environ Saf 16:25–35. 10.1016/0147-6513(88)90013-9.3181066
Goeva OE. 1966. [Maximum permissible concentration of vinyl acetate in water basins]. Hyg Sanit 31:209–214. (Russian)
Greń I, Gaszczak A, Guzik U, . 2011. A comparative study of biodegradation of vinyl acetate by environmental strains. Ann Microbiol 61(2):257–265. 10.1007/s13213-010-0130-4.21654921
Gruvberger B, Bruze M, Almgren G. 1998. Occupational dermatoses in a plant producing binders for paints and glues. Contact Dermatitis 38(2):71–77. 10.1111/j.1600-0536.1998.tb05656.x.9506218
Guerin MR. 1980. Chemical composition of cigarette smoke. In: Gori GB, Bock FG, eds. Banbury Report: A safe cigarette? Vol. 3. Proceedings of a Meeting, Cold Spring Harbor, NY, USA, October 14-16, 1979. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 191–204.
Hansch C, Leo AJ. 1979. Vinyl acetate. In: Substituent constants for correlation analysis in chemistry and biology. New York, NY: John Wiley & Sons, 1983.
Hawley GG. 1981. Vinyl acetate. In: The condensed chemical dictionary. 10^th^ ed. New York, NY: Van Nostrand Reinhold Co., 1084.
Hazleton. 1979a. Investigations into the metabolic fate of vinyl acetate in the rat and mouse: Part I. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1979b. Vinyl acetate: 4 week inhalation dose ranging study in the mouse. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1979c. Vinyl acetate: 4 week inhalation dose ranging study in the rat. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1979d. Vinyl acetate: 4 week oral (drinking water) dose range-finding study in the rat and mouse. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1980a. Investigations into the metabolic fate of vinyl acetate in the rat and mouse: Part 2. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1980b. Vinyl acetate: 3 month inhalation toxicity study in the mouse. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1980c. Vinyl acetate: 3 month inhalation toxicity study in the rat. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1980d. Vinyl acetate: oral and inhalation teratology studies in the rat. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1980e. Vinyl acetate: 3 month oral (drinking water) toxicity study in the mouse. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1980f. Vinyl acetate: 3 month oral (drinking water) toxicity study in the rat. The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000278-0. FYI-OTS-0184-0278. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002780.xhtml. September 24, 2024.
Hazleton. 1988. Vinyl acetate: 104 week inhalation combined chronic toxicity and carcinogenicity study in the rat and mouse (Vol. I, II, IV & Vol. I of Amendment to final report, with cover letter 01/31/89). The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8e. OTS0510582. 890000088. 8EHQ01890642.
He SM, Lambert BO. 1985. Induction and persistence of SCE-inducing damage in human lymphocytes exposed to vinyl acetate and acetaldehyde in vitro. Mutat Res 158:201–208. 10.1016/0165-1218(85)90086-2.4079951
Hinderliter PM, Thrall KD, Corley RA, . 2005. Validation of human physiologically based pharmacokinetic model for Vinyl acetate against human nasal dosimetry data. Toxicol Sci 85(1):460–467. 10.1093/toxsci/kfi091.15659566
Hine J, Mookerjee PK. 1975. The intrinsic hydrophilic character of organic compounds. Correlations in terms of structural contributions. J Org Chem 40(3):292–298.
Hodgson AT, Wooley JD, Daisey JM. 1993. Emissions of volatile organic compounds from new carpets measured in a large-scale environmental chamber. Air Waste 43(3):316–324. 10.1080/1073161x.1993.10467136.8457318
Holub I, Tarkowski S. 1982. Hepatic content of free sulfhydryl compounds in animals exposed to vinyl acetate. Int Arch Occup Environ Health 51:185–189. 10.1007/BF00378162.7160917
Howard PH. 1989. Vinyl acetate. In: Handbook of environmental fate and exposure data for organic chemicals: Large production and priority pollutants. Vol. 1. Chelsea, MI: Lewis Publishers, Inc., 545.
Hsiao YC, Liu CW, Hoffman G, . 2022. Molecular dosimetry of DNA adducts in rats exposed to vinyl acetate monomer. Toxicol Sci 185(2):197–207. 10.1093/toxsci/kfab140.34904679
Hughes PC, Tanner JM, Williams JP. 1978. A longitudinal radiographic study of the growth of the rat skull. J Anat 127(Pt 1):83–91.701198
Hurtt ME, Vinegar MB, Rickard RW, . 1995. Developmental toxicity of oral and inhaled vinyl acetate in the rat. Fundam Appl Toxicol 24(2):198–205. 10.1006/faat.1995.1023.7737431
IARC. 1995. Vinyl acetate. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 63. Dry cleaning, some chlorinated solvents and other industrial chemicals. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/81. June 22, 2022.
ICRP. 1994. Human respiratory tract model for radiological protection. Annals of the ICRP. Vol. 24. International Commission on Radiological Protection. ICRP Publication 66. https://www.icrp.org/publication.asp?id=ICRP%20Publication%2066. September 24, 2024.
IRIS. 1990. Vinyl acetate; CASRN 108-05-4. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0512_summary.pdf. June 22, 2022.
ITII. 1982. Toxic and hazardous industrial chemicals safety-manual. Tokyo, Japan: International Technical Information Institute.
Izumi N, Sakai Y, Hasumura Y. 1988. Immune response to acetaldehyde protein adducts in alcoholic liver disease. In: Kuriyama K, Takada A, Ishii H, eds. Biomedical and social aspects of alcohol and alcoholism. Amsterdam, The Netherlands: Elsevier Science Publishers, 335–338.
Jantunen K, Maeki-Paakkanen J, Norppa H. 1986. Induction of chromosome aberrations by styrene and vinyl acetate in cultured human lymphocytes: Dependence on erythrocytes. Mutat Res 159:109–116. 10.1016/0027-5107(86)90119-3.3941660
Joshi SB, Dodge MC, Bufalini JJ. 1982. Reactivities of selected organic compounds and contamination effects. Atmos Environ 16:1301–1310. 10.1016/0004-6981(82)90051-8.
Jung R, Engelhart G, Herbolt B, . 1992. Collaborative study of mutagenicity with Salmonella typhimurium TA102. Mutat Res 278(4):265–270. 10.1016/s0165-1218(10)80006-0.1373863
Kennedy GL, Graepel GJ. 1991. Acute toxicity in the rat following either oral or inhalation exposure. Toxicol Lett 56(3):317–326. 10.1016/0378-4274(91)90160-8.2035177
Khoshakhlagh AH, Saberi HR, Gruszecka-Kosowska A, . 2023. Respiratory functions and health risk assessment in inhalational exposure to vinyl acetate in the process of carpet manufacturing using Monte Carlo simulations. Environ Sci Pollut Res Int 30(12):32560–32572. 10.1007/s11356-022-24469-5.36469263
Knowles SE, Jarrett IG, Filsell OH, . 1974. Production and utilization of acetate in mammals. Biochem J 142(2):401–411. 10.1042/bj1420401.4441381
Krieger SM, Bell MP, Harkema JR, . 2020. Vinyl acetate: evaluation of epithelial cell proliferation in nasal airways of Crl:CD(SD) rats repeatedly exposed to vinyl acetate vapors. The Dow Chemical Company. Study ID: 121019.
Kuykendall JR, Bogdanffy MS. 1992. Reaction kinetics of DNA-histone crosslinking by vinyl acetate and acetaldehyde. Carcinogenesis 13(11):2095–2100. 10.1093/carcin/13.11.2095.1423881
Kuykendall JR, Taylor ML, Bogdanffy MS. 1993. Cytotoxicity and DNA-protein crosslink formation in rat nasal tissues exposed to vinyl acetate are carboxylesterase-mediated. Toxicol Appl Pharmacol 123(2):283–292. 10.1006/taap.1993.1247.8248935
Lahdetie J. 1988. Effects of vinyl acetate and acetaldehyde on sperm morphology and meiotic micronuclei in mice. Mutat Res 202:171–178. 10.1016/0027-5107(88)90179-0.3185588
Laib RJ, Bolt HM. 1986. Vinyl acetate, a structural analog of vinyl carbamate, fails to induce enzyme-altered foci in rat liver. Carcinogenesis 7:841–843. 10.1093/carcin/7.5.841.2870825
Lambert B, Chen Y, He S, . 1985. DNA cross-links in human leucocytes treated with vinyl acetate and acetaldehyde in vitro. Mutat Res 146:301–303. 10.1016/0167-8817(85)90072-0.4058447
Lantz RC, Orozco J, Bogdanffy MS. 2003. Vinyl acetate decreases intracellular pH in rat nasal epithelial cells. Toxicol Sci 75(2):423–431. 10.1093/toxsci/kfg198.12883081
Lee B, Liu JZ, Sun B, . 2008. Thermally conductive and electrically insulating EVA composite encapsulants for solar photovoltaic (PV) cell. Express Polym Lett 2(5):357–363. 10.3144/expresspolymlett.2008.42.
Leonard EC. 1970. Vinyl acetate. In: Vinyl and diene monomers: Part 1. New York, NY: Wiley Interscience, 263–328.
Lijinsky W, Andrews AW. 1980. Mutagenicity of vinyl compounds in Salmonella typhimurium. Teratog Carcinog Mutagenesis 1:259–267. 10.1002/tcm.1770010303.
Lijinsky W, Reuber MD. 1983. Chronic toxicity studies of vinyl acetate in Fischer rats. Toxicol Appl Pharmacol 68:43–53. 10.1016/0041-008x(83)90353-8.6845374
Lin RC, Lumeng L. 1988. Formation of a protein-acetaldehyde adduct in liver in vivo during chronic alcohol ingestion. In: Kuriyama K, Takada A, Ishii H, eds. Biomedical and social aspects of alcohol and alcoholism. Amsterdam, The Netherlands: Elsevier Science Publishers, 325–328.
Liu J, Liang Q, Oldham MJ, . 2017. Determination of selected chemical levels in room air and on surfaces after the use of cartridge- and tank-based E-vapor products or conventional cigarettes. Int J Environ Res Public Health 14(9):969. 10.3390/ijerph14090969.28846634
Liu CW, Hsiao YC, Hoffman G, . 2021. LC-MS/MS analysis of the formation and loss of DNA adducts in rats exposed to vinyl acetate monomer through inhalation. Chem Res Toxicol 34(3):793–803. 10.1021/acs.chemrestox.0c00404.33486946
Llewellyn I, Williams H. 1972. Vinyl acetate homopolymers and copolymers. In: Matthews G, ed. Vinyl and allied polymers. Vol. 2. Cleveland, Ohio: CRC Press, Inc., 362–385.
Mabey W, Mill T. 1978. Critical review of hydrolysis of organic compounds in water under environmental conditions. J Phys Chem Ref Data 7:383–415. 10.1063/1.555572.
Maki-Paakkanen J, Norppa H. 1987. Induction of micronuclei by vinyl acetate in mouse bone marrow cells and cultured human lymphocytes. Mutat Res 190:41–45. 10.1016/0165-7992(87)90080-7.3796670
Maltoni C, Ciliberti A, Lefemine G, . 1997. Results of a long-term experimental study on the carcinogenicity of vinyl acetate monomer in mice. Ann N Y Acad Sci 837:209–238. 10.1111/j.1749-6632.1997.tb56876.x.9472342
Mebus CA, Carpanini FM, Rickard RW, . 1995. A two-generation reproduction study in rats receiving drinking water containing vinyl acetate. Fundam Appl Toxicol 24(2):206–216. 10.1006/faat.1995.1024.7737432
Minardi F, Belpoggi F, Soffritti M, . 2002. Results of long-term carcinogenicity bioassay on vinyl acetate monomer in Sprague-Dawley rats. Ann N Y Acad Sci 982:106–122. 10.1111/j.1749-6632.2002.tb04927.x.12562631
Montana DEQ. 2012. Typical indoor air concentrations of volatile organic compounds in non-smoking Montana residences not impacted by vapor intrusion. Montana Department of Environmental Quality. https://deq.mt.gov/files/Land/StateSuperfund/Documents/VI_guide/CompleteIndoorVOCReport.pdf. May 23, 2022.
Moroni S, Bischi F, Aluigi A, . 2023. 3D printing fabrication of ethylene-vinyl acetate (EVA) based intravaginal rings for antifungal therapy. J Drug Deliv Sci Technol 84:104469. 10.1016/j.jddst.2023.104469.
Morris TD. 1995. Delayed contact hypersensitivity study in guinea pigs (Buehler Technique) of: Vinyl acetate with cover letter dated 5/10/95. Vinyl Acetate Toxicology Group. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8d. OTS0572569. 86950000263. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0572569.xhtml. June 22, 2022.
Morris JB, Hassett DN, Blanchard KT. 1993. A physiologically based pharmacokinetic model for nasal uptake and metabolism of nonreactive vapors. Toxicol Appl Pharmacol 123(1):120–129. 10.1006/taap.1993.1228.8236250
Morris JB, Symanowicz P, Sarangapani R. 2002. Regional distribution and kinetics of vinyl acetate hydrolysis in the oral cavity of the rat and mouse. Toxicol Lett 126(1):31–39. 10.1016/s0378-4274(01)00442-8.11738268
Muller W, Engelhart G, Herbold B, . 1993. Evaluation of mutagenicity testing with Salmonella typhimurium TA102 in three different laboratories. Environ Health Perspect 101(3):33–36. 10.1289/ehp.101-1521147.
Mumtaz MM, Ray M, Crowell SR, . 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, . 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Munch JW, Eichelberger JW. 1992. Evaluation of 48 compounds for possible inclusion in US EPA method 524.2, revision 3.0: Expansion of the method analyte list to a total of 83 compounds. J Chromatogr Sci 30(12):471–477. 10.1093/chromsci/30.12.471.
Mustonen R, Kangas J, Vuojolahti P, . 1986. Effects of phenoxyacetic acids on the induction of chromosome aberrations in vitro and in vivo. Mutagenesis 1(4):241–245. 10.1093/mutage/1.4.241.3331666
Nakamoto T, Wagner M, Melvin JE, . 2005. Vinyl acetate induces intracellular acidification in mouse oral buccal epithelial cells. Toxicol Lett 158(2):116–121. 10.1016/j.toxlet.2005.03.002.16039400
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
NFPA. 1994. Vinyl acetate. In: Fire protection guide on hazardous materials. 7^th^ ed. Boston, MA: National Fire Protection Association, 49–152 to 149–153.
Nieder M, Sunarko B, Meyer O. 1990. Degradation of vinyl acetate by soil, sewage, sludge, and the newly isolated aerobic bacterium V2. Appl Environ Microbiol 56(10):3023–3028. 10.1128/aem.56.10.3023-3028.1990.2285314
NIOSH. 1978. Criteria for a recommended standard: Occupational exposure to vinyl acetate. National Institute for Occupational Safety and Health. PB80176993. DHEW (NIOSH) Publication No. 78-205. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80176993.xhtml. June 22, 2022.
NIOSH. 1983. Health hazard evaluation report: National Starch and Chemical, Meredosia, Illinois. National Institute for Occupational Safety and Health. HETA 82-51-1269. https://www.cdc.gov/niosh/hhe/reports/pdfs/82-51-1269.pdf. July 31, 2023.
NIOSH. 1990. Health hazard evaluation report: A.E. Staley Manufacturing Company, Decatur, Illinois. National Institute for Occupational Safety and Health. HETA 88-348-2081. https://www.cdc.gov/niosh/hhe/reports/pdfs/1988-0348-2081.pdf. July 31, 2023.
NIOSH. 2019. Vinyl acetate. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0656.html. June 22, 2022.
NITE. 2010. Biodegradation in water: screening tests; Vinyl acetate (CASRN 108-05-4). Japan Chemicals Collaborative Knowledge database. National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/template.action?ano=2958&mno=2-0728&cno=108-054&request_locale=en. May 23, 2022.
NLM. 2022. PubChem: Vinyl acetate. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7904. July 29, 2022.
Norppa H, Tursi F, Pfaffli P, . 1985. Chromosome damage induced by vinyl acetate through in vitro formation of acetaldehyde in human lymphocytes and Chinese hamster ovary cells. Cancer Res 45:4816–4821.4027971
Norppa H, Makipaakkanen J, Jantunen K, . 1988. Mutagenicity studies on styrene and vinyl acetate. Ann N Y Acad Sci 534:671–678. 10.1111/j.1749-6632.1988.tb30157.x.3291724
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. September 13, 2024.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2017a. Genetic toxicity evaluation of Vinyl acetate (018-05-4) in micronucleus study A23879 in F344 rats. National Toxicology Program. https://manticore.niehs.nih.gov/cebssearch/test_article/108-05-4. December 06, 2017.
NTP. 2017b. Genetic toxicity evaluation of vinyl acetate in Salmonella/E. coli mutagenicity test or Ames test. Study A99540. National Toxicology Program. https://manticore.niehs.nih.gov/cebssearch/test_article/108-05-4. December 06, 2017.
NTP. 2021. CASRN index. Report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
OSHA. 2023a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol6/pdf/CFR-2023-title29-vol6-sec1910-1000.pdf. September 13, 2024.
OSHA. 2023b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol7/pdf/CFR-2023-title29-vol7-sec1915-1000.pdf. September 13, 2024.
OSHA. 2023c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol8/pdf/CFR-2023-title29-vol8-sec1926-55.pdf. September 13, 2024.
Pahren HR, Bloodgood DE. 1961. Biological oxidation of several vinyl compounds. J Water Pollut Contr Fed 33:233–238.
Peterson CM, Jovanovic-Peterson L, Schmid-Formby F, . 1988. Association of acetaldehyde with hemoglobin and plasma after ethanol: Potential markers of ethanol intake with different kinetics. In: Kuriyama K, Takada A, Ishii H, eds. Biomedical and social aspects of alcohol and alcoholism. Amsterdam, The Netherlands: Elsevier Science Publishers, 321–324.
Picquet-Varrault B, Scarfogliero M, Doussin JF. 2010. Atmospheric reactivity of vinyl acetate: kinetic and mechanistic study of its gas-phase oxidation by OH, O3, and NO3. Environ Sci Technol 44(12):4615–4621. 10.1021/es902037p.20491436
Plowchalk DR, Andersen ME, Bogdanffy MS. 1997. Physiologically based modeling of vinyl acetate uptake, metabolism, and intracellular pH changes in the rat nasal cavity. Toxicol Appl Pharmacol 142(2):386–400. 10.1006/taap.1996.8052.9070362
Price KS, Waggy GT, Conway RA. 1974. Brine shrimp bioassay and seawater BOD of petrochemicals. J Water Pollut Control Fed 46(1):63–77.4812499
Rago R, Rezendes A, Peters J, . 2021. Indoor air background levels of volatile organic compounds and air-phase petroleum hydrocarbons in office buildings and schools. Ground Water Monit Rem 41(2):27–47. 10.1111/gwmr.12433.
RePORTER. 2024. Vinyl acetate. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. September 13, 2024.
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Ruiz P, Ray M, Fisher J, . 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Simon P, Filser JG, Bolt HM. 1985a. Metabolism and pharmacokinetics of vinyl acetate. Arch Toxicol 57:191–195. 10.1007/BF00290886.4062553
Simon P, Ohenwalder H, Bolt HM. 1985b. Vinyl acetate: DNA-binding assay in vivo. Toxicol Lett 27:115–120. 10.1016/0378-4274(85)90128-6.4060182
Sipi P, Jarventaus H, Norppa H. 1992. Sister-chromatid exchanges induced by vinyl esters and respective carboxylic acids in cultured human lymphocytes. Mutat Res 279(2):75–82. 10.1016/0165-1218(92)90248-x.1375341
Slikker W, Andersen ME, Bogdanffy MS, . 2004. Dose-dependent transitions in mechanisms of toxicity: case studies. Toxicol Appl Pharmacol 201(3):226–294. 10.1016/j.taap.2004.06.027.15582646
Smyth HF, Carpenter CP. 1948. Further experience with the range finding test in the industrial toxicology laboratory. J Ind Hyg Toxicol 30:63–68.18895731
Stuckey DC, Owen WF, McCarty PL, . 1980. Anaerobic toxicity evaluation by batch and semi-continuous assays. J Water Pollut Contr Fed 52:720–729.
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press, 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Takeshita T, Iijima S, Higurashi M. 1986. Vinyl acetate-induced sister chromatid exchanges in murine bone marrow cells. Proc Jpn Acad Ser B Phys Biol Sci 62:239–242. 10.2183/pjab.62.239.
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tanaka S, Lucas JB. 1984. Dermatitis in paperhangers. Contact Dermatitis 10:54–55. 10.1111/j.1600-0536.1984.tb00073.x.
Teeguarden JG, Bogdanffy MS, Covington TR, . 2008. A PBPK model for evaluating the impact of aldehyde dehydrogenase polymorphisms on comparative rat and human nasal tissue acetaldehyde dosimetry. Inhal Toxicol 20(4):375–390. 10.1080/08958370801903750.18302046
Thomas RG. 1990. Volatilization from water. In: Lyman WL, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co., 15.11–15.34.
Timchalk C, Kousba AA, Poet TS. 2007. An age-dependent physiologically based pharmacokinetic/pharmacodynamic model for the organophosphorus insecticide chlorpyrifos in the preweanling rat. Toxicol Sci 98(2):348–365. 10.1093/toxsci/kfm119.17504771
TRI23. 2024. Vinyl acetate. TRI search. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. November 9, 2024.
U.S. Coast Guard. 1974. A review of violent monomer polymerization: A selected literature survey. Washington, DC: U.S. Coast Guard. ADA017443. https://apps.dtic.mil/sti/citations/ADA017443. September 13, 2024.
U.S. Coast Guard. 1978. Chemical Hazard Response Information System (CHRIS). Manual 2. Washington, DC: U.S. Coast Guard.
Umeda Y, Matsumoto M, Yamazaki K, . 2004. Carcinogenicity and chronic toxicity in mice and rats administered vinyl acetate monomer in drinking water. J Occup Health 46(2):87–99. 10.1539/joh.46.87.15090683
Union Carbide. 1958. Vinyl acetate H.Q.: Toxicology studies. New York, NY: Union Carbide Corporation.
Union Carbide. 1973. Initial submission: Vinyl acetate: Single animal inhalation and human sensory response with cover letter dated 082792. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0571724. 88920010328. 8EHQ-0992-12090. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0571724.xhtml. June 22, 2022.
Union Carbide. 1989. Lymphatic and hematopoietic tissue cancer in a chemical manufacturing environment, and a mortality study of men assigned to ethylene production or other related chemical manufacturing with cover letter 081789. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0513414-3. 89890000225. 8EHQ-0889-0698. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS05134143.xhtml. June 22, 2022.
USITC. 2024. Vinyl acetate. DataWeb. U.S. International Trade Commission. https://dataweb.usitc.gov/. September 19, 2024.
Valentine R, Bamberger JR, Szostek B, . 2002. Time- and concentration-dependent increases in cell proliferation in rats and mice administered vinyl acetate in drinking water. Toxicol Sci 67(2):190–197. 10.1093/toxsci/67.2.190.12011478
Vasilev D, Havel D, Liebscher S, . 2021. Three water restriction schedules used in rodent behavioral tasks transiently impair growth and differentially evoke a stress hormone response without causing dehydration. eNeuro 8(6):0424. 10.1523/ENEURO.0424-21.2021.
Verschueren K. 1983. Vinyl acetate. In: Handbook of environmental data on organic chemicals. 2^nd^ ed. New York, NY: Van Nostrand Reinhold Co, 633, 1184–1185.
Watanabe K, Sasaki T, Kawakami K. 1998. Comparisons of chemically-induced mutation among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: collaborative study III and evaluation of the usefulness of these strains. Mutat Res 416(3):169–181. 10.1016/s1383-5718(98)00085-0.9729366
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.who.int/publications/i/item/9789289002134. September 13, 2024.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Windholz M. 1983. Vinyl acetate. In: The Merck index. Vol. 10. Rahway, NJ: Merck Co., Inc., 1429.
WQP. 2024. Water Quality Portal data: Vinyl acetate. Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/beta/. September 10, 2024.
Xu A, Fan Z, Chen Z, . 2017. Simultaneous determination of furan and vinyl acetate in vapor phase of mainstream cigarette smoke by GC-MS. An Acad Bras Cienc 89(Suppl 1):383–390. 10.1590/0001-3765201720160230.28492733
Yamada S, Richardson K, Tang M, . 2010. Genetic variation in carboxylesterase genes and susceptibility to isoniazid-induced hepatotoxicity. Pharmacogenomics J 10(6):524–536. 10.1038/tpj.2010.5.20195289
Zhu H, Patrick KS, Yuan H, . 2008. Two CES1 gene mutations lead to dysfunctional carboxylesterase 1 activity in man: Clinical significance and molecular basis. Am J Hum Genet 82(6):1241–1248. 10.1016/j.ajhg.2008.04.015.18485328