# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Rae T. Benedict, Ph.D. (Lead)
  Franco Scinicariello, M.D., M.P.H.
  Carolyn Harper, Ph.D.
  Kambria Haire, M.P.H., Ph.D.
  ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA

- Kimberly Zaccaria, Ph.D., D.A.B.T.
  Frances Belmonte, Ph.D.
  Gary L. Diamond, Ph.D.
  Savannah Sierco, M.S.
  Mario Citra, Ph.D.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Sa Liu, Ph.D., M.P.H., C.I.H.; Assistant Professor; School of Health Sciences; Purdue University; Fellow, Robert Wood Johnson Foundation; Interdisciplinary Research Leaders Cohort 5; West Lafayette, Indiana
2. Ann Verwiel, M.P.P.; Senior Managing Scientist; ToxStrategies, Inc.; San Rafael, California
3. Jordan N. Smith, Ph.D.; Team Lead of Integrated Health Science; Pacific Northwest National Laboratory Chemical Biology and Exposure Science; Richland, Washington
4. Ivan Rusyn, Ph.D.; Professor, Department of Veterinary Integrative Biosciences, College of Vet Medicine & Biomedical Sciences, Texas A&M University, College Station, Texas; peer-review of JRBC (1995) and Krieger et al./Dow (2020) studies only
5. James Bruckner, Ph.D.; Interdisciplinary Toxicology Program, Professor Emeritus, Pharmaceutical & Biomedical Sciences, College of Pharmacy, University of Georgia, Athens, Georgia; peer-review of JRBC (1995) and Krieger et al./Dow (2020) studies only

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.