# VERSION HISTORY

Date | Description
January 2025 | Final toxicological profile released
August 2023 | Draft for public comment toxicological profile released
July 1992 | Final toxicological profile released