# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR VINYL ACETATE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to vinyl acetate.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for vinyl acetate. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as IARC documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of vinyl acetate have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of vinyl acetate are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen^a^

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

a Physical-chemical properties are not generally obtained from literature searches, but rather from curated governmental databases such as PubChem.

### B.1.1 Literature Search

The literature search was conducted to update the Toxicological Profile for Vinyl Acetate released in 1992. All literature cited in the previous (1992) toxicological profile were considered for inclusion in the updated profile. The initial literature search, which was performed in April 2017 and October 2021, was restricted to studies added to databases since January 1990. An updated literature search was performed after the Toxicological Profile for Vinyl Acetate Draft for Public Comment was released in August 2023 to identify any additional studies added to databases between September 2021 and December 2023.

The following main databases were searched in April 2017, October 2021, and December 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER
- National Library of Medicine’s TOXLINE (April 2017 only)

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for vinyl acetate. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to vinyl acetate were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
12/2023 | ((108-05-4[rn] OR “vinyl acetate”[supplementary concept]) AND (2021/09/01:3000[mhda])) OR (((“1-Acetoxyethylene”[tw] OR “Acetate de vinyle”[tw] OR “Acetic acid vinyl ester”[tw] OR “Acetic acid, ethenyl ester”[tw] OR “Acetic acid, ethylene ether”[tw] OR “Acetoxyethene”[tw] OR “Ethanoic acid, ethenyl ester”[tw] OR “Ethenyl acetate”[tw] OR “Ethenyl ethanoate”[tw] OR “Octan winylu”[tw] OR “Vinile (acetato di)”[tw] OR “Vinyl A monomer”[tw] OR “Vinyl acetate”[tw] OR “Vinyl acetate H.Q.”[tw] OR “Vinyl acetate monomer”[tw] OR “Vinyl ethanoate”[tw] OR “Vinylacetaat”[tw] OR “Vinylacetat”[tw] OR “Vinylacetate”[tw] OR “Vinyle (acetate de)”[tw] OR “Vinylester kyseliny octove”[tw] OR “Zeset T”[tw]) AND (2021/09/01:3000[edat] OR 2021/09/01:3000[crdat])) NOT medline[sb])
10/2021 | ((108-05-4[rn] OR L9MK238N77[rn] OR “vinyl acetate”[supplementary concept] OR “vinyl acetate”[nm]) AND (1990/01/01 : 3000[dp] OR 1990/01/01 : 3000[mhda])) OR (((“1-Acetoxyethylene”[tw] OR “Acetate de vinyle”[tw] OR “Acetic acid vinyl ester”[tw] OR “Acetic acid, ethenyl ester”[tw] OR “Acetic acid, ethylene ether”[tw] OR “Acetoxyethene”[tw] OR “Ethanoic acid, ethenyl ester”[tw] OR “Ethenyl acetate”[tw] OR “Ethenyl ethanoate”[tw] OR “Octan winylu”[tw] OR “Vinile (acetato di)”[tw] OR “Vinyl A monomer”[tw] OR “Vinyl acetate”[tw] OR “Vinyl acetate H.Q.”[tw] OR “Vinyl acetate monomer”[tw] OR “Vinyl ethanoate”[tw] OR “Vinylacetaat”[tw] OR “Vinylacetat”[tw] OR “Vinylacetate”[tw] OR “Vinyle (acetate de)”[tw] OR “Vinylester kyseliny octove”[tw] OR “Zeset T”[tw]) AND (1990/01/01 : 3000[dp] OR 1990/01/01 : 3000[crdat] OR 1990/01/01 : 3000[edat])) NOT medline[sb])
NTRL
12/2023 | Limited to date published 2020 to 2023 Searched in title or keyword “1-Acetoxyethylene” OR “Acetate de vinyle” OR “Acetic acid vinyl ester” OR “Acetic acid, ethenyl ester” OR “Acetic acid, ethylene ether” OR “Acetoxyethene” OR “Ethanoic acid, ethenyl ester” OR “Ethenyl acetate” OR “Ethenyl ethanoate” OR “Octan winylu” OR “Vinile (acetato di)” OR “Vinyl A monomer” OR “Vinyl acetate” OR “Vinyl acetate H.Q.” OR “Vinyl acetate monomer” OR “Vinyl ethanoate” OR “Vinylacetaat” OR “Vinylacetat” OR “Vinylacetate” OR “Vinyle (acetate de)” OR “Vinylester kyseliny octove” OR “Zeset T”
10/2021 | “1-Acetoxyethylene” OR “Acetate de vinyle” OR “Acetic acid vinyl ester” OR “Acetic acid, ethenyl ester” OR “Acetic acid, ethylene ether” OR “Acetoxyethene” OR “Ethanoic acid, ethenyl ester” OR “Ethenyl acetate” OR “Ethenyl ethanoate” OR “Octan winylu” OR “Vinile (acetato di)” OR “Vinyl A monomer” OR “Vinyl acetate” OR “Vinyl acetate H.Q.” OR “Vinyl acetate monomer” OR “Vinyl ethanoate” OR “Vinylacetaat” OR “Vinylacetat” OR “Vinylacetate” OR “Vinyle (acetate de)” OR “Vinylester kyseliny octove” OR “Zeset T”
Toxcenter
12/2023 | FILE ‘TOXCENTER’ ENTERED AT 16:48:25 ON 11 DEC 2023
| CHARGED TO COST=ET027.02.08.LB.01
| L1 | 4404 SEA FILE=TOXCENTER 108-05-4
| L2 | 1957 SEA FILE=TOXCENTER L1 NOT PATENT/DT
| L3 | 205 SEA FILE=TOXCENTER L2 AND ED>=20210901
| L38 | 200 DUP REM L3 (5 DUPLICATES REMOVED)
10/2021 | FILE ‘TOXCENTER’ ENTERED AT 11:35:18 ON 01 OCT 2021
| CHARGED TO COST=EH038.10.01.04
| L1 | 3988 SEA 108-05-4
| L2 | 3903 SEA L1 NOT TSCATS/FS
| L3 | 1652 SEA L2 NOT PATENT/DT
| L4 | 284 SEA L3 AND ED>=20170401
| | ACT TOXQUERY/Q
| | -------
| L5 | QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L6 | QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR
| EPIDEMIOLOGY/ST,CT,
| | IT)
| L7 | QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L8 | QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L9 | QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L10 | QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L11 | QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS
| OR
| | DIETARY OR DRINKING(W)WATER?)
| L12 | QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR
| PERMISSIBLE))
| L13 | QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L14 | QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM?
| OR
| | OVUM?)
| L15 | QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L16 | QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L17 | QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI?
| OR SPERMAS? OR
| | SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L18 | QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR
| SPERMATOX? OR
| | SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L19 | QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR
| DEVELOPMENTAL?)
| L20 | QUE (ENDOCRIN? AND DISRUPT?)
| L21 | QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR
| INFANT?)
| L22 | QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?)
| L23 | QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L24 | QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER?
| OR
| | NEOPLAS?)
| L25 | QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR
| CARCINOM?)
| L26 | QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR
| GENETIC(W)TOXIC?)
| L27 | QUE (NEPHROTOX? OR HEPATOTOX?)
| L28 | QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L29 | QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L30 | QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29
| L31 | QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR
| MURIDAE
| | OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR
| SWINE
| | OR PORCINE OR MONKEY? OR MACAQUE?)
| L32 | QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR
| LAGOMORPHA
| | OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L33 | QUE L30 OR L31 OR L32
| L34 | QUE (NONHUMAN MAMMALS)/ORGN
| L35 | QUE L33 OR L34
| L36 | QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL?
| OR
| | PRIMATES OR PRIMATE?)
| L37 | QUE L35 OR L36
| | -------
| L38 | 128 SEA L4 AND L37
| L39 | 11 SEA L38 AND MEDLINE/FS
| L40 | 2 SEA L38 AND BIOSIS/FS
| L41 | 115 SEA L38 AND CAPLUS/FS
| L42 | 0 SEA L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS)
| L43 | 127 DUP REM L39 L40 L41 (1 DUPLICATE REMOVED)
| L*** DEL | 11 S L38 AND MEDLINE/FS
| L*** DEL | 11 S L38 AND MEDLINE/FS
| L44 | 11 SEA L43
| L*** DEL | 2 S L38 AND BIOSIS/FS
| L*** DEL | 2 S L38 AND BIOSIS/FS
| L45 | 2 SEA L43
| L*** DEL | 115 S L38 AND CAPLUS/FS
| L*** DEL | 115 S L38 AND CAPLUS/FS
| L46 | 114 SEA L43
| L47 | 116 SEA (L44 OR L45 OR L46) NOT MEDLINE/FS
| | SAVE TEMP L47 VINYLACETATE/A
| | D SCAN L47
| FILE HOME
| FILE TOXCENTER
04/2017 | (FILE ‘HOME’ ENTERED AT 12:26:28 ON 07 APR 2017)
| FILE ‘TOXCENTER’ ENTERED AT 12:26:47 ON 07 APR 2017
| | CHARGED TO COST=EH011.13.01.01
| L1 | 2765 SEA 108-05-4
| L2 | 2680 SEA L1 NOT TSCATS/FS
| L3 | 1221 SEA L2 NOT PATENT/DT
| L4 | 2125 SEA L1 AND PY>=1990
| L5 | 795 SEA L3 AND PY>=1990
| | ACTIVATE TOXQUERY/Q
| | -------
| L6 | QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L7 | QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR
| EPIDEMIOLOGY/ST,CT,
| | IT)
| L8 | QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L9 | QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L10 | QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L11 | QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L12 | QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS
| OR
| | DIETARY OR DRINKING(W)WATER?)
| L13 | QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR
| PERMISSIBLE))
| L14 | QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L15 | QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM?
| OR
| | OVUM?)
| L16 | QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L17 | QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L18 | QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR
| SPERMAS? OR
| | SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L19 | QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR
| SPERMATOX? OR
| | SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L20 | QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR
| DEVELOPMENTAL?)
| L21 | QUE (ENDOCRIN? AND DISRUPT?)
| L22 | QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR
| INFANT?)
| L23 | QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?)
| L24 | QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L25 | QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER?
| OR
| | NEOPLAS?)
| L26 | QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR
| CARCINOM?)
| L27 | QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR
| GENETIC(W)TOXIC?)
| L28 | QUE (NEPHROTOX? OR HEPATOTOX?)
| L29 | QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L30 | QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L31 | QUE L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30
| L32 | QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR
| MURIDAE
| | OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR
| SWINE
| | OR PORCINE OR MONKEY? OR MACAQUE?)
| L33 | QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR
| LAGOMORPHA
| | OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L34 | QUE L31 OR L32 OR L33
| L35 | QUE (NONHUMAN MAMMALS)/ORGN
| L36 | QUE L34 OR L35
| L37 | QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL?
| OR
| | PRIMATES OR PRIMATE?)
| L38 | QUE L36 OR L37
| | -------
| L39 | 382 SEA L5 AND L38
| L40 | 43 SEA L39 AND MEDLINE/FS
| L41 | 48 SEA L39 AND BIOSIS/FS
| L42 | 274 SEA L39 AND CAPLUS/FS
| L43 | 71 SEA L39 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS)
| L44 | 323 DUP REM L40 L41 L43 L42 (59 DUPLICATES REMOVED)
| L*** DEL | 43 S L39 AND MEDLINE/FS
| L*** DEL | 43 S L39 AND MEDLINE/FS
| L45 | 43 SEA L44
| L*** DEL | 48 S L39 AND BIOSIS/FS
| L*** DEL | 48 S L39 AND BIOSIS/FS
| L46 | 30 SEA L44
| L*** DEL | 274 S L39 AND CAPLUS/FS
| L*** DEL | 274 S L39 AND CAPLUS/FS
| L47 | 235 SEA L44
| L*** DEL | 17 S L39 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS)
| L*** DEL | 17 S L39 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS)
| L48 | 15 SEA L44
| L49 | 280 SEA (L45 OR L46 OR L47 OR L48) NOT MEDLINE/FS
Toxline
04/2017 | ( “1-acetoxyethylene” OR “acetate de vinyle” OR “acetic acid vinyl ester” OR “acetic acid ethenyl ester” OR “acetic acid ethylene ether” OR “acetoxyethene” OR “ethanoic acid ethenyl ester” OR “ethenyl acetate” OR “ethenyl ethanoate” OR “octan winylu” OR “vinile ( acetato di )” OR “vinyl a monomer” OR “vinyl acetate” OR “vinyl acetate h q” OR “vinyl acetate monomer” OR “vinyl ethanoate” OR “vinylacetaat” OR “vinylacetat” OR “vinylacetate” OR “vinyle ( acetate de )” OR “vinylester kyseliny octove” OR “zeset t” OR 108-05-4 [rn] ) AND 1990:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via
ChemView
12/2023; 10/2021 | Compounds searched: 108-05-4
NTP
12/2023 | Limited 2020-present
| 108-05-4
| “Vinyl acetate”
| “Vinylacetate”
| “Acetic acid, ethenyl ester”
| “1-Acetoxyethylene” “Acetic acid vinyl ester” “Acetic acid, ethylene ether”
| “Acetoxyethene”
| “Ethanoic acid, ethenyl ester” “Ethenyl acetate” “Vinyl A monomer” “Vinyl ethanoate”
10/2021 | “108-05-4” “Vinyl acetate” “Vinylacetate” “Acetic acid, ethenyl ester”
| “1-Acetoxyethylene” “Acetic acid vinyl ester” “Acetic acid, ethylene ether”
| “Acetoxyethene”
| “Ethanoic acid, ethenyl ester” “Ethenyl acetate” “Vinyl A monomer” “Vinyl ethanoate”
Regulations.gov
12/2023 | “108-05-4”
| “Vinyl acetate”
| “Vinylacetate”
| No date limit; Docket and EPA notices
NIH RePORTER
09/11/2024 | Fiscal Year: Active Projects Text Search: “1-Acetoxyethylene” OR “Acetate de vinyle” OR “Acetic acid vinyl ester” OR “Acetic acid, ethenyl ester” OR “Acetic acid, ethylene ether” OR “Acetoxyethene” OR “Ethanoic acid, ethenyl ester” OR “Ethenyl acetate” OR “Ethenyl ethanoate” OR “Octan winylu” OR “Vinile (acetato di)” OR “Vinyl A monomer” OR “Vinyl acetate” OR “Vinyl acetate H.Q.” OR “Vinyl acetate monomer” OR “Vinyl ethanoate” OR “Vinylacetaat” OR “Vinylacetat” OR “Vinylacetate” OR “Vinyle (acetate de)” OR “Vinylester kyseliny octove” OR “Zeset T” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
06/2022 | Text Search: “1-Acetoxyethylene” OR “Acetate de vinyle” OR “Acetic acid vinyl ester” OR “Acetic acid, ethenyl ester” OR “Acetic acid, ethylene ether” OR “Acetoxyethene” OR “Ethanoic acid, ethenyl ester” OR “Ethenyl acetate” OR “Ethenyl ethanoate” OR “Octan winylu” OR “Vinile (acetato di)” OR “Vinyl A monomer” OR “Vinyl acetate” OR “Vinyl acetate H.Q.” OR “Vinyl acetate monomer” OR “Vinyl ethanoate” OR “Vinylacetaat” OR “Vinylacetat” OR “Vinylacetate” OR “Vinyle (acetate de)” OR “Vinylester kyseliny octove” OR “Zeset T”; (advanced); Limit to: Project Title, Project Terms, Project Abstracts
Other | Includes additional reference identified throughout the assessment process, which may include studies found by tree searching; recommended by intraagency, interagency, peer, or public reviewers; or published more recently than the date of literature search(es). Additional references include those for specific regulations or guidelines and publications found by targeted searches for specific information (e.g., searches for reviews of general [not chemical-specific] mechanisms of toxicity).

The 2021 pre-public comment search results were:

- Number of records identified from PubMed, NTRL, TOXCENTER, and Toxline (after duplicate removal): 1,491
- Number of records identified from other strategies: 76
- Total number of records to undergo literature screening: 1,567

The 2023 post-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 456
- Number of records identified from other strategies: 36
- Total number of records to undergo literature screening: 492

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on vinyl acetate during the pre- and post-public comment drafts:

- Title and abstract screen
- Full text screen

Pre-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 1,567
- Number of studies considered relevant and moved to the next step: 129

Pre-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 129
- Number of studies cited in the previous toxicological profile: 84
- Total number of studies cited in the profile: 188

A summary of the results of the pre-public literature search and screening is presented in Figure B-1.

Figure B-1 October 2021 Literature Search Results and Screen for Vinyl Acetate

*The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.

Post-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 492
- Number of studies considered relevant and moved to the next step: 46

Post-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 46
- Number of studies cited in the pre-public draft of the toxicological profile: 188
- Total number of studies cited in the profile: 201

A summary of the results of the post-public comment literature search and screening is presented in Figure B-2.

Figure B-2 December 2023 Post-Public Comment Literature Search Results and Screen for Vinyl Acetate^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.