# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Vinyl acetate Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl acetate
CAS Numbers: | 108-05-4
Date: | January 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL | 1 ppm (3.5 mg/m^3^)
Critical Effect: | Nasal lesions
Reference: | Bogdanffy et al. 1997
Point of Departure: | NOAEL of 199.6 ppm (NOAEL_HEC_ of 29.1 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 2
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 1 ppm was derived for vinyl acetate based on nasal lesions in male rats exposed to concentrations ≥598.5 ppm for 6 hours/day for 5 days; a NOAEL of 199.6 ppm was identified (Bogdanffy et al. 1997). The MRL is based on a NOAEL_HEC_ of 29.1 ppm derived using the PBPK model by Bogdanffy et al. (1999). The NOAEL_HEC_ was divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available acute-duration inhalation studies report vinyl acetate-related effects at LOAELs in the range of 598.5–1,007.3 ppm, including respiratory effects in rats and mice and body weight and developmental effects in rats (Table A-1). The lowest identified LOAEL is for damage to the upper respiratory tract in rats, with 100% incidence of nasal lesions in rats exposed to ≥598.5 ppm for 6 hours/day for 1 or 5 days (Bogdanffy et al. 1997). While this study did not look at a comprehensive set of endpoints, data from intermediate- and chronic-duration studies, as well as mechanistic data, support that the nasal cavity is the most sensitive target following inhalation exposure (see Other Additional Studies of Pertinent Information that Lend Support to this MRL below). Based on these data, the nasal cavity lesions are selected as the critical effect.

Selection of the Principal Study: Bogdanffy et al. (1997) was selected as the principal study because it provided the lowest point of departure (POD) for the critical effect (nasal cavity lesions). The 5-day study was selected over the 1-day study since observed severity of nasal lesions increased over the 5-day exposure period.

Table A-1 Select NOAEL and LOAEL Values in Animals Following Acute-Duration Inhalation Exposure to Vinyl Acetate

Species | Duration | NOAEL/LOAEL (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Respiratory
Rat (SD) | 6 hours (WB) | 199.6 | 598.5 | Minimal-to-moderate nasal cavity lesions, cell proliferation in nasal epithelium | Bogdanffy et al. 1997
Rat (SD) | 5 days; 6 hours/day (WB) | 199.6 | 598.5 | Mild-to-severe nasal cavity lesions^a^ | Bogdanffy et al. 1997
Rat (SD) | 6 hours (WB) | 201.6 | 604.8 | Slight-to-marked degeneration/necrosis of nasal tissue (primarily proximal olfactory epithelium) | Krieger et al. 2020
Rat (SD) | 5 days; 6 hours/day (WB) | 201.6 | 604.8 | Slight-to-moderate atrophy and necrosis of nasal tissue | Krieger et al. 2020
Mouse (NS) | 4 hours (WB) | 410 | 820 | Labored breathing | Union Carbide 1973
Body weight
Rat (SD) | 10 days; GDs 6–15; 6 hours/day (WB) | 197.5 | 1,005 | 9–12% decrease in maternal body weight on GDs 10–20 | Hurtt et al. 1995; Hazleton 1980d
Rat (SD) | 5 days; 6 hours/day (WB) | 598.5 | 1,007.3 | 14% decrease in body weight | Bogdanffy et al. 1997
Developmental
Rat (SD) | 10 days; GDs 6–15; 6 hours/day (WB) | 197.5 | 1,005 | 28% decrease in fetal weight; 12% decrease in crown-to-rump-length, delayed ossification; associated with maternal body weight decreases | Hurtt et al. 1995; Hazleton 1980d

a Selected study/endpoint for derivation of acute-duration inhalation MRL.

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; NS = not specified; SD = Sprague-Dawley; (WB) = whole-body exposure

Summary of the Principal Study:

Bogdanffy MS, Gladnick NL, Kegelman T, . 1997. Four-week inhalation cell proliferation study of the effects of vinyl acetate on rat nasal epithelium. Inhal Toxicol 9(4):331–350. 10.1080/089583797198178.

Groups of male Sprague-Dawley (Crl:CD BR) rats (5/group) were exposed to 0, 50, 200, 600, or 1,000 ppm for 5 consecutive days (6 hours/day); analytical concentrations (± standard error [SE]) were 0±0, 50.8±0.7, 199.6±5.3, 598.5±6.4, and 1,007.3±11.0 ppm, respectively. Rats were observed for clinical signs and weighed 3 times/week. Sixteen hours after exposure, rats were injected with bromodeoxyuridine (BrdU) to assess cell proliferation and sacrificed 2 hours later. Respiratory tract tissues were examined for gross alterations, and nasal cavities were dissected and cut into five cross sections for histopathological analysis. Immunocytochemistry was performed for BrdU analysis of Level 2, the region with the most observed damage.

Body weights were statistically significantly decreased by 14% on day 5. No gross lesions were observed. Olfactory epithelium regenerative hyperplasia was observed in Levels 2, 3, and 5 in all rats at 598.5 and 1,007.3 ppm and 4/5 and 5/5 rats in Level 4. The most severe lesions were observed in the second and third levels (mild to severe). Increased incidence of minimal degeneration/necrosis of the olfactory epithelium were also observed in Levels 4 and 5. Incidence and severity of respiratory epithelium lesions were low across all groups. No significant changes in cell proliferation were observed.

Selection of the Point of Departure for the MRL: Bogdanffy et al. (1997) identified a NOAEL of 199.6 ppm for nasal lesions in rats following exposure to vinyl acetate for 5 days (6 hours/day). The available data in Bogdanffy et al. (1997) are not amenable to benchmark dose (BMD) modeling because incidences go from 0% at the NOAEL to 100% at the LOAEL for the most sensitive nasal lesions. Therefore, the NOAEL of 199.6 ppm is selected as the POD.

Adjustment for Intermittent Exposure: Exposure over time is accounted for in the PBPK model (HEC simulations are for continuous exposure, see details below); therefore, no additional duration adjustment is needed.

Conversion to Human Equivalent Concentration: A PBPK model (Bogdanffy et al. 1999; Hinderliter et al. 2005) was used for rat-to-human dosimetry extrapolation in deriving the acute-duration inhalation MRL for vinyl acetate. A description of the model can be found in Section 3.1.5 of the profile. This model was selected for dosimetry extrapolation because it has been shown to reliably simulate the kinetics of vinyl acetate uptake and metabolism in the nasal cavity of rats and humans (Bogdanffy et al. 1999; Hinderliter et al. 2005). Important features of vinyl acetate-induced nasal lesions and vinyl acetate kinetics that are relevant to interspecies dosimetry extrapolation include: (1) regional gradients of nasal lesions to the olfactory epithelium, with more severe lesions occurring in the anterior regions (Bogdanffy et al. 1994a, 1997); (2) nearly 100% first-pass extraction of vinyl acetate from inspired air at low concentrations which saturates at higher concentrations (Plowchalk et al. 1997); and (3) intracellular acidification resulting from metabolism of vinyl acetate to acetic acid (Bogdanffy 2002). In the derivation of inhalation MRLs, the PBPK model was used to simulate the acetic acid dose to the surficial layers of the olfactory epithelium in the anterior region of the rat and human nasal cavities. The dose metric used for interspecies dosimetry extrapolation was the area under the curve (AUC) for the acetic acid concentration. The AUC was selected based on evidence that the nature and severity of the nasal lesions in rats change with increasing duration of exposure to vinyl acetate (Bogdanffy et al. 1997; see further discussion of the selection of the dose metric below).

Implementation of the Bogdanffy et al. (1999; Hinderliter et al. 2005) Model

Source and verification of model code. Code for implementing the human vinyl acetate model in Advance Continuous Simulation Language (ASCL) was reported in Hinderliter et al. (2005). For simulations run to support derivation of MRLs, the ACSL code was migrated to Magnolia (v1.3.9 beta). Performance of the Magnolia code was confirmed by comparing predictions with those from the ACSL code reported in Table 2 of Bogdanffy et al. (1999). Examples of these comparisons are presented in Figure A-1, Panel A. The code for the rat model described in Bogdanffy et al. (1999) has not been published; however, the human model was revised to recreate the rat model via addition of a second (posterior) olfactory compartment that is present in rats, but not in humans. Parameter values for the rat model were based on those reported in Bogdanffy et al. (1999) and Plowchalk et al. (1997). Performance of the Magnolia code for the rat model was confirmed by comparing predictions with those from the ACSL model reported in Table 2 of Bogdanffy et al. (1999). Examples of these comparisons are presented in Figure A-1, Panel B. Figure A-1 shows the non-linear relationship between the vinyl acetate exposure concentration and the AUC for the acetic acid concentration in olfactory tissue that results from capacity limited metabolism of vinyl acetate (see Section 3.1.3 of the profile).

Figure A-1 Area Under the Curve for Acetic Acid Concentration in Human (A) and Rat (B) Olfactory Epithelium Predicted by the Physiologically Based Pharmacokinetic (PBPK) Model^*^ * Shown are predictions from the ACSL model reported in Table 2 of Bogdanffy et al. (1999) and from the Magnolia version of the model. The simulations are of a continuous 60-hour exposure to vinyl acetate and an inspiratory flow of 197 mg/minute for rats and 7.5 L/minute for humans.

Revisions to the rat model. In addition to including the second olfactory compartment in the rat model, parameters were introduced into the rat model to simulate body weight-dependence of the nasal cavity air flow (model variable qin). The Bogdanffy et al. (1999) model parameter value for nasal air flow was the air inspiration rate for a 0.25 kg body weight male rat (197 mL/minute; 11,820 mL/hour). However, in deriving MRLs, simulations were needed for rats having different body weights. The inspiration rate (mL/hour) in rats is dependent on body weight. Therefore, body weight dependence of nasal cavity air flow was simulated in the Magnolia code using an allometric relationship derived for inspiration rate in the male Fischer rat (EPA 1988):

q i n = 0.80 ⋅ b w^0.8206^

where qin is the modal parameter for nasal air flow (m^3^/day) and bw is body weight (kg). The conversion to mL/hour for use in the model is 1,000,000/24. This yields a value for qin of 0.271 m^3^/day and 11,279 mL/hour for a 0.25-kg rat, which is 4.5% lower than the value used in Bogdanffy et al. (1999).

Uncertainties regarding relationship between body weight and size of nasal tissue compartments. In simulations run to support derivation of inhalation MRLs, dimensions of nasal cavity tissue compartments (surface area, depth) in the rat were assumed to be independent of body weight over the range of body weights simulated in derivation of MRLs (0.2–0.6 kg). This assumption precluded having to develop a model for nasal cavity tissue growth. The assumption appears to be reasonable for simulating rats having body weights >0.25 kg. Viscerocranial growth (nose length) in hooded laboratory rats was shown to be complete by age 80 days postconception (~58 days postpartum), with relatively little growth beyond age 50 days (see Figure 3 of Hughes et al. 1978). At age 50 days (postpartum), the average body weight of male and female Sprague-Dawley is approximately 0.26 kg (Timchalk et al. 2007), which is close to the value assumed in the Bogdanffy et al. (1997) model (0.25 kg). The Hughes et al. (1978) observations are for viscerocranial length, and do not necessarily reflect growth of the nasal cavity tissues; it is possible that surface area or depth of nasal cavity tissues could change independently of viscerocranial length. The assumption of independence of nasal cavity dimensions and body weight introduces some uncertainty into predictions of nasal olfactory tissue doses, particularly in simulations of rats having body weights <0.25 kg (e.g., rat body weights during the first two weeks of exposure in the Bogdanffy et al. 1997 inhalation toxicity studies).

Simulation of olfactory tissue dosimetry in derivation of MRLs. The dose metric used in dosimetry extrapolation was the AUC for the acetic acid concentration in the surficial layers of the anterior olfactory epithelium. This dose metric was selected for the following reasons:

1. Acetic acid was selected because it is considered to be crucial in the mode of action of vinyl acetate. The mode of action is thought to be intracellular acidification resulting from metabolism of vinyl acetate to acetic acid (Bogdanffy 2002).
2. The AUC for acetic acid concentration was selected based on evidence that the severity of lesions in the olfactory epithelium of rats exposed to vinyl acetate is affected by exposure concentration and duration (Bogdanffy et al. 1994a, 1997). Therefore, a cumulative dose metric was considered to be a more appropriate internal dose metric for olfactory tissue than a mean or peak tissue concentration. The PBPK model predicts a steady state acetic acid concentration in olfactory tissue after 1 hour of exposure. As a result, the predicted olfactory concentration is independent of exposure duration for exposures >1 hour, while the AUC increases with increasing exposure duration.
3. The anterior olfactory tissue compartment was selected because it is predicted to receive the highest acetic acid doses during inhalation as a result of anterior-to-posterior air flow and clearance of vinyl acetate and metabolites along the air pathway. This pattern of internal dose is consistent with observations of regional gradients of lesions to the olfactory epithelium, with more severe lesions occurring in the anterior regions (Bogdanffy et al. 1994a, 1997).
4. The surficial region of the rat olfactory epithelium was selected because it is predicted to receive the highest tissue dose as a result of diffusive clearance and metabolism of acetic acid in the surficial layer which limits the concentration experienced by irrepressibly deeper layers (Bogdanffy et al. 1999).

Due to the complexity of the PBPK model to estimate the HEC value, it is impractical to list all the equations and parameters used in the simulations. ATSDR can provide the Magnolia source code and parameter values (based on Bogdanffy et al. 1999 and Plowchalk et al. 1997) upon request. An example of a simulation of the acetic acid concentration in the surficial layer of olfactory epithelium in rats exposed to vinyl acetate, 6 hours/day, 5 days/week for 4 weeks (Bogdanffy et al. 1997) is presented in Figure A-2 (Panel A). The model predicts two patterns of periodicity in the olfactory tissue concentration during this toxicity study. The first pattern appears daily with the attainment of steady state and complete clearance following cessation of each daily exposure. This daily pattern is repeated during each week of exposure (168 hours, inclusive of exposed plus unexposed hours during each weekly interval). The AUC for the acetic acid concentration shows a corresponding pattern of step increases in the AUC during each week of exposure (Figure A-2, Panel B). Because of the complete clearance of acetic acid between exposures, there is no accumulation of acetic acid with increasing exposure duration. As a result, the AUC for durations of more than 1 week (AUC_x wks_) at the same exposure frequency (6 hours/day, 5 day/week) is predicted by the AUC for the first week (AUC_168hr_) times the number of weeks:

A U C_x w k s_ = A U C_168 h r_ ⋅ x

equation indicates that, for exposures that have durations of multiple weeks, the number of weeks included in the calculation of the AUC will transform the dose axis of the dose-response relationship without changing its shape on the response axis. Therefore, the AUC_168hr_ can be used as the dose-response metric in continuous-exposure dosimetry extrapolation for studies of any duration in which the exposure frequency was 6 hours/day, 5 days/week, including a single-week (5-day) study (Bogdanffy et al. 1994a, 1997).

Figure A-2 Concentration (A) and AUC_168hr_ (B) for Acetic Acid (AC) in Olfactory Epithelium for Rats Predicted by the Physiologically Based Pharmacokinetic Model^*^ * The simulations are of 4 weeks of exposure to 50 ppm vinyl acetate for 6 hours/day, 5 days/week (Bogdanffy et al. 1997).

Figure A-3 (Panel A) shows the AUC_168hr_ predicted for rats exposed 6 hours/day, 5 days/week in the Bogdanffy et al. (1997) 4-week toxicity study. Figure A-3 (Panel B) shows the corresponding AUC_168hr_ predicted for humans exposed continuously to the same concentrations of vinyl acetate based on the PBPK model developed by Bogdanffy et al. (1999; Hinderliter et al. 2005). Using this model, the human is predicted to experience a 10-fold higher AUC for acetic acid concentration in olfactory tissue than the rat. This prediction applies only to exposures that occur when ventilation is restricted to nasal breathing and reflects the higher ratio of the nasal passage surface area to ventilation volume in the rat compared to the adult human. The Bogdanffy et al. (1997) model cannot be used to predict dosimetry in infants or children without reevaluating all parameters and assigning values (e.g., ventilation rate) that represent specific pre-adult life stages. It is also noted that this model does not account for situations in which nasal exposure would be lower when ventilation in the human occurs from a mix of nasal and oral breathing (e.g., during moderate to heavy exercise or in people who habitually breathe through their mouth) (ICRP 1994). This introduces some uncertainty in animal-to-human extrapolations since rodents are obligate nasal breathers (EPA 1994).

Figure A-3 AUC_168hr_ for Acetic Acid (AC) in Olfactory Epithelium for Rats (A) and Humans (B) Predicted by the Physiologically Based Pharmacokinetic Model^*^ * The simulations are of 4 weeks of exposure for 6 hours/day, 5 days/week in rats (Bogdanffy et al. 1997) and continuous exposure in humans.

HECs that are pharmacokinetically equivalent to PODs (e.g., AUC_168hr_ POD) were computed by reverse dosimetry simulations using the human PBPK model. In these simulations, the human model was run over a range of vinyl acetate exposure concentrations to determine the exposure concentration that corresponded to the AUC_168hr_ POD. The study-specific parameters utilized in the PBPK model to calculate a NOAEL_HEC_ of 29.1 ppm for the selected POD are shown in Table A-2. As previously indicated, all model parameters were based on values reported by Bogdanffy et al. (1999) and Plowchalk et al. (1997), with the exception of body weights, which were based on TWA body weights calculated for the principal study.

Table A-2 HECs Corresponding to the Rat POD Selected for Acute-Duration Inhalation MRL for Vinyl Acetate

Study | Exposure (ppm) | Duration and frequency | POD basis | POD metric | POD (hour μg/mL) | HEC^a^ (ppm)
Bogdanffy et al. (1997) | 0, 50.8, 199.6, 598.5, 1,007.3 | 5 days; 6 hours/day | NOAEL (199.6 ppm) | AUC_168 hr_ | 6,175 | 29.1

a Calculated for continuous human exposure.

AUC = area under the curve for acetic acid concentration in olfactory epithelium; HEC = human equivalent exposure concentration; MRL = Minimal Risk Level; NOAEL = no-observed adverse effect level; POD = dose-response point of departure

Uncertainty Factor: The NOAEL_HEC_ was then by divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

M R L = (N O A E L_H E C_)/(U F s) = (29.1 p p m)/(30) = 1 p p m

Other Additional Studies of Pertinent Information that Lend Support to this MRL: Limited evidence from humans has shown that the respiratory tract is a sensitive target of acute-duration vinyl acetate exposure, with irritation of throat mucous membranes from acute-duration exposure levels as low as 4 ppm and persistent irritation at 74 ppm (Deese and Joyner 1969; Union Carbide 1973). The intermediate- and chronic-duration databases confirm that the respiratory system, particularly the extrathoracic region, is the most sensitive target of toxicity following inhalation exposure to vinyl acetate. Nasal lesions are observed in rats following intermediate-duration exposure to ≥598.5 ppm (Bogdanffy et al. 1997; Krieger et al. 2020) and in rats and mice following chronic-duration exposure to ≥200.5 ppm (Bogdanffy et al. 1994a; Hazleton 1988). Lower respiratory tract lesions are also seen in rats and mice following intermediate-duration exposure to 998.9 ppm (Hazleton 1980b, 1980c) and mice following chronic-duration exposure to ≥200.5 ppm (Bogdanffy et al. 1994a; Hazleton 1988). In acute-duration inhalation lethality studies, deaths were attributed to lung damage in rats, mice, guinea pigs, and rabbits (Union Carbide 1973). Mechanistic data predict portal-of-entry effects (i.e., respiratory tract lesions) based on rapid hydrolysis of vinyl acetate into acetaldehyde and acetic acid following contact with mucosal surfaces, resulting in irritation due to tissue acidification (Bogdanffy et al. 1999, 2001, 2004; Slikker et al. 2004).

Agency Contacts (Chemical Managers): Rae T. Benedict

## Vinyl acetate Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl acetate
CAS Numbers: | 108-05-4
Date: | January 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL | 0.7 ppm (2.5 mg/m^3^)
Critical Effect: | Nasal lesions
Reference: | Bogdanffy et al. 1997
Point of Departure: | NOAEL of 199.6 ppm (NOAEL_HEC_ of 21.6 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 11
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.7 ppm was derived for vinyl acetate based on nasal lesions in male rats exposed to concentrations ≥598.5 ppm for 4 weeks (6 hours/day, 5 days/week); a NOAEL of 199.6 ppm was identified (Bogdanffy et al. 1997). The MRL is based on a NOAEL_HEC_ of 21.6 ppm derived using the PBPK model by Bogdanffy et al. (1999). The NOAEL_HEC_ was divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available intermediate-duration inhalation studies for vinyl acetate consistently report exposure-related respiratory and body weight effects in rats and mice at LOAELs in the range of 497.6–998.9 and 998.9–1,007.3 ppm, respectively (Table A-3). One study in rats reported neurological effects (degeneration/atrophy of olfactory nerve bundles) at 598.8 ppm; however, this effect was not noted in other studies in rats and mice (Table A-3). Respiratory effects are considered the most sensitive effect, with clinical signs (intermittent respiratory distress) at ≥497.6 ppm, nasal lesions at ≥598.5 ppm, and lower respiratory tract lesions at 998.9 ppm. While intermittent respiratory distress is reported at a slightly lower administered concentration, compared to nasal lesions, confidence in this endpoint is low due to intermittent nature (decreasing over the course of treatment), lack of incidence data, lack of concurrent histopathological evaluation, and lack of observation in chronic-duration studies. In contrast, the upper respiratory system (nasal cavity) is a clear target of vinyl acetate toxicity following acute-, intermediate-, and chronic-duration inhalation exposure. Therefore, nasal cavity lesions were selected as the critical effect for derivation of the intermediate-duration inhalation MRL.

Selection of the Principal Study: The 4-week rat study (Bogdanffy et al. 1997) was selected as the principal study because it provides the lowest LOAEL for the critical effect (nasal lesions) following intermediate-duration inhalation exposure. While the NOAEL for nasal lesions is similar in rats and mice, the rat is more sensitive to nasal toxicity, showing higher incidence (100%) and more severe effects (atrophy, hyperplasia) at the LOAEL of 598.5 ppm compared to mice (70% incidence of rhinitis at the LOAEL of 998.9 ppm). Additionally, a PBPK model estimating olfactory epithelium exposure metrics in rats and humans is available (Bogdanffy et al. 1999; Hinderliter et al. 2005). Use of a PBPK model will result in a higher confidence in the HEC calculation in rats, compared to use of a default HEC concentration for mice based on the regional gas dose ratio (RGDR) recommended by the EPA (1994).

Table A-3 Select NOAEL and LOAEL Values in Animals Following Intermediate-Duration Inhalation Exposure to Vinyl Acetate

Species | Duration | NOAEL/LOAEL (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Respiratory
Rat (SD) | 4 weeks; 5 days/week; 6 hours/day (WB) | 150.5 | 497.6 | Intermittent respiratory distress (histology not evaluated) | Hazleton 1979c
Mouse (CD-1) | 4 weeks; 5 days/week; 6 hours/day (WB) | 150.5 | 497.6 | Intermittent respiratory distress (histology not evaluated) | Hazleton 1979b
Rat (SD) | 4 weeks; 5 days/week; 6 hours/day (WB) | 199.6 | 598.5 | Nasal lesions^a^ | Bogdanffy et al. 1997
Rat (SD) | 4 weeks; 5 days/week; 6 hours/day (WB) | 201.6 | 604.8 | Slight-to-marked atrophy of the olfactory epithelium; minimal-to-mild transitional hyperplasia and slight respiratory metaplasia of nasal tissue | Krieger et al. 2020
Rat (SD) | 13 weeks; 5 days/week; 6 hours/day (WB) | 201.6 | 604.8 | Slight-to-marked atrophy and necrosis/degeneration of the olfactory epithelium; slight respiratory metaplasia of nasal tissue | Krieger et al. 2020
Rat (SD) | 3 months; 5 days/week; 6 hours/day (WB) | 199.9 | 998.9 | Intermittent respiratory distress, focal histiocytic alveolitis | Hazleton 1980c
Mouse (CD-1) | 3 months; 5 days/week; 6 hours/day (WB) | 199.8 | 998.9 | Intermittent respiratory distress, focal and diffuse rhinitis, mild multifocal bronchitis, hyperplasia, and metaplasia of the trachea. | Hazleton 1980b
Body weight
Rat (SD) | 3 months; 5 days/week; 6 hours/day (WB) | 199.9 | 998.9 | 18–22% decrease in body weight | Hazleton 1980c
Mouse (CD-1) | 3 months; 5 days/week; 6 hours/day (WB) | 199.8 | 998.9 | 20–24% decrease in body weight | Hazleton 1980b
Mouse (CD-1) | 4 weeks; 5 days/week; 6 hours/day (WB) | 497.6 | 1,000.2 | 16% decrease in body weight in males | Hazleton 1979b
Rat (SD) | 4 weeks; 5 days/week; 6 hours/day (WB) | 598.5 | 1,007.3 | >10% decrease in body weight | Bogdanffy et al. 1997
Neurological effects
Rat (SD) | 4 weeks; 5 days/week; 6 hours/day (WB) | 199.6 | 598.5 | Degeneration/atrophy of olfactory nerve bundle | Bogdanffy et al. 1997
Rat (SD) | 3 months; 5 days/week; 6 hours/day (WB) | 998.9 | ND | No adverse effects | Hazleton 1980c
Mouse (CD-1) | 3 months; 5 days/week; 6 hours/day (WB) | 998.9 | ND | No adverse effects | Hazleton 1980b

a Selected study/endpoint for derivation of intermediate-duration inhalation MRL.

LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; SD = Sprague-Dawley; (WB) = whole-body exposure

Summary of the Principal Study:

Bogdanffy MS, Gladnick NL, Kegelman T, . 1997. Four-week inhalation cell proliferation study of the effects of vinyl acetate on rat nasal epithelium. Inhal Toxicol 9(4):331–350. 10.1080/089583797198178.

Groups of male rats (5/group) were exposed to 0, 50, 200, 600, or 1,000 ppm for 4 weeks (5 days/week, 6 hours/day); analytical concentrations (±SE) were 0±0, 50.8±0.7, 199.6±5.3, 598.5±6.4, and 1,007.3±11.0 ppm, respectively. Rats were observed for clinical signs, and for the 5-day study, weighed 3 times/week. Sixteen hours after exposure rats were injected with BrdU to assess cell proliferation and sacrificed 2 hours later. Respiratory tract tissues were examined for gross alterations and nasal cavities were dissected and cut into five cross sections for histopathological analysis. Immunocytochemistry was performed for BrdU analysis of Level 2, the region with the most observed damage.

Body weights were statistically decreased >10% at 1,007.3 ppm from day 3 through 26 (maximal reduction of 15% on day 5). No gross lesions were observed. Microscopic lesions were observed in several nasal cavity levels in all rats at ≥598.5 ppm, including olfactory epithelium regenerative hyperplasia and degeneration/necrosis and nerve bundle degeneration/atrophy. The most severe lesions were observed in the second and third levels (mild to severe). Incidence and severity of respiratory epithelium lesions were low across all groups. Increased cell proliferation was observed in the olfactory epithelium at ≥598.5 ppm, but not the respiratory epithelium.

Selection of the Point of Departure for the MRL: Bogdanffy et al. (1997) identified a NOAEL of 199.6 ppm for nasal lesions in rats following exposure to vinyl acetate for 4 weeks (6 hours/day; 5 days/week). The available data in Bogdanffy et al. (1997) are not amenable to BMD modeling because incidences go from 0% at the NOAEL to 100% at (and above) the LOAEL for the most sensitive nasal lesions. Therefore, the NOAEL of 199.6 ppm is selected as the POD.

Adjustment for Intermittent Exposure: Exposure over time is accounted for in the PBPK model (HEC simulations are for continuous exposure, see details below); therefore, no additional duration adjustment is needed.

Conversion to Human Equivalent Concentration: The PBPK model (Bogdanffy et al. 1999; Hinderliter et al. 2005) was used for rat-to-human dosimetry extrapolation in deriving inhalation MRLs for vinyl acetate as described in the acute-duration inhalation MRL worksheet. The study-specific parameters utilized in the PBPK model to calculate a NOAEL_HEC_ of 21.6 ppm for the selected POD are shown in Table A-4. As previously indicated, model parameters were based on values reported by Bogdanffy et al. (1999) and Plowchalk et al. (1997), with the exception of body weights, which were based on TWA body weights calculated for the principal study. The difference in the acute- and intermediate-duration NOAEL_HEC_ values (based on identical administered concentrations) is due to different TWA body weight values.

Table A-4 HECs Corresponding to the Rat POD Selected for Intermediate-Duration Inhalation MRL for Vinyl Acetate

Study | Exposure (ppm) | Duration and frequency | POD basis | POD metric | POD (hour μg/mL) | HEC^a^ (ppm)
Bogdanffy et al. (1997) | 0, 50.8, 199.6, 598.5, 1,007.3 | 4 weeks; 5 days/week; 6 hours/day | NOAEL (199.6 ppm) | AUC_168 hr_ | 6,243 | 21.6

a Calculated for continuous human exposure.

AUC = area under the curve for acetic acid concentration in olfactory epithelium; HEC = human equivalent exposure concentration; MRL = Minimal Risk Level; NOAEL = no-observed adverse effect level; POD = dose-response point of departure

Uncertainty Factor: The NOAEL_HEC_ was then by divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustment
- 10 for human variability

M R L = (N O A E L_H E C_)/(U F s) = (21.6 p p m)/(30) = 0.7 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Limited evidence from humans has shown that the respiratory tract is a sensitive target of acute-duration vinyl acetate exposure, with irritation of throat mucous membranes from acute-duration exposure levels as low as 4 ppm and persistent irritation at 74 ppm (Deese and Joyner 1969; Union Carbide 1973). The acute-, intermediate-, and chronic-duration databases confirm that the respiratory system, particularly the extrathoracic region, is the most sensitive target of toxicity following inhalation exposure to vinyl acetate. Nasal lesions are observed in rats following acute- or intermediate-duration exposure to ≥598.5 ppm (Bogdanffy et al. 1997; Krieger et al. 2020) and in rats and mice following chronic-duration exposure to ≥200.5 ppm (Bogdanffy et al. 1994a; Hazleton 1988). Lower respiratory tract lesions are also seen in rats and mice following intermediate-duration exposure to 998.9 ppm (Hazleton 1980b, 1980c) and mice following chronic-duration exposure to ≥200.5 ppm (Bogdanffy et al. 1994a; Hazleton 1988). In acute-duration inhalation lethality studies, deaths were attributed to lung damage in rats, mice, guinea pigs, and rabbits (Union Carbide 1973). Mechanistic data predict portal-of-entry effects (i.e., respiratory tract lesions) based on rapid hydrolysis of vinyl acetate into acetaldehyde and acetic acid following contact with mucosal surfaces, resulting in irritation due to tissue acidification (Bogdanffy et al. 1999, 2001, 2004; Slikker et al. 2004).

Agency Contacts (Chemical Managers): Rae T. Benedict

## Vinyl acetate Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl acetate
CAS Numbers: | 108-05-4
Date: | January 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL | 0.3 ppm (1.1 mg/m^3^)
Critical Effect: | Nasal lesions
References: | Bogdanffy et al. 1994a; Hazleton 1988
Point of Departure: | NOAEL of 49.4 ppm (NOAEL_HEC_ of 8.52 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 19
Species: | Rat

MRL Summary: A chronic-duration inhalation MRL of 0.3 ppm was derived for vinyl acetate based on nasal lesions in male rats exposed to concentrations ≥200.5 ppm for 104 weeks (6 hours/day, 5 days/week); a NOAEL of 49.4 ppm was identified (Bogdanffy et al. 1994a; Hazleton 1988). The MRL is based on a NOAEL_HEC_ of 8.52 ppm derived using the PBPK model by Bogdanffy et al. (1999). The NOAEL_HEC_ was divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available chronic-duration inhalation studies for vinyl acetate report exposure-related respiratory and body weight effects in rats and mice at LOAELs of 200.5 and 594.7 ppm, respectively (Table A-5). Respiratory effects are considered the most sensitive effect, with nasal lesions in rats and mice and pulmonary lesions in mice at ≥200.5 ppm. Therefore, respiratory lesions were selected as the critical effect for derivation of the chronic-duration inhalation MRL.

Selection of the Principal Study: While both rats and mice are similarly sensitive to the development of respiratory lesions, the chronic-duration rat study (Bogdanffy et al. 1994a; Hazleton 1988) was selected as the principal study due to the availability of a PBPK model estimating olfactory epithelium exposure metrics in rats and humans (Bogdanffy et al. 1999). Use of a PBPK model will result in higher confidence in the HEC calculation, compared to use of a default HEC concentration based on the RGDR recommended by EPA (1994).

Table A-5 Select NOAEL and LOAEL Values in Animals Following Chronic-Duration Inhalation Exposure to Vinyl Acetate

Species | Duration | NOAEL/LOAEL (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Respiratory
Rat (SD) | 104 weeks; 5 days/week; 6 hours/day (WB) | 49.4 | 200.5 | Nasal lesions^a^ | Bogdanffy et al. 1994a; Hazleton 1988
Mouse (CD-1) | 104 weeks; 5 days/week; 6 hours/day (WB) | 49.4 | 200.5 | Nasal lesions | Bogdanffy et al. 1994a; Hazleton 1988
Body weight
Rat (SD) | 104 weeks; 5 days/week; 6 hours/day (WB) | 200.5 | 594.7 | 14% decrease in terminal body weight in females | Bogdanffy et al. 1994a; Hazleton 1988
Mouse (CD-1) | 104 weeks; 5 days/week; 6 hours/day (WB) | 200.5 | 594.7 | 11–15% decrease in terminal body weight | Bogdanffy et al. 1994a; Hazleton 1988

a Selected study for derivation of chronic-duration inhalation MRL.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; SD = Sprague-Dawley; (WB) = whole-body exposure

Summary of the Principal Study:

Bogdanffy MS, Dreef-van der Meulen HC, Beems RB, . 1994a. Chronic toxicity and oncogenicity inhalation study with vinyl acetate in the rat and mouse. Fundam Appl Toxicol 23(2):215–229. 10.1006/faat.1994.1100.7982530

Hazleton. 1988. Vinyl acetate: 104 week inhalation combined chronic toxicity and carcinogenicity study in the rat and mouse (Vol. I, II, IV & Vol. I of Amendment to final report, with cover letter 01/31/89). The Society of the Plastics Industry Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8e. OTS0510582. 890000088. 8EHQ01890642.

Groups of Crl:CD(SD)BR Sprague-Dawley rats (60/sex/group) were exposed whole-body to vinyl acetate at concentrations of 0, 50, 200, or 600 ppm for 6 hours/day, 5 days/week for 104 weeks. Analytical concentrations for the exposure groups were 49.4±2.4, 200.5±9.7, and 594.7±16.8 ppm, respectively. Body weights were recorded at weekly intervals to Week 28 and every 4 weeks thereafter. All animals were observed briefly for clinical abnormalities before each exposure, received a detailed examination 1 time/week, and were examined twice daily for morbidity and mortality. Blood was collected from 10/sex/group in Week 104 for clinical chemistry and hematology. Urine samples were collected overnight. All animals underwent gross necropsy at sacrifice. The adrenals, gonads, kidneys, lungs, spleen, brain, heart, liver, pituitary, and thyroids were weighed. Histopathology was conducted on a complete set of tissues in control and high-exposure group. The respiratory tract tissues, including the nasal cavity, were examined in all animals. The respiratory tract histology was conducted in two independent labs, while one lab evaluated the nasal cavity in four cross sections.

Additional animals were used in satellite groups. One satellite group (10/sex/group) was used for clinical laboratory evaluation at Week 51 and interim sacrifice at Weeks 52–53. A second satellite group (10/sex/group) was used for clinical laboratory evaluation at Week 81 and interim sacrifice at Weeks 85–86. A third satellite group (10/sex/group) was used to evaluate recovery after 70 weeks of exposure followed by 15–16 weeks exposure-free.

No adverse treatment-related effects or mortality were observed. The study authors mentioned treatment-related clinical signs of rough haircoat and hunched posture at all concentrations; however, these findings were not uncommon in the control group and no exposure-related findings were observed when weekly incidence data were reviewed. Body weight gain was significantly decreased at 594.7 ppm during the study and absolute body weight in the high exposure group was decreased ~10%. No clear exposure-related hematological changes were observed. Blood glucose was decreased in 594.7-ppm females and urine volume was significantly reduced at 594.7 ppm in males at Week 51 and both sexes at Weeks 81 and 104. These findings were attributed by the study author to reductions in food and water intake (although these parameters were not specifically measured). Relative lung weight was significantly increased in all exposure groups at terminal sacrifice by 12–17% in females; this effect was reversed in the satellite recovery group. Elevated relative lung weight in males was only observed at the 53-week interim sacrifice at 594.7 ppm (20–30%). The biological relevance of reversible elevated relative lung weight in the absence of histopathological changes is unclear, especially considering body weight effects. The unpublished study (Hazleton 1988) also reported decreased relative spleen weight; this is not mentioned in the published report (Bogdanffy et al. 1994a), nor is it accompanied by histopathological changes.

Treatment-related nonneoplastic nasal lesions were observed in animals exposed to 200.5 or 594.7 ppm (olfactory epithelial atrophy, olfactory epithelial squamous metaplasia, olfactory epithelial regeneration, olfactory epithelial inflammatory cell infiltrate, epithelial nest-like infolds, olfactory epithelial leukocytic exudate, basal cell hyperplasia, turbinate leukocytic exudate, submucosal inflammatory cell infiltrate). Nonneoplastic lesions in the lungs were observed at 594.7 ppm (bronchial exfoliation, intraluminal fibrous projections, pigmented macrophages, peribronchiolar/ perivascular lymphoid aggregates). The total incidence of neoplastic nasal tumors (combined) was significantly elevated in male rats at 594.7 ppm (7/59) compared with controls (0/59) and nonsignificantly elevated in females (4/59 compared with 0/59 controls). Only squamous cell carcinoma was observed in females at 594.7 ppm. Nasal tumors observed in 594.7-ppm males included inverted papilloma, two squamous cell carcinomas, carcinoma in situ (4/59 total incidence of benign tumors and 3/59 total incidence of malignant tumors). One 200-ppm male had a nasal papilloma. No exposure-related lung tumors were observed in either sex. One squamous cell carcinoma of the larynx was observed in a 594.7-ppm female. The study author attributed the observed olfactory atrophy and tumors in the nasal cavity and lung lesions to chronic irritation.

Selection of the Point of Departure for the MRL: In order to identify the POD, BMD modeling was attempted for nasal lesions (atrophy, basal cell hyperplasia) in male and female rats reported by Bogdanffy et al. (1994a). Male and female rat nasal lesion data modeled are shown in Tables A-6 and A-7, respectively. Prior to modeling, the PBPK model described in the acute-duration inhalation MRL section was utilized to convert administered concentrations to acetic acid concentration overtime (AUC) in rat nasal olfactory epithelial tissue. Conversion to tissue dosimetry was performed prior to BMD modeling due to nonlinear relationship observed between external concentration and tissue concentration (attributed to metabolic saturation). The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS) (version 3.2) using a benchmark response (BMR) of 10% extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMCL (95% lower confidence limit on the benchmark concentration [BMC]) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was ≥3 fold; otherwise, the BMCL from the model with the lowest Akaike Information Criterion (AIC) was chosen.

Table A-6 Incidence of Select Nasal Lesions in the Olfactory Epithelium of Male Sprague-Dawley Rats Following Inhalation Exposure to Vinyl Acetate for 104 Weeks (5 Days/Week, 6 Hours/Day)

| Analytical concentration in ppm (AC AUC in week μg/mL^a^)
| 0 (0) | 49.4 (2,295) | 200.5 (5,975) | 594.7 (9,715)
Atrophy | 0/59 (0%) | 0/60 (0%) | 53/60^b^ (88%) | 50/60^b^ (83%)
Basal cell hyperplasia | 2/59 (3%) | 5/60 (8%) | 54/60^b^ (92%) | 46/60^b^ (78%)

a Calculated using the PBPK model by Bogdanffy et al. (1999), described in the acute-duration inhalation MRL worksheet.

b Statistically significant (p<0.05) based on Fisher’s Exact Probability test conducted for this review.

AC = acetic acid; AUC = area under the curve; PBPK = physiologically based pharmacokinetic

Source: Bogdanffy et al. 1994a

Table A-7 Incidence of Select Nasal Lesions in the Olfactory Epithelium of Female Sprague-Dawley Rats Following Inhalation Exposure to Vinyl Acetate for 104 Weeks (5 Days/Week, 6 Hours/Day)

| Analytical concentration in ppm (AC AUC in week μg/mL^a^)
| 0 (0) | 49.4 (2,267) | 200.5 (6,224) | 594.7 (10,140)
Atrophy | 0/60 (0%) | 1/60 (2%) | 27/60^b^ (45%) | 51/59^b^ (86%)
Basal cell hyperplasia | 0/60 (0%) | 0/60 (0%) | 34/60^b^ (57%) | 51/59^b^ (86%)

a Calculated using the PBPK model by Bogdanffy et al. (1999), described in the acute-duration inhalation MRL worksheet.

b Statistically significant (p<0.05) based on Fisher’s Exact Probability test conducted for this review.

AC = acetic acid; AUC = area under the curve; PBPK = physiologically based pharmacokinetic

Source: Bogdanffy et al. 1994a

Details of the modeling results for atrophy in male rats are provided in Table A-8. The only model that provided an adequate statistical fit was the Dichotomous Hill model. However, this model was considered unstable due to overparameterization for this dataset (only four exposure groups) and a mid-range p-value (p=0.41). Additionally, graphing the cumulative distribution function plot did not result in the characteristic sigmoidal shape expected for a viable model (Figure A-4). None of the models tested adequately fit the data for basal cell hyperplasia in male rats.

Table A-8 BMD Model Predictions for Olfactory Epithelium Atrophy in Male Sprague-Dawley Rats Following Inhalation to Vinyl Acetate for 104 Weeks (5 Days/Week, 6 Hours/Day) (Bogdanffy et al. 1994a)

Model | BMC_10_^a^ (week μg/mL) | BMCL_10_^a^ (week μg/mL) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (week μg/mL) | BMCL_10_^a^ (week μg/mL) | p-value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill | 2,419.085 | 2275.090 | 0.407 | 119.708 | -0.0001 | -0.001
Gamma^d^ | | | <0.0001 | 143.918 | -1.637 | -0.001
Log-Logistic^e^ | | | <0.0001 | 136.008 | -1.249 | -0.001
Multistage Degree 3^f^ | | | <0.0001 | 147.915 | -2.117 | -0.001
Multistage Degree 2^f^ | | | <0.0001 | 145.915 | -2.117 | -0.001
Multistage Degree 1^f^ | | | <0.0001 | 163.073 | -0.001 | -0.001
Weibull^d^ | | | <0.0001 | 149.646 | -2.416 | -0.001
Logistic | | | <0.0001 | 155.779 | -1.792 | -1.284
Log-Probit | | | <0.0001 | 138.181 | -1.282 | -0.001
Probit | | | <0.0001 | 159.273 | -1.889 | -1.186

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Figure A-4 Cumulative Distribution Function of Dichotomous Hill Model for Olfactory Epithelium Atrophy in Male Sprague-Dawley Rats Following Inhalation Exposure to Vinyl Acetate for 104 Weeks (Bogdanffy et al. 1994a)

Details of the modeling results for olfactory epithelium atrophy in female rats are in Table A-9. All models except the Multistage (1-Degree) provided adequate fit to the incidence data. The Gamma model was recommended by BMDS; however, the p-value of approximately 1 and scaled residuals of 0.0 suggest that the Gamma model is overfit, so it was not considered further. In accordance with the selection criteria mentioned above, the models with the next lowest AIC value were reviewed (Dichotomous Hill and Log-Logistic). From these, the model with the slightly lower BMCL was selected (frequentist, restricted Log-Logistic model) for olfactory epithelium atrophy in female rats.

Table A-9 BMD Model Predictions for Olfactory Epithelium Atrophy in Female Sprague-Dawley Rats Following Inhalation to Vinyl Acetate for 104 Weeks (6 Hours/Day) (Bogdanffy et al. 1994a)

Model | BMC_10_^a^ (week μg/mL) | BMCL_10_^a^ (week μg/mL) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (week μg/mL) | BMCL_10_^a^ (week μg/mL) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill | 3,768.407 | 3,036.528 | 0.805 | 145.640 | 0.174 | -0.001
Gamma^d^ | 3,607.948 | 2,909.137 | 0.995 | 145.581 | 0.004 | -0.001
Log-Logistic ^e^ ^,^ ^f^ | 3,768.406 | 3,036.527 | 0.805 | 145.640 | 0.174 | -0.001
Multistage Degree 3^g^ | 3,573.788 | 2,713.506 | 0.303 | 146.685 | -0.569 | -0.001
Multistage Degree 2^g^ | 2,527.031 | 2,197.032 | 0.224 | 147.522 | -1.832 | -0.001
Multistage Degree 1^g^ | | | <0.0001 | 175.866 | -0.001 | -0.001
Weibull^d^ | 3,480.679 | 2,746.145 | 0.365 | 146.482 | -0.649 | -0.015
Logistic | 3,843.494 | 3,187.257 | 0.184 | 147.591 | -0.900 | -0.718
Log-Probit | 3,572.231 | 2,930.895 | 0.481 | 146.060 | 0.411 | -0.001
Probit | 3,725.311 | 3,047.144 | 0.328 | 146.067 | -0.716 | -0.442

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Selected model. All models except the Multistage (1-degree) provided adequate statistical fit to the data. The Gamma model was overfit to the data and was not considered further. BMCLs for the remaining models differed by <3-fold; therefore, the models with the next lowest AIC were reviewed (Dichotomous Hill, Log-Logistic). Since these models have identical AIC values, the model with the (slightly) lower BMCL (Log-Logistic) was selected.

f Slope restricted to ≥1.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Details of the modeling results for basal cell hyperplasia in female rats in female rats are in Table A-10. The Dichotomous Hill, Log-Logistic, and Log-Probit models provided adequate fit to the incidence data for atrophy. The Dichotomous Hill model was recommended by BMDS; however, the p-value of approximately 1 and scaled residuals of 0.0 suggest that the Dichotomous Hill model is overfit, so it was not considered further. In accordance with the selection criteria mentioned above, the next lowest AIC was selected (frequentist, restricted Log-Probit model) for basal cell hyperplasia in female rats.

Table A-10 BMD Constant Variance Model Predictions for Olfactory Epithelium Basal Cell Hyperplasia in Female Sprague-Dawley Rats Following Inhalation to Vinyl Acetate for 104 Weeks (6 Hours/Day) (Bogdanffy et al. 1994a)

Model | BMC_10_^a^ (week μg/mL) | BMCL_10_^a^ (week μg/mL) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (week μg/mL) | BMCL_10_^a^ (week μg/mL) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill | 4,943.384 | 3,326.149 | 0.977 | 134.942 | 0.0005 | -0.001
Gamma^d^ | | | 0.079 | 138.960 | -1.014 | -0.003
Log-Logistic^e^ | 3,631.587 | 2,933.453 | 0.154 | 137.815 | -0.952 | -0.001
Multistage Degree 3^f^ | | | 0.007 | 144.070 | -1.481 | -0.001
Multistage Degree 2^f^ | | | 0.081 | 143.161 | -2.460 | -0.001
Multistage Degree 1^f^ | | | <0.0001 | 174.279 | -0.001 | -0.001
Weibull^d^ | | | 0.016 | 143.239 | -1.630 | -0.001
Logistic | | | 0.005 | 146.229 | -1.717 | -0.769
Log-Probit ^g^ | 3,576.574 | 2,929.227 | 0.232 | 136.868 | -0.724 | -0.001
Probit | | | 0.009 | 144.601 | -1.585 | -0.488

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. Only the Dichotomous Hill, Log-Logistic, and Log-Probit models provided adequate statistical fit. However, the Dichotomous Hill model was considered unstable due to low number of dose groups and a p-value near unity; it was not considered further. BMCLs for the remaining two models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC of these models was selected (Log-Probit).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

To select the POD for the chronic-duration inhalation MRL, the POD values for olfactory epithelial lesions in male and female rats were compared (Table A-11). The increased incidence for olfactory epithelial lesions in male rats was selected because it is the most sensitive POD for the critical effect (nasal lesions). Incidence data also support that the male rat is more sensitive to nasal toxicity associated with vinyl acetate exposure, compared to the female rat. The apparent (slight) decrease in the incidence of atrophy and basal cell hypertrophy in male rats at the highest exposure concentration is likely attributable to progression to lesions of increased severity (e.g., metaplasia) that are only observed at the highest exposure level.

Table A-11 Summary of Candidate Effects and POD Values Considered for Derivation of a Chronic-Duration Inhalation MRL for Vinyl Acetate

Species | Duration | Effect | Candidate POD (week μg/mL) | POD type | Reference
Sprague-Dawley rat (male) | 104 weeks | Olfactory epithelial atrophy and basal cell hypertrophy | 2,295^a^ | NOAEL | Bogdanffy et al. 1994a; Hazleton 1988
Sprague-Dawley rat (female) | 104 weeks | Olfactory epithelial atrophy | 3,037 | BMCL_10_ | Bogdanffy et al. 1994a; Hazleton 1988
Sprague-Dawley rat (female) | 104 weeks | Olfactory epithelial basal cell hypertrophy | 2,929 | BMCL_10_ | Bogdanffy et al. 1994a; Hazleton 1988

a Selected POD for derivation of chronic-duration inhalation MRL.

BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk); MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; POD = point of departure

Adjustment for Intermittent Exposure: Exposure over time is accounted for in the PBPK model (HEC simulations are for continuous exposure, see details below); therefore, no additional duration adjustment is needed.

Conversion to Human Equivalent Concentration: The PBPK model (Bogdanffy et al. 1999; Hinderliter et al. 2005) was used for rat-to-human dosimetry extrapolation in deriving the chronic-duration inhalation MRL for vinyl acetate as described in the acute-duration inhalation MRL section. The study-specific parameters utilized in the PBPK model to calculate a NOAEL_HEC_ of 8.52 ppm for the selected POD are shown in Table A-12. As previously indicated, all model parameters were based on values reported by Bogdanffy et al. (1999) and Plowchalk et al. (1997), with the exception of body weights, which were based on TWA body weights calculated for the principal study.

Table A-12 HECs Corresponding to Rat POD Selected for Chronic-Duration Inhalation MRL for Vinyl Acetate

Study | Exposure (ppm) | Duration and frequency | POD basis | POD metric | POD (hour μg/mL) | HEC^a^ (ppm)
Bogdanffy et al. (1994a) | 0, 49.4, 200.5, 594.7 | 4 weeks; 5 days/week; 6 hours/day | NOAEL (49.4 ppm) | AUC_168 hr_ | 2,295 | 8.52

a Calculated for continuous human exposure.

AUC = area under the curve for acetic acid concentration in olfactory epithelium; HEC = human equivalent exposure concentration; MRL = Minimal Risk Level; NOAEL = no-observed adverse effect level; POD = dose-response point of departure

Uncertainty Factor: The NOAEL_HEC_ was then by divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustment
- 10 for human variability

M R L = (N O A E L_H E C_)/(U F s) = (8.52 p p m)/(30) = 0.3 p p m

Other Additional Studies of Pertinent Information that Lend Support to this MRL: Limited evidence from humans has shown that the respiratory tract is a sensitive target of acute-duration vinyl acetate exposure, with irritation of throat mucous membranes from acute-duration exposure levels as low as 4 ppm and persistent irritation at 74 ppm (Deese and Joyner 1969; Union Carbide 1973). One cross-sectional study reported subjective respiratory complaints and mild reductions in pulmonary function at an average vinyl acetate concentration of 3.61 ppm (range of 0.02–11.71 ppm) in carpet manufacturers (Khoshakhlagh et al. 2023). However, another occupational study suggests that repeated occupational exposure to vinyl acetate is generally without adverse respiratory effect at levels <10 ppm (Deese and Joyner 1969).

In rodents, the acute-, intermediate- and chronic-duration databases confirm that the respiratory system, particularly the extrathoracic region, is the most sensitive target of toxicity following inhalation exposure to vinyl acetate. Nasal lesions are observed in rats following acute- or intermediate-duration exposure to ≥598.5 ppm (Bogdanffy et al. 1997; Krieger et al. 2020) and in rats and mice following chronic-duration exposure to ≥200.5 ppm (Bogdanffy et al. 1994a; Hazleton 1988). Lower respiratory tract lesions are also seen in rats and mice following intermediate-duration exposure to 998.9 ppm (Hazleton 1980b, 1980c) and mice following chronic-duration exposure to ≥200.5 ppm (Bogdanffy et al. 1994a; Hazleton 1988). In acute-duration inhalation lethality studies, deaths were attributed to lung damage in rats, mice, guinea pigs, and rabbits (Union Carbide 1973). Mechanistic data predict portal-of-entry effects (i.e., respiratory tract lesions) based on rapid hydrolysis of vinyl acetate into acetaldehyde and acetic acid following contact with mucosal surfaces, resulting in irritation due to tissue acidification (reviewed by Bogdanffy et al. 1999, 2001, 2004; Slikker et al. 2004).

Agency Contacts (Chemical Managers): Rae T. Benedict

## Vinyl acetate Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl acetate
CAS Numbers: | 108-05-4
Date: | January 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The acute oral database is limited to acute-duration lethality studies (Goeva 1966; Smyth and Carpenter 1948), a developmental exposure study that does not identify adverse effects at maternal doses up to 477 mg/kg/day (Hurtt et al. 1995), and a study reporting a lack of gastrointestinal lesions in rats and mice exposed to doses up to 1,400 mg/kg/day and 5,300 mg/kg/day, respectively, for 1–8 days (no other organ systems were evaluated) (Valentine et al. 2002).

Agency Contacts (Chemical Managers): Rae T. Benedict

## Vinyl acetate Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl acetate
CAS Numbers: | 108-05-4
Date: | January 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No intermediate-duration oral MRL was derived for vinyl acetate because effects potentially associated with intermediate-duration oral exposure to vinyl acetate are of questionable biological significance and/or human relevance:

1. Body weight effects noted in drinking water studies at ≥165 mg/kg/day in F1 rats and 697 mg/kg/day in F0 rats in a 2-generation study and at 1,040 mg/kg/day in mice exposed for 4 weeks were associated with decreased water consumption during some or all of the exposure period (attributed to palatability issues) (Hazleton 1979d; Mebus et al. 1995). Since decreased water consumption can result in body weight loss even in the absence of clinical dehydration (Vasilev et al. 2021), it is difficult to distinguish compound-related effects on body weight from direct effects of decreased water consumption.
2. The developmental serious LOAEL of 697 mg/kg/day based on decreased F1 weanling body weight in a 2-generation study in rats (Mebus et al. 1995) is thought to be secondary to a significant decrease in maternal water intake, attributed to unpalatability of drinking water (which could impair milk supply); F0 dams also showed significant decreases in body weight gain during lactation at 669 mg/kg/day. Therefore, these effects are of questionable biological significance and therefore, not an appropriate basis for the MRL.
3. All of the remaining available intermediate-duration oral NOAELs are “free-standing” and are thus not an appropriate basis for the calculation of an MRL (Hazleton 1979d, 1980e, 1980f; Valentine et al. 2002).

Agency Contacts (Chemical Managers): Rae T. Benedict

## Vinyl acetate Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vinyl acetate
CAS Numbers: | 108-05-4
Date: | January 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No chronic-duration oral MRL was derived for vinyl acetate. Only one reliable, comprehensive chronic-duration study was identified (Bogdanffy et al. 1994b). In this study, the only potentially adverse effect reported was decreased body weight at ≥202 mg/kg/day in rats. However, as observed in intermediate-duration drinking water studies, findings were associated with decreased water consumption (attributed to palatability issues). Since decreased water consumption can result in body weight loss even in the absence of clinical dehydration (Vasilev et al. 2021), it is difficult to distinguish compound-related effects on body weight from direct effects of decreased water consumption. Additionally, male rats also showed decreased food intake, further confounding body weight findings. The remaining reliable chronic-duration studies focused on neoplastic changes. Exposure-related effects in these studies were limited to serious LOAELs, including death and cancer (Belpoggi et al. 2002; Maltoni et al. 1997; Minardi et al. 2002).

A second comprehensive chronic-duration study reported pre-neoplastic and neoplastic lesions in the upper gastrointestinal tract of rats and mice (Umeda et al. 2004). However, this study is not listed in the LSE tables as there are quality issues with this study precluding accurate dose estimation. The drinking-water solution was only mixed twice weekly (instead of daily, as found in other drinking water studies for vinyl acetate). The study authors reported that the test solution stabilities at 4 days were 72–80% in the rat study and 86–96% in the mouse study. The lost concentration was attributed mainly to evaporation. Acetic acid concentration after 4 days was 9.2, 4.7, and 263 ppm at 400, 2,000, or 10,000 ppm, respectively. It is unclear if acetic acid in the drinking water and/or decreased pH contributed to the observed effects. Therefore, while discussed in the profile, this study was not considered as the basis for the MRL.

Agency Contacts (Chemical Managers): Rae T. Benedict