# 9 REFERENCES

* Not cited in text

ACGIH. 2008. Vanadium pentoxide. In: Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adachi A, Asai K, Koyama Y, 1998a. Vanadium content of cigarettes. Bull Environ Contam Toxicol 61(2):276–280.9702367
Adachi A, Asai K, Koyama Y, 2000a. Subacute vanadium toxicity in rats. J Health Sci 46(6):503–508.
Adachi A, Ogawa K, Tsushi Y, 2000b. Balance, excretion and tissue distribution of vanadium in rats after short-term ingestion. J Health Sci 46(1):59–62.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Afkhami-Arekani M, Karimi M, Mohammadi Mohammad S, 2008. Effect of sodium metavanadate supplementation on lipid and glucose metabolism biomarkers in type e diabetic patients. Malays J Nutr 14(1):113–119.22691769
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
AIHA. 2008. Emergency R esponse Planning Guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. http://www.aiha.org/1documents/Committees/ERP-erpglevels.pdf. May 19, 2009.
Akgün-Dar K, Bolkent S, Yanardag R, 2007. Vanadyl sulfate protects against streptozotocin-induced morphological and biochemical changes in rat aorta. Cell Biochem Funct 25(6):603–609.16892454
Al-Bayati MA, Xie Y, Mohr FC, 2002. Effect of pirfenidone against vanadate-induced kidney fibrosis in rats. Biochem Pharmacol 64(3):517–525.12147304
Allen RO, Steinnes E. 1978. Determination of vanadium in biological materials by radiochemical neutron activation analysis. Anal Chem 50:1553–1555.707811
Allen SK, Allen JM, Lucas S. 1996. Dissolved metal concentrations in surface waters from west-central Indiana contaminated with acidic mine drainage. Bull Environ Contam Toxicol 56:240–243.8720095
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology.
Amorim FA, Welz B, Costa AC, 2007. Determination of vanadium in petroleum and petroleum products using atomic spectrometric techniques. Talanta 72(2):349–359.19071624
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Barceloux DG. 1999. Vanadium. J Toxicol Clin Toxicol 37(2):265–278.10382561
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Baroch EF. 2006. Vanadium and vanadium alloys. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/vana.a01/current/pdf. May 12, 2009.
Beauge LA, Cavieres JJ, Glynn IM, 1980. The effects of vanadate on the fluxes of sodium and potassium ions through the sodium pump. J Physiol 301:7–23.6251203
Beg MU, Al-Muzaini S, Saeed T, 2001. Chemical contamination and toxicity of sediment from a coastal area receiving industrial effluents in Kuwait. Arch Environ Contam Toxicol 41:289–297.11503065
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Birnboim HC. 1988. A superoxide anion induced DNA strand-break metabolic pathway in human leukocytes: Effects of vanadate. Biochem Cell Biol 66:374–381.2841951
Bocio A, Nadal M, Domingo JL. 2005. Human exposure to metals through the diet in Tarragona, Spain: Temporal trend. Biol Trace Elem Res 104(3):193–201.15930589
Boden G, Chen X, Ruiz J, 1996. Effects of vanadyl sulfate on carbohydrate and lipid metabolism in patients with non-insulin-dependent diabetes mellitus. Metabolism 45(9):1130–1135.8781301
Bogden JD, Higashino H, Lavenhar MA, 1982. Balance and tissue distribution of vanadium after short-term ingestion of vanadate. J Nutr 112:2279–2285.6923926
Boscolo P, Carmignani M, Volpe AR, 1994. Renal toxicity and arterial hypertension in rats chronically exposed to vanadate. Occup Environ Med 51(7):500–503.8044251
Boulassel B, Sadeg N, Roussel O, 2011. Fatal poisoning by vanadium. Forensic Sci Int 206(1–3):e79–e81.21130588
Bronzetti G, Morichetti E, Della Croce C, 1990. Vanadium: Genetical and biochemical investigations. Mutagenesis 5(3):293–295.2200949
Bruech M, Quintanilla ME, Legrum W, 1984. Effects of vanadate on intracellular reduction equivalents in mouse liver and the fate of vanadium in plasma, erthrocytes, and liver. Toxicology 31:283–295.6564811
Buchet JP, Knepper E, Lauwerys R. 1982. Determination of vanadium in urine by electrothermal atomic absorption spectrometry. Anal Chim Acta 136:243–248.
Buchter B, Davidoff B, Amacher MC, 1989. Correlation of Freundlich Kd and n retention parameters with soils and elements. Soil Sci 148(5):370–378.
Bursztyn M, Mekler J. 1993. Acute hypertensive response to saline induced by vanadate, an insulinomimetic agent. J Hypertens 11(6):605–609.8397239
Byczkowski JZ, Kulkarni AP. 1998. Oxidative stress and pro-oxidant biological effects of vanadium. In: Nriagu JO, ed. Vanadium in the environment. Part 2: Health effects. Vol. 31. New York, NY: John Wiley & Sons, 235–264.
Byerrum RU. 1991. Vanadium. In: Merian E, ed. Metals and their compounds in the environment. Weinheim, Germany: VCH, 1289–1297.
Byerrum RU, Eckardt RE, Hopkins LL, 1974. Vanadium. Washington, DC: National Academy of Sciences, 19–45.
Byrne AR, Kosta L. 1978. Vanadium in foods and in human body fluids and tissues. Sci Total Environ 10:17–30.684404
Byrne AR, Kucera J. 1991. New data on levels of vanadium in man and his diet. In: Momcilovic B, ed. Trace elements in man and animals. Vol. 7. Copenhagen, Denmark: World Health Organisation (WHO), Regional Office for Europe, 25–18 to 25–20.
Cannon HL. 1963. The biogeochemistry of vanadium. Soil Sci 98:196–204.
*Carlton BD, Beneke MB, Fisher GL. 1982. Assessment of the teratogenicity of ammonium vanadate using syrian golden hamsters. Environ Res 29:256–262.6925525
Carmignani M, Boscolo P, Volpe AR, 1991. Cardiovascular system and kidney as specific targets of chronic exposure to vanadate in the rat: Functional and morphological findings. Arch Toxicol Suppl 14:124–127.1805718
Carmignani M, Volpe AR, Porcelli G, 1992. Chronic exposure to vanadate as factor of arterial hypertension in the rat: Toxicodynamic mechanisms. Arch Toxicol Suppl 15:117–120.1510576
Castranova V, Bowman L, Wright JR, 1984. Toxicity of metallic ions in the lung: Effects on alveolar macrophages and alveolar type II cells. J Toxicol Environ Health 13:845–856.6492205
*Chanh PH. 1965. The comparative toxicity of sodium chromate, molybdate, tungstate and metavanadate. II. Experiments on mice and rats. Arch Int Pharmacodyn Ther 157(1):109–114.5884990
ChemIDplus. 2009. Vanadium and vanadium compounds. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://chem.sis.nlm.nih.gov/chemidplus/chemidlite.jsp. May 21, 2009.
Chen ZL, Owens G. 2008. Trends in speciation analysis of vanadium in environmental samples and biological fluids - a review. Anal Chim Acta 607(1):1–14.18155404
Chillrud SN, Bopp RF, Simpson HJ, 1999. Twentieth century atmospheric metal fluxes into Central Park Lake, New York City. Environ Sci Technol 33(5):657–662.21850150
Ciranni R, Antonetti M, Migliore L. 1995. Vanadium salts induce cytogenetic effects in in vivo treated mice. Mutat Res 343(1):53–60.7753106
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cohen MD, Klein CB, Costa M. 1992. Forward mutations and DNA-protein crosslinks induced by ammonium metavanadate in cultured mammalian cells. Mutat Res 269(1):141–148.1381466
Cohen MD, Wei C, Tan H, 1986. Effect of ammonium metavanadate on the murine immune response. J Toxicol Environ Health 19:279–298.3093687
Cohen MD, Yang Z, Zelikoff JT, 1996. Pulmonary immunotoxicity of inhaled ammonium metavanadate in Fisher 344 rats. Fundam Appl Toxicol 33(2):254–263.8921344
Cohen N, Halberstam M, Shlimovich P, 1995. Oral vanadyl sulfate improves hepatic and peripheral insulin sensitivity in patients with non-insulin-dependent diabetes mellitus. J Clin Invest 95(6):2501–2509.7769096
Cong Z, Kang S, Dong S, 2008. Elemental and individual particle analysis of atmospheric aerosols from high Himalayas. Environ Monit Assess [Dec 13; Epub ahead of print.]
Conklin AW, Skinner CS, Felten TL, 1982. Clearance and distribution of intratracheally instilled vanadium-48 compounds in the rat. Toxicol Lett 11:199–203.7090012
Crampton EW, Lloyd LE. 1954. The effect of water restriction on the food intake and food efficiency of growing rats. J Nutr 54(2):221–224.13212461
Crans DC, Amin SS, Keramidas AD. 1998. Chemistry of relevance to vanadium in the environment. In: Nriagu JO, ed. Vanadium in the environment. Vol. 30. New York, NY: John Wiley & Sons, Inc., 73–95.
Curran GL, Azarnoff DL, Bolinger RE. 1959. Effect of cholesterol synthesis inhibition in normocholesteremic young men. J Clin Invest 38(7):1251–1261.13664799
Cusi K, Cukier S, DeFronzo RA, 2001. Vanadyl sulfate improves hepatic and muscle insulin sensitivity in type 2 diabetes. J Clin Endocrinol Metab 86(3):1410–1417.11238540
Dai S, McNeill JH. 1994. One-year treatment of non-diabetic and streptozotocin-diabetic rats with vanadyl sulphate did not alter blood pressure or haematological indices. Pharmacol Toxicol 74(2):110–115.8190698
Dai S, Thompson KH, McNeill JH. 1994a. One-year treatment of streptozotocin-induced diabetic rats with vanadyl sulphate. Pharmacol Toxicol 74(2):101–109.8190697
Dai S, Thompson KH, Vera E, 1994b. Toxicity studies on one-year treatment of non-diabetic and streptozotocin-diabetic rats with vanadyl sulphate. Pharmacol Toxicol 75(5):265–273.7870697
Dai S, Vera E, McNeill JH. 1995. Lack of haematological effect of oral vanadium treatment in rats. Pharmacol Toxicol 76(4):263–268.7617557
Dannecker W, Schroeder B, Stechmann H. 1990. Organic and inorganic substances in highway tunnel exhaust air. Sci Total Environ 93:293–300.
de la Torre A, Granero S, Mayayo E, 1999. Effect of age on vanadium nephrotoxicity in rats. Toxicol Lett 105(1):75–82.10092059
Dimond EG, Caravaca J, Benchimol A. 1963. Excretion, toxicity, lipid effect in man. Am J Clin Nutr 12:49–53.14027941
DOE. 2008. Fuel oil and kerosene sales 2007. Washington, DC: U.S. Department of Energy, Energy Information Administration, Office of Oil and Gas.
Domingo JL, Gomez M, Llobet JM, 1990. Chelating agents in the treatment of acute vanadyl sulphate intoxication in mice. Toxicology 62(2):203–211.2353359
Domingo JL, Llobet JM, Tomas JM, 1985. Short-term toxicity studies of vanadium in rats. J Appl Toxicol 5(6):418–420.3878374
Domingo JL, Paternan JM, Llobet JM, 1986. Effects of vanadium on reproduction, gestation, parturition and lactation in rats upon oral administration. Life Sci 39:819–824.3747732
*Donaldson J, Hemming R, LaBella F. 1985. Vanadium exposure enhances lipid peroxidation in the kidney of rats and mice. Can J Physiol Pharmacol 63:196–199.3845830
Duce RA, Hoffman GL. 1976. Atmospheric vanadium transport to the ocean. Atmos Environ 10:989–996.1008922
Dundar MS. 2006. Vanadium concentrations in settled outdoor dust particles. Environ Monit Assess 123(1–3):345–350.16761173
Edel J, Sabbioni E. 1988. Retention of intratracheally instilled and ingested tetravalent and pentavalent vanadium in the rat. J Trace Elem Electrolytes Health Dis 2:23–30.2980788
Edel J, Pietra R, Sabbioni E, 1984. Disposition of vanadium in rat tissues at different age. Chemosphere 13:87–93.
Ehrlich VA, Nersesyan AK, Atefie K, 2008. Inhalative exposure to vanadium pentoxide causes DNA damage in workers: Results of a multiple end point study. Environ Health Perspect 116(12):1689–1693.19079721
Elfant M, Keen CL. 1987. Sodium vanadate toxicity in adult and developing rats. Biol Trace Elem Res 14:193–208.24254821
Engler RM. 1979. Bioaccumulation of toxic substances from contaminated sediments by fish and benthic organisms. In: Management of bottom sediments containing toxic substances. Washington, DC: U.S. Environmental Protection Agency, 325–354.
EPA. 1982. Management of hazardous waste leachate. Washington, D.C.: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. PB91181578.
EPA. 1983a. Methods for chemical analysis of water and wastes. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600479020.
EPA. 1983b. Method 286.1. In: Methods for chemical analysis of water and wastes. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600479020.
EPA. 1983c. Method 286.2. In: Methods for chemical analysis of water and wastes. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600479020.
EPA. 1985a. Health and environmental effects profile for vanadium pentoxide. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600x85114.
*EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
EPA. 1994a. Determination of metals and trace elements in water and wastes by inductively coupled plasma-atomic emission spectrometry. Method 200.7. In: Methods for the determination of metals in environmental samples, Supplement 1. Cincinnati, OH: U.S. Environmental Protection Agency. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300036HL.txt. May 22, 2009.
EPA. 1994b. Determination of trace elements in waters and wastes by inductively coupled plasma - mass spectrometry. Method 200.8. In: Methods for the determination of metals in environmental samples, Supplement 1. Cincinnati, OH: U.S. Environmental Protection Agency. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300036HL.txt. May 22, 2009.
EPA. 1994c. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Office of Research and Development, Washington DC. EPA600890066F.
EPA. 1997a. Determination of trace elements in marine waters by on-line chelation preconcentration and inductively coupled plasma - mass spectrometry. Method 200.10. In: Methods for the determination of chemical substances in marine and estuarine environmental matrices. 2nd ed. Cincinnati, OH: National Exposure Research Laboratory, Office of Research and Development, U.S. Environmental Protection Agency. EPA600R97072. http://www.epa.gov/microbes/marinmet.pdf. May 22, 2009.
*EPA. 1997b. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum.
*EPA. 1998a. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
EPA. 1998b. The drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 63:10274. http://www.gpoaccess.gov/fr/index.html. May 11, 2009.
EPA. 2003a. Method 200.5: Determination of trace elements in drinking water by axially viewed inductively coupled plasma - atomic emission spectrometry Cincinnati, OH: U.S. Environmental Protection Agency, National Exposure Research Laboratory, Office of Research and Development. http://www.epa.gov/nerlcwww/m_200_5.pdf. May 23, 2009.
EPA. 2003b. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. http://www.epa.gov/safewater/contaminants/index.html. May 19, 2009.
EPA. 2005a. Partition coefficients for metals in surface water, soil, and waste. Washington DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600R05074.
EPA. 2005b. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2006a. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. http://epa.gov/waterscience/criteria/drinking/. May 19, 2009.
EPA. 2006b. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/criteria/wqcriteria.html. May 11, 2009.
EPA. 2007. Method 6010C: Inductively coupled plasma-atomic emission spectrometry. In: Test methods for evaluating solid waste, physical/chemical methods. U.S. Environmental Protection Agency, http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/6010c.pdf. August 10, 2009.
EPA. 2008. Drinking water contaminant candidate list and regulatory determinations. U.S. Environmental Protection Agency. http://www.epa.gov/OGWDW/ccl/basicinformation.html. August 13, 2009.
EPA. 2009. Vanadium and vanadium compounds. Modernized STORET system: Regular results by project (stormodb): Characteristic search by CAS number. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dbtop.html. April 23, 2009.
EPA. 2010. Hazardous air pollutants. U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.gpo.gov/fdsys/pkg/USCODE-2010-title42/pdf/USCODE-2010-title42-chap85-subchapI-partA-sec7412.pdf. February 2, 2012.
EPA. 2011a. Determination of reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol22/pdf/CFR-2011-title40-vol22-sec117-3.pdf. February 2, 2012.
EPA. 2011b. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-sec302-4.pdf. February 2, 2012.
EPA. 2011c. The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-part355-appA.pdf. February 2, 2012.
*EPA. 2011d. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-sec372-65.pdf. February 2, 2012.
EPA. 2011e. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol31/pdf/CFR-2011-title40-vol31-sec712-30.pdf. February 2, 2012.
EPA. 2011f. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol22/pdf/CFR-2011-title40-vol22-part116.pdf. February 1, 2012.
EPA. 2012. Acute exposure guideline levels (AEGLs). Second AEGL Chemical Priority List. Washington, DC. http://www.epa.gov/oppt/aegl/pubs/priority_2.htm. February 2, 2012.
Etcheverry SB, Cortizo AM. 1998. Bioactivity of vanadium compounds on cells in culture. In: Nriagu JO, ed. Vanadium in the environment. Part I: Chemistry and biochemistry. John Wiley & Sons, Inc., 359–394.
Fawcett JP, Farquhar SJ, Thou T, 1997. Oral vanadyl sulphate does not affect blood cells, viscosity or biochemistry in humans. Pharmacol Toxicol 80:202–206.9140141
FDA. 2008. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/eafus.html. May 19, 2009.
FEDRIP. 2012. Vanadium. Federal Research in Progress database. Springfield, VA: National Technical Information Service. September 2012.
Fernandes KG, Nogueira AR, Neto JA, 2007. Determination of vanadium in human hair slurries by electrothermal atomic absorption spectrometry. Talanta 71(3):1118–1123.19071421
Figueroa DA, Rodriguez-Sierra CJ, Jimenez-Velez BD. 2006. Concentrations of Ni and V, other heavy metals, arsenic, elemental and organic carbon in atmospheric fine particles (PM2.5) from Puerto Rico. Toxicol Ind Health 22(2):87–99.16716038
Fiorentino CE, Paoloni JD, Sequeira ME, 2007. The presence of vanadium in groundwater of southeastern extreme the Pampean region Argentina relationship with other chemicals. J Contam Hydrol 93(1–4):122–129.17379355
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(suppl 5):1169–1175.7081099
Foresti M, Scippa S, Mele F, 2001. A short low-level exposure to metavanadate during a cell cycle-specific interval of time is sufficient to permanently derange the differentiative properties of Mel cells. Mutagenesis 16(5):395–400.11507238
Fox MR. 1987. Assessment of cadmium, lead and vanadium status of large animals as related to the human food chain. J Anim Sci 65:1744–1752.3327851
Franke KW, Moxon AL. 1937. The toxicity of orally ingested arsenic, selenium, tellurium, vanadium and molybdenum. J Pharmacol Exp Ther 61:89–102.
Gallagher FJ, Pechmann I, Bogden JD, 2008. Soil metal concentrations and vegetative assemblage structure in an urban brownfield. Environ Pollut 153(2):351–361.17900771
*Ganguli S, Reuland DJ, Franklin LA, 1994a. Effects of maternal vanadate treatment of fetal development. Life Sci 55(16):1267–1276.7934628
Ganguli S, Reuland DJ, Franklin LA, 1994b. Effect of vanadate on reproductive efficiency in normal and streptozocin-treated diabetic rats. Metabolism 43(11):1384–1388.7968594
Gibson DP, Brauninger R, Shaffi HS, 1997. Induction of micronuclei in Syrian hamster embryo cells: Comparison of results in the SHE cell transformation assay for national toxicology program test chemicals. Mutat Res 392(1–2):61–70.9269331
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(supp 2):65–71.7902273
Goldfine AB, Patti ME, Zuberi L, 2000. Metabolic effects of vanadyl sulfate in humans with noninsulin-dependent diabetes mellitus: in vivo and in vitro studies. Metabolism 49(3):400–410.10726921
Goldfine AB, Simonson DC, Folli F, 1995. Metabolic effects of sodium metavanadate in humans with insulin-dependent and noninsulin-dependent diabetes mellitus in vivo and in vitro studies. J Clin Endocrinol Metab 80(11):3311–3320.7593444
Gomez M, Domingo JL, Llobet JM, 1988. Effectiveness of chelation therapy with time after acute vanadium intoxication. J Appl Toxicol 8:439–444.3230256
Gomez M, Domingo JL, Llobet JM, 1991. Effectiveness of some chelating agents on distribution and excretion of vanadium in rats after prolonged oral administration. J Appl Toxicol 11(3):195–198.1918793
Grayson M. 1983. Kirk-Othmer encyclopedia of chemical technology. 3rd ed. New York, NY: John Wiley & Sons, 688–704.
Gummow B, Botha CJ, Noordhuizen JP, 2005. The public health implications of farming cattle in areas with high background concentrations of vanadium. Prev Vet Med 72(3–4):281–290.16140407
Gummow B, Botha CJ, Williams MC. 2006. Chronic vanadium poisoning in calves and its treatment with calcium disodium ethylenediaminetetraacetate. Vet Res Commun 30(7):807–822.17004042
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Gylseth B, Leira HL, Steinnes E, 1979. Vanadium in the blood and urine of workers in a ferroalloy plant. Scand J Work Environ Health 5:188–194.20120566
Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, 163, 332, 335-336, 524, 542-551, 964-965, 1029-1033, 1058-1059, 1076-1087, 1128-1129, 1209, 1214-1215, 1221, 1224, 1226-1227, 1235-1243, 1250-1252, 1290-1292, 1477-1451, 1481.
*Haider SS, Kashyap SK. 1989. Vanadium intoxication inhibits sulfhydryl-groups and glutathione in the rat brain. Ind Health 27:23–25.2708077
Hamel FG, Duckworth WC. 1995. The relationship between insulin and vanadium metabolism in insulin target tissues. Mol Cell Biochem 153(1–2):95–102.8927053
Hanauske U, Hanauske A, Marshall MH, 1987. Biphasic effect of vanadium salts on in vitro tumor colony growth. Int J Cell Cloning 5:170–178.3106514
*Hansard SL, Ammerman CB, Henry RR, 1982. Vanadium metabolism in sheep. I. Comparative and acute toxicity of vanadium compounds in sheep. J Anim Sci 55:344–349.6982890
Harland BF, Harden-Williams BA. 1994. Is vanadium of human nutritional importance yet? J Am Diet Assoc 94(8):891–894.8046184
Harris WR, Carrano CJ. 1984. Binding of vanadate to human serum transferrin. J Inorg B iochem 22:201–218.
Harris WR, Friedman SB, Silberman D. 1984. Behavior of vanadate and vanadyl ion in canine blood. J Inorg Biochem 20:157–169.6609223
Harrison RM, Smith DJ, Luhana L. 1996. Source apportionment of atmospheric polycyclic aromatic hydrocarbons collected from an urban location in Birmingham, U.K. Environ Sci Technol 30(3):825–832.
HazDat. 2009. Vanadium. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Heit M, Klusek C, Baron J. 1984. Evidence of deposition of anthropogenic pollutants in remote Rocky Mountain lakes. Water Air Soil Pollut 22:403–416.
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoshishima K, Shimai KS, Kano K. 1983. The combined administration of certain metals in trace dose upon the post natal development of behavior in mice. Dev Toxicol Environ Sci 11:529–532.6677499
Hovmand MF, Kemp K, Kystol J, 2008. Atmospheric heavy m etal deposition accumulated in rural forest soils of southern Scandinavia. Environ Pollut 155(3):537–541.18359134
HSDB. 2009. Vanadium and vanadium compounds. Hazardous Substances Data Bank, National Library of Medicine. http://toxnet.nlm.nih.gov. May 21, 2009.
IARC. 2006. Vanadium Pentoxide. In: IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 86: Cobalt in hard metals and cobalt sulfate gallium arsenide, indium phosphide and vanadium pentoxide. Lyon, France: International Agency for Research on Cancer, 227–292.
IARC. 2009. Agents Reviewed by the IARC Monographs. Volumes 1–99. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. May 19, 2009.
Ikem A, Nwankwoala A, Odueyungbo S, 2002. Levels of 26 elements in infant formula from USA, UK, and Nigeria by microwave digestion and ICP-OES. Food Chem 77:439–447.
International Joint Commission. 1978. Great Lakes water quality board - appendix E Status report on organic and heavy metal contaminants in the lakes Erie, Michigan, Huron and Superior basins. Windsor, Ontario: International Joint Commission, Great Lakes Water Quality Board.
IOM. 2001. Arsenic, boron, nickel, silicon, and vanadium. In: Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. Washington, DC: National Academy Press, Food and Nutrition Board, Institute of Medicine. http://books.nap.edu/openbook.php?record_id=10026&page=502. May 27, 2009.
IRIS. 2012. Vanadium pentoxide. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. February 1, 2012.
Irsigler GB, Visser PJ, Spangenberg PA. 1999. Asthma and chemical bronchitis in vanadium plant workers. Am J Ind Med 35(4):366–374.10086213
Ishida O, Kihira K, Tsukamoto Y, 1989. Improved determination of vanadium in biological fluids by electrothermal atomic absorption spectrometry. Clin Chem 35:127–130.2910551
Ivancsits S, Pilger A, Diem E, 2002. Vanadate induces DNA strand breaks in cultured human fibroblasts at doses relevant to occupational exposure. Mutat Res 519(1–2):25–35.12160889
Jain GC, Pareek H, Sharma S, 2007. Reproductive toxicity of vanadyl sulphate in male rats. J Health Sci 53(1):137–141.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190(1):3–16.6769537
Jones MM, Basinger MA. 1983. Chelate antidotes for sodium vanadate and vanadyl sulfate intoxication in mice. J Toxicol Environ Health 12:749–756.6608005
Kada T, Koichi H, Shirasu Y. 1980. Screening of environmental chemical mutagens by the rec-assay system with Bacillus subtilis. In: De Serres FJ, Hollaender A, eds. Chemical mutagens: Principles and methods for their detection. Vol. 6. New York, NY: Plenum Press, 149–173.
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77:109–116.6769036
*Kasibhatla U, Rai V. 1993a. Changes in the plasma levels of phosphatases and transaminases in rabbits following vanadium exposure. Pollut Res 12(1):19–27.
Kasibhatla U, Rai V. 1993b. Haematological changes following vanadium exposure. Geobios 20(2):85–95.
Kennish MJ. 1998. Trace metal-sediment dynamics in estuaries: Pollution assessment. Rev Environ Contam Toxicol 155:69–110.
Kingsnorth AN, LaMuraglia GM, Ross JS, 1986. Vanadate supplements and 1,2-dimethyl-hydrazine induced colon cancer in mice: Increased thymidine incorporation without enhanced carcinogenesis. Br J Cancer 53:683–686.2424483
Kim JY, Hauser R, Wand MP, 2003. Association of expired nitric oxide with urinary metal concentrations in boilermakers exposed to residual oil fly ash. Am J Ind Med 44(5):458–466.14571509
Kinney PL, Chillrud SN, Ramstrom S, 2002. Exposures to multiple air toxics in New York City. Environ Health Perspect 110(suppl 4):539–546.12194883
Kiviluoto M. 1980. Observations on the lungs of vanadium workers. Br J Ind Med 37:363–366.7448130
Kiviluoto M, Pyy L, Pakarinen A. 1981a. Clinical laboratory results of vanadium-exposed workers. Arch Environ Health 36:109–113.6972739
Kiviluoto M, Pyy L, Pakarinen A. 1981b. Serum and urinary vanadium of workers processing vanadium pentoxide. Int Arch Occup Environ Health 48:251–256.6972918
Kiviluoto M, Rasanen O, Rinne A, 1979b. Effects of vanadium on the upper respiratory tract of workers in a vanadium factory: A macroscopic and microscopic study. Scand J Work Environ Health 5:50–58.
*Kiviluoto M, Rasanen O, Rinne A, 1981c. Intracellular immunoglobulins in plasma cells of nasal biopsies taken from vanadium-exposed workers: A retrospective case control study by the peroxidase-antiperoxidase (PAP) method. Anat Anz 149:446–450.7025705
Klein CB, Kargacin B, Su L, 1994. Metal mutagenesis in transgenic Chinese hamster cell lines. Environ Health Perspect 102(suppl 3):63–67.
Kleinsasser N, Dirschedl P, Staudenmaier R, 2003. Genotoxic effects of vanadium pentoxide on human peripheral lymphocytes and mucosal cells of the upper aerodigestive tract. Int J Environ Health Res 13(4):373–379.14594703
Knecht EA, Moorman WJ, Clark JC, 1992. Pulmonary reactivity to vanadium pentoxide following subchronic inhalation exposure in a non-human primate animal model. J Appl Toxicol 12(6):427–434.1452976
Knecht EA, Moorman WJ, Clark JC, 1985. Pulmonary effects of acute vanadium pentoxide inhalation in monkeys. Am Rev Respir Dis 132:1181–1185.3907443
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Koutrakis P, Briggs SLK, Leaderer BP. 1992. Source apportionment of indoor aerosols in Suffolk and Onondaga counties, New York. Environ Sci Technol 26:521–527.
Kowalska M. 1988. The effect of vanadium on lung collagen content and composition in two successive generations of rats. Toxicol Lett 41:203–208.3376147
Krishna AK, Govil PK. 2007. Soil contamination due to heavy metals from an industrial area of Surat, Gujarat, Western India. Environ Monit Assess 124(1–3):263–275.17058016
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kučera J, Byrne AR, Mravcova A, 1992. Vanadium levels in hair and blood of normal and exposed persons. Sci Total Environ 115(3):191–205.1604305
Kučera J, Lener J, Mnukova J, 1998. Vanadium exposure tests in human: Hair, nails, blood. In: Nriagu JO, ed. Vanadium in the environment, part 2: Health effects. New York, NY: John Wiley & Sons, Inc., 55–74.
Kučera J, Sabbioni E. 1998. Baseline vanadium levels in human blood, serum, and urine. In: Nriagu JO, ed. Vanadium in the environment, part 2: Health effects. New York, NY: John Wiley & Sons, Inc., 75–90.
Laden F, Neas LM, Dockery DW, 2000. Association of fine particulate matter from different sources with daily mortality in six U.S. cities. Environ Health Perspect 108(10):941–947.11049813
Lagerkvist B, Nordberg GF, Vouk V. 1986. Vanadium. In: Friberg L, Nordberg GR, Vouk VB, , eds. Handbook on the toxicology of metals. Vol. II: Specific metals. Amsterdam: Elsevier, 638–663.
Lavi N, Alfassi ZB. 1988. Determination of trace amounts of titanium and vanadium in human blood serum by neutron activation analysis: Coprecipitation with Pb/PDC/2 or Be/PDC/3. J Radioanal Chem 126:361–374.
*Lee KP, Gillies PJ. 1986. Pulmonary response and intrapulmonary lipids in rats exposed to bismuth orthovanadate dust by inhalation. Environ Res 40:115–135.3011396
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lener J, Kucera J, Kodl M, 1998. Health effects of environmental exposure to vanadium. In: Nriagu JO, ed. Vanadium in the environment. Part 2: Health Effects. New York, NY: John Wiley & Sons, Inc., 1–19.
Léonard A, Gerber GB. 1994. Mutagenicity, carcinogenicity and teratogenicity of vanadium compounds. Mutat Res 317(1):81–88.7507574
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levy BS, Hoffman L, Gottsegan S. 1984. Boilermakers’ bronchitis. J Occup Med 26:567–570.6332888
Lewis CE. 1959. The biological effects of vanadium. II. The signs and symptoms of occupational vanadium exposure. AMA Arch Ind Health 19:497–503.13636463
Lewis RJ. 2007. Hawley’s condensed chemical dictionary. 15th ed. Hoboken, NJ: John Wiley & Sons, Inc., 71, 1149, 1151.
Lide DR. 2008. CRC handbook of chemistry and physics. 88th ed. Boca Raton, FL: CRC Press, 4-40, 4–90, 4–92, 4–98.
Lin TS, Chang CL, Shen FM. 2004. Whole blood vanadium in Taiwanese college students. Bull Environ Contam Toxicol 73(5):781–786.15669719
Liu Y, Woodin MA, Smith TJ, 2005. Exposure to fuel-oil ash and welding emissions during the overhaul of an oil-fired boiler. J Occup Environ Hyg 2(9):435–443.16048845
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Llobet JM, Domingo JL. 1984. Acute toxicity of vanadium compounds in rats and mice. Toxicol Lett 23:227–231.6334379
Llobet JM, Colomina MT, Sirvent JJ, 1993. Reproductive toxicity evaluation of vanadium in male mice. Toxicology 80(2–3):199–206.8328000
Lusky LM, Braun HA, Laug EP. 1949. The effect of BAL on experimental lead, tungsten, vanadium, uranium, copper and copper-arsenic poisoning. J Ind Hyg Toxicol 31:301–305.18141688
Macias-Zamora JV, Villaescusa-Celaya JA, Munoz-Barbosa A, 1999. Trace metals in sediment cores from the Campeche shelf, Gulf of Mexico. Environ Pollut 104(1):69–77.
Mamane Y, Pirrone N. 1998. Vanadium in the atmosphere. In: Nriagu JO, ed. Advances in environmental science and technology. Vanadium in the environment, Part 1: Chemistry and biochemistry. Vol. 30. New York, NY: John Wiley and Sons, 37–71.
Martin DM, Chasteen ND. 1988. Vanadium. Methods Enzymol 158:402–421.2836695
Martin HW, Kaplan DI. 1998. Temporal changes in cadmium, thallium and vanadium mobility in soil and phytoavailability under field conditions. Water Air Soil Pollut 101(1–4):399–410.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
Mermut AR, Jain JC, Song L, 1996. Trace element concentrations of selected soils and fertilizers in Saskatchewan, Canada. J Environ Qual 25(4):845–853.
Mielke HW, Gonzales CR, Smith MK, 2000. Quantities and associations of lead, zinc, cadmium, manganese, chromium, nickel, vanadium, and copper in fresh Mississippi Delta alluvium and New Orleans alluvial soils. Sci Total Environ 246:249–259.10696726
Migliore L, Bocciardi R, Macri C, 1993. Cytogenetic damage induced in human lymphocytes by four vanadium compounds and micronucleus analysis by fluorescence in situ hybridization with a centromeric probe. Mutat Res 319(3):205–213.7694142
Migliore L, Scarpato R, Falco P. 1995. The use of fluorescence in situ hybridization with a beta-satellite DNA probe for the detection of acrocentric chromosomes in vanadium-induced micronuclei. Cytogenet Cell Genet 69(3–4):215–219.7698016
Miguel AH, De Aquino Neto FR, Cardoso JN, 1995. Characterization of indoor air quality in the cities of Sao Paulo and Rio de Janeiro, Brazil. Environ Sci Technol 29:338–345.22201379
Mitchell WG, Floyd EP. 1954. Ascorbic acid and ethylene diamine tetraacetate as antidotes in experimental vanadium poisoning. Proc Soc Exp Biol Med 85:206–208.13155548
Morgan AM, El-Tawil OS. 2003. Effects of ammonium metavanadate on fertility and reproductive performance of adult male and female rats. Pharmacol Res 47(1):75–85.12526865
Morrison RJ, Gangaiya P, Naqasima MR, 1997. Trace metal studies in the Great Astrolabe Lagoon, Fiji, a pristine marine environment. Mar Pollut Bull 34(5):353–356.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Mosher BW, Winkler P, Jaffrezo JL. 1993. Seasonal aerosol chemistry at dye 3 greenland. Atmospheric Environment Part a General Topics 27(17–18):2761–2772.
Mountain JT, Delker LL, Stokinger HE. 1953. Studies in vanadium toxicology. Reduction in the cystine content of rat hair. AMA Arch Ind Hyg Occup Med 8:406–411.13091443
Mousty F, Omenetto N, Pietra R, 1984. Atomic-absorption spectrometric, neutron-activation and radioanalytical techniques for the determination of trace metals in environmental, biochemical and toxicological research. Part I. Vanadium. Analyst 109:1451–1454.6529007
Mravcová A, Jirova D, Janci H, 1993. Effects of orally administered vanadium on the immune system and bone metabolism in experimental animals. Sci Total Environ Suppl Pt 1:663–669.
Mukherjee B, Patra B, Mahapatra S, 2004. Vanadium-an element of atypical biological significance. Toxicol Lett 150(2):135–143.15093669
Musk AW, Tees JG. 1982. Asthma caused by occupational exposure to vanadium compounds. Med J Aust 1:183–184.6978990
NAS/NRC. 1989. Report of the oversight committee. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. Biologic markers in reproductive toxicology.
*Naylor GJ, Smith AH, Bryce-Smith D, 1984. Elevated vanadium content of hair and mania. Biol Psychiatry 19:759–764.6733183
NIOSH. 1983. Health hazard evaluation report HETA 80-096-1359, Eureka Company, Bloomington, IL. Washington, DC: U.S. Department of Health and Human Services, National Institute of Occupational Safety and Health. PB85163574.
NIOSH. 1994. Vanadium oxides. Method 7504. In: NIOSH manual of analytical methods. Centers for Disease Control, National Institute for Occupational Safety and Health, http://www.cdc.gov/niosh/nmam/pdfs/7504.pdf. May 26, 2009.
NIOSH. 2003a. Elements by ICP (nitric/perchloric acid ashing). Method 7300. In: NIOSH manual of analytical methods. 4th ed. Centers for Disease Control, National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/7300.pdf. May 26, 2009.
NIOSH. 2003b. Elements by ICP (aqua regia ashing). Method 7301. In: NIOSH manual of analytical methods. 4th ed. Centers for Disease Control, National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/7301.pdf. May 26, 2009.
NIOSH. 2003c. Elements by ICP (hot block/HCl/HNO3 digestion). Method 7303. In: NIOSH manual of analytical methods. 4th ed. Centers for Disease Control, National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/7303.pdf. May 26, 2009.
NIOSH. 2003d. Elements on wipes. Method 9102. In: NIOSH manual of analytical methods. 4th ed. Centers for Disease Control, National Institute for Occupational Safety and Health, http://www.cdc.gov/niosh/nmam/pdfs/9102.pdf. May 26, 2009.
NIOSH. 2004. NIOSH Health Hazard Evaluation Report: HETA No. 2003-0171-2925, PCC Schlosser, Redmond, Oregon. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 2012. Vanadium compounds. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. July 12, 2012.
Nixon DE, Neubauer KR, Eckdahl SJ, 2002. Evaluation of a tunable bandpass reaction cell for an inductively coupled plasma mass spectrometer for the determination of chromium and vanadium in serum and urine. Spectrochim Acta Part B 57:951–966.
NLM. 2009. Vanadium. Bethesda, MD: U.S. National Library of Medicine, National Institutes of Health, Department of Health and Human Services. http://dietarysupplements.nlm.nih.gov/dietary/ingredDetail.jsp?contain=Vanadium&id=1280. June 17, 2009.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
Nriagu JO. 1992. Review: Toxic metal pollution in Africa. Sci Total Environ 121:1–37.1439723
NTP. 2002. NTP toxicology and carcinogenesis studies of vanadium pentoxide (CAS No. 1314-62-1) in F344/N rats and B6C3F1 mice (inhalation). Natl Toxicol Program Tech Rep Ser (507):1–343.
NTP. 2011. Report on carcinogens, 12th edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. September 21, 2012.
NTP. 2008. Chemical information review document for oral exposure to tetravalent and pentavalent vanadium compounds. National Toxicology Program, National Institute of Environmental Health Sciences, National Institutes of Health,. http://ntp.niehs.nih.gov/ntp/htdocs/Chem_Background/ExSumPdf/NIEHS_Vanadium_compounds_508.pdf. August 3, 2009.
Oberg SG, Parker R, Sharma RP. 1978. Distribution and elimination of an intratracheally administered vanadium compound in the rat. Toxicology 11:315–323.749270
O’Neil MJ, Heckelman PE, Koch CB, eds. 2006. The merck index. 14th ed. Whitehouse Station, NJ: Merck & Co., Inc., 90, 4192, 1705–1706.
Ordóñez A, Loredo J, Demiguel E, 2003. Distribution of heavy m etals in the street dusts and soils of an industrial city in northern Spain. Arch Environ Contam Toxicol 44:160–170.12520388
OSHA. 1991. Confirmation of vanadium pentoxide in workplace atmospheres. Occupational Safety and Health Administration. http://www.osha.gov/dts/sltc/methods/inorganic/id185/id185.html. April 7, 2009.
OSHA. 2002. Metal and metalloid particulates in workplace atmospheres (ICP analysis). Occupational Safety and Health Administration. Division of Physical Measurements and Inorganic Analyses, OSHA Technical Center. http://www.osha.gov/dts/sltc/methods/inorganic/id125g/id125g.pdf. May 23, 2009.
OSHA. 2011. Toxic and Hazardous Substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z 1. http://www.gpo.gov/fdsys/pkg/CFR-2011-title29-vol6/pdf/CFR-2011-title29-vol6-sec1910-1000.pdf. February 2, 2012.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Owusu-Yaw J, Cohen MD, Fernando SY, 1990. An assessment of the genotoxicity of vanadium. Toxicol Lett 50(2–3):327–336.2309250
Parker RD, Sharma RP. 1978. Accumulation and depletion of vanadium in selected tissues of rats treated with vanadyl sulfate and sodium orthovanadate. J Environ Pathol Toxicol 2:235–245.739212
Paternain JL, Domingo JL, Gomez M, 1990. Developmental toxicity of vanadium in mice after oral administration. J Appl Toxicol 10(3):181–186.2380479
Paternain JL, Domingo JL, Llobet JM, 1987. Embryotoxic effects of sodium metavanadate administered to rats during organogenesis. Rev Esp Fisiol 43(2):223–228.3659548
Patterson BW, Hansard SL, Ammerman CB, 1986. Kinetic model of whole-body vanadium metabolism: Studies in sheep. Am J Physiol 251:R325–R332.3740315
Pennington JA, Jones JW. 1987. Molybdenum, nickel, cobalt, vanadium, and strontium in total diets. J Am Diet Assoc 12:1644–1650.
Poggioli R, Arletti R, Bertolini A, 2001. Behavioral and developmental outcomes of prenatal and postnatal vanadium exposure in the rat. Pharmacol Res 43(4):341–347.11352539
Polissar AV, Hopke PK, Poirot RL. 2001. Atmospheric aerosol over Vermont: Chemical composition and sources. Environ Sci Technol 35:4604–4621.11770762
Poucheret P, Verma S, Grynpas MD, 1998. Vanadium and diabetes. Mol Cell Biochem 188:73–80.9823013
Pyrzyńska K, Wierzbicki T. 2004. Determination of vanadium species in environmental samples. Talanta 64:823–829.18969676
Ramanadham S, Heyliger C, Gresser MJ, 1991. The distribution and half-life for retention of vanadium in the organs of normal and d iabetic rats orally fed vanadium(IV) and vanadium(V). Biol Trace Elem Res 30(2):119–124.1723884
Rhoads K, Samders CL. 1985. Lung clearance, translocation, and acute toxicity of arsenic, beryllium, cadmium, cobalt, lead, selenium, vanadium and ytterbium oxides following deposition in rat lung. Environ Res 36:359–378.3872210
Riediker M, Williams R, Devlin R, 2003. Exposure to particulate matter, volatile organic compounds, and other air pollutants inside patrol cars. Environ Sci Technol 37:2084–2093.12785511
Rodriguez-Mercado JJ, Mateos-Nava RA, Altamirano-Lozano MA. 2011. DNA damage induction in human cells exposed to vanadium oxides in vitro. Toxicology I n Vitro [Epub ahead of print].
Rojas E, Valverde M, Herrera LA, 1996. Genotoxicity of vanadium pentoxide evaluate by the single cell gel electrophoresis assay in human lymphocytes. Mutat Res 359(2):77–84.8598834
Roldán RE, Altamirano LM. 1990. Chromosomal aberrations, sister-chromatid exchanges, cell-cycle kinetics and satellite associations in human lymphocyte cultures exposed to vanadium pentoxide. Mutat Res 245(2):61–66.2215552
Rondini EA, Walters DM, Bauer AK. 2010. Vanadium pentoxide induces pulmonary inflammation and tumor promotion in a strain-dependent manner. Part Fibre Toxicol 7:9. http://www.particleandfibretoxicology.com/content/pdf/1743-8977-7-9.pdf. November 29, 2011. 20385015
*Roschin IV. 1967. [Vanadium]. In: Izrael’son ZI, ed. [Toxicology of the rare metals]. Jerusalem: Israel Program for Scientific Translations, 52–60. (Russian)
Roshchin AV, Ordzhonikidze EK, Shalganova IV. 1980. [Vanadium-toxicity, metabolism, carrier state]. J Hyg Epidemiol Microbiol Immunol 24:377–383. (Russian)
RTECS. 2009. Vanadium and vanadium compounds. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. May 26, 2009.
Rydzynski K. 2001. Vanadium, Niobium, and Tantalum. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. Vol. 3. 5th ed. New York, NY: John Wiley & Sons, Inc., 1–38.
Sabbioni E, Marafante E. 1978. Metabolic patterns of vanadium in the rat. Bioinorg Chem 9:389–408.
Sabbioni E, Kueera J, Pietra R, 1996. A critical review on normal concentrations of vanadium in human blood, serum, and urine. Sci Total Environ 188(1):49–58.8810089
Sadiq M, Alam I. 1997. Metal concentrations in a shallow groundwater aquifer underneath petrochemical complex. Water Res 31(12):3089–3097.
Sadiq M, Mian AA. 1994. Nickel and vanadium in air particulates at Dhahran (Saudi Arabia) during and after the Kuwait oil fires. Atmos Environ 28(13):2249–2253.
Salazar-Coria L, Amezcua-Allieri MA, Tenorio-Torres M, 2007. Polyaromatic hydrocarbons (PAHs) and metal evaluation after a diesel spill in Oaxaca, Mexico. Bull Environ Contam Toxicol 79(4):462–467.17712506
Saleh MA, Wilson BL. 1999. Analysis of metal pollutants in the Houston Ship Channel by inductively coupled plasma/mass spectrometry. Ecotoxicol Environ Saf 44:113–117.10499997
Sanchez D, Ortega A, Domingo JL, 1991. Developmental toxicity evaluation of orthovanadate in the mouse. Biol Trace Elem Res 30(3):219–226.1720642
Sanchez DJ, Colomina MT, Domingo JL. 1998. Effects of vanadium on activity and learning in rats. Physiol Behav 63(3):345–350.9469725
Sanchez DJ, Colomina MT, Domingo JL, 1999. Prevention by sodium 4,5-dihydroxybenzene-1,3-disulfonate (tiron) of vanadium-induced behavioral toxicity in rats. Biol Trace Elem Res 69(3):249–259.10468162
Schroeder HA, Balassa JJ. 1967. Arsenic, germanium, tin and vanadium in mice: Effects on growth, survival and tissue levels. J Nutr 92(2):245–252.6029075
Schroeder HA, Mitchener M. 1975. Life-term effects of mercury, methyl mercury, and nine other trace metals on mice. J Nutr 105(4):452–458.1113210
Schroeder HA, Balassa JJ, Tipton IH. 1963. Abnormal trace metals in man - vanadium. J Chronic Dis 16:1047–1071.14068919
Schroeder HA, Mitchener M, Nason AP. 1970. Zirconium, niobium, antimony, vanadium and lead in rats: Life term studies. J Nutr 100(1):59–68.5412131
Schroeder WH, Dobson M, Kane DM, 1987. Toxic trace elements associated with airborne particulate matter: A review. JAPCA 37(11):1267–1285.3327920
Schuhmacher M, Bocio A, Agramunt MC, 2002. PCDD/F and metal concentrations in soil and herbage samples collected in the vicinity of a cement plant. Chemosphere 48:209–217.12117056
Scibior A. 2005. Some selected blood parameters in rats exposed to vanadium and chromium via drinking water. Trace Elem Electrolytes 22(1):40–46.
Scibior A, Zaporowska H, Ostrowski J. 2006. Selected haematological and biochemical parameters of blood in rats after subchronic administration of vanadium and/or magnesium in drinking water. Arch Environ Contam Toxicol 51(2):287–295.16783625
Seiler HG. 1995. Analytical procedures for the determination of vanadium in biological materials. In: Sigel H, Sigel A, eds. Metal ions in biological systems. New York, NY: Marcel Dekker, Inc., 671–688.
Sepe A, Ciaralli L, Ciprotti M, 2003. Determination of cadmium, chromium, lead and vanadium in six fish species from the Adriatic Sea. Food Addit Contam 20(6):543–552.12881127
Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Sharma RP, Bourcier DR, Brinkerhoff CR, 1981. Effects of vanadium on immunologic functions. Am J Ind Med 2(2):91–99.7349044
Sharma RP, Oberg SG, Parker RD. 1980. Vanadium retention in rat tissues following acute exposures to different dose levels. J Toxicol Environ Health 6:45–54.7381974
Sheridan CJ, Pfleger RC, McClellan RO. 1978. Cytotoxicity of vanadium pentoxide on pulmonary alveolar macrophages from dog, rabbit, and rat: Effect on viability and effect on lipid metabolism. Ann Resp Inhalation Toxicol:294–298.
Sjöberg SG. 1950. Vanadium pentoxide dust: A clinical and experimental investigation on its effect after inhalation. Stockholm: Esselte AB, 6–188.
Sjöberg SG. 1956. Vanadium dust, chronic bronchitis and possible risk of emphysema. Acta Med Scand 154:381–386.13326280
Smith DJ, Harrison RM, Luhana L, 1996. Concentrations of particulate airborne polycyclic aromatic hydrocarbons and metals collected in Lahore, Pakistan. Atmos Environ 30(23):4031–4040.
Smith JB. 1983. Vanadium ions stimulated DNA synthesis in Swill mouse 3T3 and 3T6 cells. Proc Natl Acad Sci USA 80:6162–6166.6353410
Smith DM, Pickering RM, Lewith GT. 2008. A systematic review of vanadium oral supplements for glycaemic control in type 2 diabetes mellitus. Q J Med 101(5):351–358.
Somerville J, Davies B. 1962. Effect of vanadium on serum cholesterol. Am Heart J 64:54–56.13915099
Sora S, Carbone MLA, Pacciarini M, 1986. Disomic and diploid meiotic products induced in Saccharomyuces cerevisiae by the salts of 27 elements. Mutagenesis 1(1):21–28.3325730
SRI. 2008. Directory of chemical producers: United States. Menlo Park, CA: SRI Consulting, 912.
Steffen RP, Pamnani MB, Clough DL, 1981. Effect of prolonged dietary administration of vanadate on blood pressure in the rat. Hypertension 3(3 Pt 2):I-173 to I-178.6266956
Stokinger HE, Wagner WD, Mountain JT, 1953. Unpublished results. Cincinnati, OH: Division of Occupational Health. (As cited in IRIS 2012).
Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 406–407.
Susic D, Kentera D. 1986. Effect of chronic vanadate administration on pulmonary circulation in the rat. Respiration 49:68–72.2937124
Susic D, Kentera D. 1988. Dependence of the hypertensive effect of chronic vanadate administration on renal excretory function in the rat. J Hypertens 6(3):199–204.3361118
Sweet CW, Vermette SJ, Landsberger S. 1993. Sources of toxic trace elements in urban air in Illinois. Environ Sci Technol 27(12):2502–2510.
Taylor HE, Antweiler RC, Roth DA, 2001. The occurrence and distribution of selected trace elements in the upper Rio Grande and tributaries in Colorado and northern New Mexico. Arch Environ Contam Toxicol 41:410–426.11598778
Thomas DL, Stiebris K. 1956. Vanadium poisoning in industry. Med J Aust 1:607–609.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thomas KW, Pellizzari ED, Berry MR. 1999. Population-based dietary intakes and tap water concentrations for selected elements in the EPA region V national human exposure assessment survey (NHEXAS). J Expo Anal Environ Epidemiol 9:402–413.10554143
Thompson KH, Orvig C. 2006. Vanadium in diabetes: 100 years from Phase 0 to Phase I. J Inorg Biochem 100(12):1925–1935.17055061
Thompson HJ, Chasteen ND, Meeker LD. 1984. Dietary vanadyl (IV) sulfate inhibits chemically-induced mammary carcinogenesis. Carcinogenesis 5:849–851.6722991
Thompson KH, Tsukada Y, Xu Z, 2002. Influence of chelation and oxidation state on vanadium bioavailability, and their effects on tissue concentrations of zinc, copper, and iron. Biol Trace Elem Res 86(1):31–44.12002658
TRI09. 2011. TRI explorer. Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access, Office of Environmental Information, U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. September 23, 2011.
Tubafard S, Fatemi SJ, Saljooghi AS, 2010. Removal of vanadium by combining desferrioxamine and deferiprone chelators in rats. Med Chem Res 19(8):854–863.
Turpin EA, Antao-Menezes A, Cesta MF, 2010. Respiratory syncytial virus infection reduces lung inflammation and fibrosis in mice exposed to vanadium pentoxide. Respir Res 11:20. http://respiratory-research.com/content/pdf/1465-9921-11-20.pdf. November 29, 2011. 20175905
USGS. 1987. Metals, atomic emission spectrometry, inductively coupled plasma (ICP). In: Methods for the determination of inorganic substances in water and fluvial sediments, techniques of water-resources investigations of the United States Geological Survey. Denver, CO: U.S. Geological Survey. http://infotrek.er.usgs.gov/pls/htmldb/f?p=119:38:8660777138310287::::P38_METHOD_ID:8896. May 23, 2009.
USGS. 1993. Vanadium, colorimetry, catalytic oxidation, automated-segmented flow. U.S. Geological Survey. http://pubs.er.usgs.gov/djvu/OFR/1993/ofr_93_125.djvu. May 26, 2009.
USGS. 1996. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory - preparation procedure for aquatic biological material determined for trace metals. Denver, CO: U.S. Geological Survey, Department of the Interior. Open-File Report 96-362. http://nwql.usgs.gov/Public/pubs/OFR96-362/OFR96-362.pdf. May 22, 2009.
USGS. 1998. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory - determination of elements in whole-water digests using inductively coupled plasma-optical emission spectrometry and inductively coupled plasma-optical emission spectrometry and inductively coupled plasma-mass spectrometry. Denver, CO: U. S. Geological Survey. Open-File Report 98-165. http://pubs.er.usgs.gov/usgspubs/ofr/ofr98165. May 22, 2009.
USGS. 1999. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory - determination of dissolved arsenic, boron, lithium, selenium, strontium, thallium, and vanadium using inductively. Denver, CO: U.S. Geological Survey. Open-file report 99-093. http://nwql.usgs.gov/Public/pubs/OFR99-093/OFR99-093.pdf. May 23, 2009.
USGS. 2006. Determination of elements in natural-water, biota, sediment, and soil samples using collision/reaction cell inductively - coupled plasma - mass spectrometry. U.S. Department of the Interior, U.S. Geological Survey. http://pubs.usgs.gov/tm/2006/tm5b1/PDF/TM5-B1.pdf. May 22, 2009.
USGS. 2009b. 2007 Minerals yearbook. U.S. Department of the Interior, U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/vanadium/myb1-2007-vanad.pdf. May 27, 2009.
USGS. 2009a. Quality of water from domestic wells in principal aquifers of the United States, 1991–2004. Reston, VA: U.S. Department of the Interior, U.S. Geological Survey. Scientific Investigations Report 2008–5227. http://pubs.usgs.gov/sir/2008/5227. August 3, 2009.
USGS. 2012. Vanadium. Mineral commodity summaries. U.S. Geological Survey. 178–179. http://minerals.usgs.gov/minerals/pubs/commodity/vanadium/mcs-2012-vanad.pdf. July 12, 2012.
Van Zinderen Bakker, Jaworski JF. 1980. Effects of vanadium in the Canadian environment. Ottawa, Canada: National Research Council Canada, Associate Committee Scientific Criteria for Environmental Quality, 1–94.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Villani P, Cordelli E, Leopardi P, 2007. Evaluation of genotoxicity of oral exposure to tetravalent vanadium in vivo. Toxicol Lett 170(1):11–18.17374461
Vintinner FJ, Vallenas R, Carlin CE, 1955. Study of the health of workers employed in mining and processing of vanadium ore. AMA Arch Ind Health 12:635–642.13268082
Vouk VB. 1979. Vanadium. In: Friberg L, Nordberg GR, Vouk VB, eds. Handbook on the toxicology of metals. New York, NY: Elsevier North Holland, 659–674.
Wang L, Medan D, Mercer R, 2003. Vanadium-induced apoptosis and pulmonary inflammation in mice: Role of reactive oxygen species. J Cell Physiol 195(1):99–107.12599213
Waters MD. 1977. Toxicology of vanadium. In: Mehlam MA, Marzulli FN, Maibach HI, eds. Advances in Modern Toxicology. Vol. 2. New York, NY: Wiley, 147–189.
Waters MD, Gardner DE, Coffin DL. 1974. Cytotoxic effects of vanadium on rabbit alveolar macrophages in vitro. Toxicol Appl Pharmacol 28:253–263.4851253
Wehrli B, Stumm W. 1989. Vanadyl in natural waters: Adsorption and hydrolysis promote oxygenation. Geochim Cosmochim Acta 53:69–77.
Wei C, Misra HP. 1982. Cytotoxicity of ammonium metavanadate to cultured bovine alveolar macrophages. J Toxicol Environ Health 9:995–1006.6981709
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Westenfelder C, Hamburger RK, Garcia ME. 1981. Effect of vanadate on renal tubular function in rats. Am J Physiol Renal Physiol 240(6):F522–F529.
WHO. 1988. Vanadium. In: Environmental health criteria 81. Geneva, Switzerland: World Health Organization,
WHO. 2000. Air quality guidelines. 2nd edition. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/activities/20050223_4. May 11, 2009.
WHO. 2006. Guidelines for drinking-water quality. 3rd edition. Geneva, Switzerland: World Health Organization.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Vol. II. New York, NY: Academic Press, 1–247.
*Wide M. 1984. Effect of short-term exposure to five industrial metals on the embryonic and fetal development of the mouse. Environ Res 33(1):47–53.6692813
Witkowska D, Oledzka R, Markowska B. 1988. Effect of intoxication with vanadium compounds on copper metabolism in the rat. Bull Environ Contam Toxicol 40:309–316.3349204
Woodin MA, Hauser R, Liu Y, 1998. Molecular markers of acute upper airway inflammation in workers exposed to fuel-oil ash. Am J Respir Crit Care Med 158(1):182–187.9655727
Woolery M. 2005. Vanadium compounds. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/vanawool.a01/current/pdf. May 27, 2009.
Wozniak K, Blasiak J. 2004. Vanadyl sulfate can differentially damage DNA in human lymphocytes and HeLa cells. Arch Toxicol 78(1):7–15.13680095
Wyers H. 1946. Some toxic effects of vanadium pentoxide. Br J Ind Med 3:177–182.20991176
Yao J, Battell ML, McNeill JH. 1997. Acute and chronic response to vanadium following two methods of streptozotocin-diabetes induction. Can J Physiol Pharmacol 75(2):83–90.9114928
Yu D, Walters DM, Zhu L, 2011. Vanadium pentoxide (V_2_O_5_) induced mucin production by airway epithelium. Am J Physiol Lung Cell Mol Physiol 301(1):L31–L39.21531775
Zaporowska H, Wasilewski W. 1989. Some selected peripheral blood and haemopoietic system indices in Wistar rats with chronic vanadium intoxication. Comp Biochem Physiol C Comp Pharmacol Toxicol 93C(1):175–180.
Zaporowska H, Wasilewski W. 1990. Some selected hematological indices in Wistar rats in the vanadium-ethanol interaction. Comp Biochem Physiol C Comp Pharmacol Toxicol 96(1):33–38.1980881
Zaporowska H, Wasilewski W. 1991. Significance of reduced food and water consumption in rats intoxicated with vanadium. Comp Biochem Physiol C 99(3):349–352.1685406
Zaporowska H, Wasilewski W. 1992a. Combined effect of vanadium and zinc on certain selected haematological indices in rats. Comp Biochem Physiol C 103(1):143–147.1360368
Zaporowska H, Wasilewski W. 1992b. Haematological results of vanadium intoxication in Wistar rats. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 101C(1):57–61.
Zaporowska H, Wasilewski W, Slotwinska M. 1993. Effect of chronic vanadium administration in drinking water to rats. Biometals 6(1):3–10.8471823
Zenz C, Berg BA. 1967. Human responses to controlled vanadium pentoxide exposure. Arch Environ Health 14:709–712.6024651
Zenz C, Bartlett JP, Thiede WM, 1962. Acute vanadium pentoxide intoxication. Arch Environ Health 5:542–546.14003485
Zhong BZ, Gu ZW, Wallace WE, 1994. Genotoxicity of vanadium pentoxide in Chinese hamster V79 cells. Mutat Res 321(1–2):35–42.7510843
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zoller WH, Gordon GE, Cladney ES, 1973. The sources and distribution of vanadium in the atmosphere. In: Advances in chemistry series no. 123. Trace elements in the environment. Washington DC: American Chemical Society, 31–47.