# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration inhalation MRL of 0.0008 mg vanadium/m^3^ based on a LOAEL of 0.56 mg vanadium/m^3^ for lung inflammation in rats exposed to vanadium pentoxide 6 hours/day, 5 days/week for 13 days (NTP 2002). The MRL was derived by dividing the human equivalent concentration of the LOAEL (0.073 mg vanadium/m^3^) by an uncertainty factor of 90 (3 for use of a minimal LOAEL, 3 for animal to human extrapolation with dosimetric adjustments, and 10 for human variability).

ATSDR has derived a chronic-duration inhalation MRL of 0.0001 mg vanadium/m^3^ based on a BMCL_10_ of 0.04 mg vanadium/m^3^ for degeneration of epiglottis respiratory epithelium of rats exposed to vanadium pentoxide 6 hours/day, 5 days/week for 2 years (NTP 2002). The MRL was derived by dividing the human equivalent concentration of the BMCL_10_ (0.003 mg vanadium/m^3^) by an uncertainty factor of 30 (3 for animal to human extrapolation with dosimetric adjustments and 10 for human variability).

ATSDR has derived an intermediate-duration oral MRL of 0.01 mg vanadium/kg/day based on a NOAEL of 0.12 mg vanadium/kg/day for hematological and blood pressure effects in humans exposed to vanadyl sulfate for 12 weeks (Fawcett et al. 1997) and an uncertainty factor of 10 for human variability.

IRIS (2012) has derived an oral reference dose (RfD) of 0.009 mg/kg/day for vanadium pentoxide based on a NOAEL of 0.89 mg/kg/day for decreased hair cysteine levels in rats exposed to vanadium pentoxide for 2.5 years (Stokinger et al. 1953) and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 to protect against unusually susceptible individuals).

EPA has not derived an inhalation reference concentration (RfC) for vanadium and vanadium compounds.

Vanadium pentoxide, vanadyl sulfate dehydrate, and ammonium metavanadate are on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986" and have been assigned a reportable quantity (RQ) limit of 1,000 pounds each (EPA 20011b). Vanadium pentoxide is also considered to be an extremely hazardous substance (EPA 2011c). The RQ represents the amount of a designated hazardous substance which, when released to the environment, must be reported to the appropriate authority.

The international and national regulations, advisories, and guidelines regarding vanadium and compounds in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Vanadium and Compounds

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2009
| Vanadium pentoxide | Group 2B^a^
WHO | Air quality guidelines | | WHO 2000
| Vanadium
| TWA based on effects other than cancer or odor/annoyance using an averaging time of 24 hours | 1 μg/m^3^
| Drinking water quality guidelines | No data | WHO 2006
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA)^b^ | | ACGIH 2008
| Vanadium pentoxide (respirable fraction of dust or fume, as V_2_O_5_) | 0.05 mg/m^3^
| TLV Basis | Irritation and lung
AIHA | ERPG values | No | AIHA 2008
EPA | Second AEGL chemical priority list | | EPA 2012
| Vanadium and compounds | Yes^c^
| Hazardous air pollutant | No | EPA 2010 42; USC 7412
NIOSH | REL (15-minute ceiling) | | NIOSH 2012
| Vanadium compounds^a^ | 0.05 mg/m^3^
| REL (TWA)
| Vanadium metal and vanadium carbide | 1 mg/m^3^
| IDLH | 35 mg/m^3^
| Target organ | Eyes, skin, and respiratory system
OSHA | PEL (ceiling limit) for general industry | 0.5 mg/m^3^ | OSHA 2011
| Vanadium pentoxide | | 29 CFR 1910.1000,
| Respirable dust (as V_2_O_5_) | | Table Z-1
| Fume (as V_2_O_5_) | 0.1 mg/m^3^
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | | EPA 2011f 40 CFR 116.4
| Vanadium pentoxide | Yes
| Vanadyl sulfate dehydrate | Yes
| Drinking water contaminant candidate list | | EPA 1998b 63 FR 10274
| Vanadium | Yes
EPA | Drinking water standards and health advisories | No | EPA 2006a
| National primary drinking water standards | No | EPA 2003b
| National recommended water quality criteria | No | EPA 2006b
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2011a 40 CFR 117.3
| Vanadium pentoxide | 1,000 pounds
| Vanadyl sulfate dehydrate | 1,000 pounds
c. Food
FDA | EAFUS^e^ | No | FDA 2008
d. Other
ACGIH | Carcinogenicity classification | A4^f^ | ACGIH 2008
| Biological exposure indices (end of shift at end of workweek)
| Vanadium in urine | 50 μg/g creatinine
EPA | Carcinogenicity classification | No | IRIS 2012
| RfC | No
| RfD
| Vanadium pentoxide | 9×10^−3^ mg/kg/day
| Superfund, emergency planning, and community right-to-know
| Designated CERCLA hazardous substance and their reportable quantities | | EPA 2011b 40 CFR 302.4
| Vanadium pentoxide^g^ | 1,000 pounds
| Vanadyl sulfate^h^ | 1,000 pounds
| Vanadi c acid, ammonium salt^i^ | 1,000 pounds
| Effective date of toxic Chemical release reporting | | EPA 2011d 40 CFR 372.65
| Vanadium (except when contained in an alloy) | 01/01/2000
| Extremely hazardous substance and its threshold planning quantity | | EPA 2011c 40 CFR 355,
| Vanadium pentoxide | 100/10,000 pounds | Appendix A
| TSCA chemical lists and reporting periods | | EPA 2011e 40 CFR 712.30
| Vanadium, vanadium pentoxide, vanadyl sulfate pentahydrate, sodium metavanadate, sodium orthovanadate, and ammonium metavanadate
| Effective date | 07/11/2003
| Reporting date | 09/09/2003
DHHS | Carcinogenicity classification | No data | NTP 2011
IOM | Upper Tolerable Limit | 1.8 mg/day | IOM 2001

a Group 2B: possibly carcinogenic to humans

b Vanadium peroxide is included in the 2008 Notice of Intended Changes in which the substance and its corresponding values and notations for which the withdrawal of the Documentation and adopted TLV are proposed.

c Vanadium and compounds are included on the list of 371 priority chemicals that are acutely toxic and represent the selection of chemicals for AEGL development by the NAC/AEGL committee during the next several years.

d The REL applies to all vanadium compounds except vanadium metal and vanadium carbide.

e The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

f A4: not classifiable as a human carcinogen

g Designated CERCLA hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act and Section 3001 of the Resource Conservation and Recovery Act.

h Designated CERCLA hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act.

i Designated CERCLA hazardous substance pursuant to Section 3001 of the Resource Conservation and Recovery Act.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DHHS = Department of Health and Human Services; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; IOM = Institute of Medicine; NAC = National Advisory Council; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization