# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Vanadium is a naturally occurring element that appears in group 5(B5) of the periodic table (Lide 2008). Vanadium is widely distributed in the earth’s crust at an average concentration of 100 ppm (approximately 100 mg/kg), similar to that of zinc and nickel (Byerrum 1991). Vanadium is the 22^nd^ most abundant element in the earth’s crust (Baroch 2006). Vanadium is found in about 65 different minerals; carnotite, roscoelite, vanadinite, and patronite are important sources of this metal along with bravoite and davidite (Baroch 2006, Lide 2008). It is also found in phosphate rock and certain ores and is present in some crude oils as organic complexes (Lide 2008). Table 4-1 lists common synonyms and other pertinent identification information for vanadium and representative vanadium compounds.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Vanadium is a gray metal with a body-centered cubic crystal system. It is a member of the first transition series. Because of its high melting point, it is referred to as a refractory metal (Baroch 2006). When highly pure, it is a bright white metal that is soft and ductile. It has good structural strength and a low-fission neutron cross section. Vanadium has good corrosion resistance to alkalis, sulfuric and hydrochloric acid, and salt water; however, the metal oxidizes readily above 660 °C (Lide 2008). The chemistry of vanadium compounds is related to the oxidation state of the vanadium (Woolery 2005). Vanadium has oxidation states of +2, +3, +4, and +5. When heated in air at different temperatures, it oxidizes to a brownish black trioxide, a blue black tetraoxide, or a reddish orange pentoxide. It reacts with chlorine at fairly low temperatures (180 °C) forming vanadium tetrachloride and with carbon and nitrogen at high temperatures forming VC and VN, respectively. The pure metal in massive form is relatively inert toward oxygen, nitrogen, and hydrogen at room temperature (HSDB 2009). Vanadium pentoxide is an industrially important vanadium compound (Lide 2008). Table 4-2 lists important physical and chemical properties of vanadium and vanadium compounds.

Table 4-1 Chemical Identity of Vanadium and Compounds^a^

Characteristic | Vanadium | Vanadium pentoxide | Vanadyl sulfate
Synonym(s) | Vanadium, elemental | Vanadium oxide; vanadium(V) oxide; vanadic anhydride; divanadium pentoxide | Vanadic sulfate; vanadium oxide sulfate
Registered trade name(s)
Chemical formula | V | V_2_O_5_ | VOSO_4_
Identification numbers:
CAS registry | 7440-62-2 | 1314-62-1 | 27774-13-6
EINECS | 231-171-1 | 215-239-8 | 248-652-7
RTECS^b^ | YW1355000 | YW2450000 | YW1925000
EPA hazardous waste | No data | P120 | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | UN2862 | UN2931
HSDB | 1022 | 1024 | 1026
NCI | No data | No data | No data
Characteristic | Sodium metavanadate | Sodium orthovanadate | Ammonium metavanadate
Synonym(s) | Sodium vanadate(V); vanadic acid, monosodium | Sodium o-vanadate; sodium pervanadate; sodium vanadium oxide; vanadic(II) acid, trisodium salt | Ammonium vanadate(V); ammonium monovanadate; ammonium vanadium oxide; ammonium vanadium trioxide; vanadic acid, ammonium salt
Registered trade name(s)
Chemical formula | NaVO_3_ | Na_3_VO_4_ | NH_4_VO_3_
Identification numbers:
CAS registry | 13718-26-8 | 13721-39-6 | 7803-55-6
EINECS | 237-272-7 | 237-287-9 | 232-261-3
RTECS^b^ | YW1050000 | YW1120000 | YW0875000
EPA hazardous waste | No data | No data | P119
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | UN2859
HSDB | No data | No data | 6310
NCI | No data | No data | No data

a All information obtained from ChemIDPlus 2009 and HSDB 2009, except where noted.

b RTECS 2009

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Vanadium and Compounds^a^

Property | Vanadium | Vanadium pentoxide | Vanadyl sulfate dihydrate
Molecular weight | 50.9415 | 181.88 | 199.035^c^
Color | Light gray or white lustrous powder, fused hard lumps or body-centered cubic crystals. Pure vanadium is bright white, soft and ductile. | Yellow to rust-brown orthorhombic crystals. Yellow-orange powder or dark-gray flakes dispersed in air. Yellow to red crystalline powder. | Blue crystalline powder^c^
Physical state | Solid^b^ | Solid^b^ | Solid
Melting point | 1,910 °C | 690 °C
Boiling point | 3,407 °C | 1,750 °C (decomposes)
Density at 18.7 °C | 6.11 | 3.357 | No data
Odor | No data | Odorless | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | Insoluble | 1 g dissolves in approximately 125 mL water | Soluble in water^c^
Other solvents | Soluble in nitric, hydrofluoric, and concentrated sulfuric acids; attacked by alkali, forming water soluble vanadates | Soluble in concentrated acids, alkalies; insoluble in alcohol | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | 2.34×10^−2^ mm Hg at 1,916 °C (extrapolated) | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data
Property | Sodium metavanadate | Sodium orthovanadate | Ammonium metavanadate
Molecular weight | 121.830^c^ | 183.909^c^ | 116.98
Color | Colorless, monoclinic, prismatic crystals or pale-green crystalline powder^b^ | Colorless, hexagonal prisms^b^ | White or slightly yellow, crystalline powder
Physical state | Solid | Solid | Solid
Melting point | 630°C^b^ | 850–866 °C^b^ | 200 °C
Boiling point | No data | No data | No data
Density | No data | No data | 2.326 g/cm^3^
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 21 g/100 g water at 25 °C^c^ | Soluble in water^c^ | Slightly soluble in cold water
Other Solvents | No data | Insoluble in ethanol^c^ | Insoluble in alcohol, ether, ammonium chloride
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | No data | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | Noncombustible^b^ | No data | Nonflammable^b^
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

a All information obtained from HSDB 2009, except where noted.

b Lewis 2007

c Lide 2008

d Vanadyl sulfate pentahydrate - Ethereal blue solid; readily soluble in water