# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99-499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences (proposed), expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences (proposed), Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-62, Atlanta, Georgia 30333.

## Vanadium compounds Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vanadium compounds
CAS Numbers: | 7440-62-2
Date: | July 2012
Profile Status: | Post-Public Comment, Third Draft
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 4
Species: | Rat

[underlined: Minimal Risk Level]: 0.0008 [ ] mg/kg/day [X] mg vanadium/m^3^

[underlined: Reference]: NTP. 2002. NTP toxicology and carcinogenesis studies of vanadium pentoxide (CAS No. 1314-62-1) in F344/N rats and B6C3F1 mice (inhalation). Natl Toxicol Program Tech Rep Ser (507):1–343.

[underlined: Experimental design]: Groups of 40–60 female F344 rats were exposed to 0, 1, 2, or 4 mg vanadium pentoxide/m^3^ (0, 0.56, 1.1, and 2.2 mg vanadium/m^3^) 6 hours/day, 5 days/week for 16 days. On days 6 and 13, 10 rats/group were killed and a histopathological examination of the lungs was conducted. Four animals per group were killed for examination of onset and extent of lung lesions on days 1, 2, 5, 10, and 16. The remaining animals were used to measure blood and lung concentrations of vanadium, lung clearance half-times, and cell proliferation rates.

[underlined: Effect noted in study and corresponding doses]: Hyperplasia of alveolar epithelium and bronchiole epithelium were observed in 100% of the female rats exposed to 1.1 or 2.2 mg vanadium/m^3^ for 6 or 13 days. Significant increases in the incidence of histiocytic infiltrate and inflammation were observed in rats exposed to 1.1 or 2.2 mg vanadium/m^3^ for 6 or 13 days and in rats exposed to 0.56 mg vanadium/m^3^ for 13 days. A significant increase in fibrosis was observed in rats exposed to 2.2 mg vanadium/m^3^ for 13 days. No histopathological alterations were observed in the four female rats killed after 1 day of exposure; by day 2, inflammation and histiocytic infiltrates (increased number of alveolar macrophages) were observed in the rats exposed to 2.2 mg vanadium/m^3^. Hyperplasia of the alveolar and bronchiolar epidthelium was first observed on day 5 in rats exposed to 1.1 or 2.2 mg vanadium/m^3^.

[underlined: Dose and end point used for MRL derivation]: Increase in the incidence of lung inflammation in rats exposed to 0.56 mg vanadium/m^3^ as vanadium pentoxide for 13 days; the human equivalent concentration of this LOAEL (LOAEL_HEC_) is 0.073 mg vanadium/m^3^.

[ ] NOAEL [X] LOAEL

A BMD analysis was considered for determining the point of departure for the inflammation in female rats exposed to vanadium pentoxide for 13 days. All available dichotomous models in the EPA benchmark dose software ([BMDS] version 2.1) were fit to the incidence data for lung inflammation (0/10, 8/10, 10/10, and 10/10 in rats exposed to 0, 0.56, 1.1, or 2.2 mg vanadium/m^3^) using the extra risk option. The multistage model was run for all polynomial degrees up to n-1 (where n is the number of dose groups including control). Adequate model fit is judged by three criteria: goodness-of-fit p-value (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). Among all the models providing adequate fit to the data, the lowest lower bound on the BMC (BMCL) is selected as the point of departure when the difference between the BMDLs estimated from these models are more than three-fold; otherwise, the BMCL from the model with the lowest AIC is chosen. In accordance with U.S. EPA (2000) guidance, benchmark concentrations (BMCs) and BMCLs associated with an extra risk of 10% are calculated for all models.

Table A-1 Model Predictions for the Incidence of Inflammation in Female Rats Exposed to Vanadium Pentoxide 6 Hours/Day, 5 Days/Week for 13 Days

Model | χ^2^ Goodness of fit p-value^a^ | AIC | BMC_10_(mg V/m^3^) | BMCL_10_(mg V/m^3^)
Gamma ^b^ | 1.00 | 12.01 | 0.33 | 0.02
Logistic | 1.00 | 14.01 | 0.46 | 0.10
LogLogistic | 1.00 | 12.01 | 0.46 | 0.01
LogProbit | 1.00 | 14.01 | 0.42 | 0.03
Multistage^c^ | 0.93 | 12.69 | 0.03 | 0.02
Probit | 1.00 | 14.01 | 0.38 | 0.09
Weibull^b^ | 1.00 | 14.01 | 0.25 | 0.02
Quantal-linear | 0.93 | 12.69 | 0.03 | 0.02

a Values <0.10 fail to meet conventional goodness-of-fit criteria

b Power restricted to ≥1

c Betas restricted to ≥0; 1-degree polynomial

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC

Source: NTP 2002

Figure A-1 Fit of Gamma Model to Data on the Incidence of Inflammation in Female Rats Exposed to Vanadium Pentoxide for 13 Days

BMCs and BMCLs indicated are associated with an extra risk of 10%, and are in units of mg vanadium/m^3^

Source: NTP 2002

Although the data provide an adequate statistical fit, the estimated BMCL_10_ of 0.02 mg vanadium/m^3^ appears to be an overly conservative estimate of a no-adverse-effect level, which may be a reflection of the limited amount of information from the study on the shape of the exposure-response relationship (incidences of lung inflammation were 0/10 in controls and 8/10 at the lowest vanadium concentration). In a chronic-duration study conducted by NTP (2002), no significant alterations in the incidence of lung inflammation were observed in male and female rats exposed to 0.28 mg vanadium/m^3^; the LOAEL for lung inflammation was 0.56 mg vanadium/m^3^ in males and 1.1 mg vanadium/m^3^ in females.

Due to the low confidence in the BMCL_10_, a NOAEL/LOAEL approach was used to determine the point of departure for the acute MRL.

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 3 for extrapol

0.ation from animals to humans with dosimetric adjustment

- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]:

The duration-adjusted LOAEL of 0.1 mg vanadium/m^3^ was converted to a human equivalent concentration (LOAEL_HEC_) using the following equation:

- LOAEL_HEC_ = LOAEL_ADJ_ × RDDR_TH_
- LOAEL_HEC_ = 0.1 mg vanadium/m^3^ × 0.732
- LOAEL_HEC_ = 0.073 mg vanadium/m^3^

where:

The RDDR is a multiplicative factor used to adjust an observed inhalation particulate exposure concentration of an animal to the predicted inhalation particulate exposure concentration for a human. The RDDR program (EPA 1990) was used to calculate a multiplier of 0.732 for the thoracic region was determined using a default body weight of 0.124 kg (EPA 1994c) and a particle size MMAD of 1.2 μm with a geometric standard deviation of 1.9

[underlined: Was a conversion used from intermittent to continuous exposure]? The LOAEL was adjusted for intermittent exposure as follows:

- LOAEL_ADJ_ = LOAEL × 6 hours/day × 5 days/week
- LOAEL_ADJ_ = 0.56 mg vanadium/m^3^ × 6 hours/24 hours × 5 days/7 days
- LOAEL_ADJ_ = 0.1 mg vanadium/m^3^

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Data on acute toxicity of vanadium in humans are limited to an experimental study in which a small number of subjects were exposed to vanadium pentoxide dust for 8 hours (Zenz and Berg 1967). A persistent cough lasting for 8 days developed in two subjects exposed to 0.6 mg vanadium/m^3^; at 0.1 mg vanadium/m^3^, a productive cough without any subjective complaints or impact on work or home activities were observed in 5 subjects. The available studies in laboratory animals focused on potential respiratory tract effects. Impaired lung function characterized as airway obstructive changes (increased resistance and decreased airflow) were observed in monkeys exposed to 2.5 or 1.7 mg vanadium/m^3^ as vanadium pentoxide for 6 hours (Knecht et al. 1985, 1992); the highest NOAEL for this effect was 0.34 mg vanadium/m^3^. Alveolar and bronchiolar epithelial hyperplasia and inflammation were observed in the lungs of mice exposed to 1.1 mg vanadium/m^3^ 6 hours/day, 5 days/week for 13 days (NTP 2002). Although the Knecht et al. (1985, 1992) or NTP (2002) studies did not include examination of potential end points outside of the respiratory tract, longer-duration studies have identified the respiratory tract as the most sensitive target of toxicity (NTP 2002).

[underlined: Agency Contacts (Chemical Managers)]: Jessilynn Taylor, Sam Keith, Larry Cseh

## Vanadium compounds Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vanadium compounds
CAS Numbers: | 7440-62-2
Date: | July 2012
Profile Status: | Post-Public Comment, Third Draft
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 19
Species: | Rat

[underlined: Minimal Risk Level]: 0.0001 [ ] mg/kg/day [X] mg vanadium/m^3^

[underlined: Reference]: NTP. 2002. NTP toxicology and carcinogenesis studies of vanadium pentoxide (CAS No. 1314-62-1) in F344/N rats and B6C3F1 mice (inhalation). Natl Toxicol Program Tech Rep Ser (507):1–343.

[underlined: Experimental design]: Groups of 50 male and 50 female F344 rats were exposed to 0, 0.5, 1, or 2 mg vanadium pentoxide/m^3^ (0, 0.28, 0.56, and 1.1 mg vanadium/m^3^) 6 hours/day, 5 days/week for 104 weeks. The following parameters were used to assess toxicity: clinical observations, body weights (every 4 weeks from week 5 to 89 and every 2 weeks from week 92 to 104), complete necropsy, and microscopic examination of major tissues and organs.

[underlined: Effect noted in study and corresponding doses]: No significant alterations in survival or body weight gain were observed in the vanadium-exposed rats. A summary of selected non-neoplastic respiratory tract lesions is presented in Table A-2. Alveolar histiocytic infiltrates were observed in males and females exposed to ≥0.28 mg vanadium/m^3^. Significant increases in the incidence of hyperplasia of the alveolar and bronchiolar epithelium were observed in males exposed to ≥0.28 mg vanadium/m^3^ and females exposed to ≥0.56 mg vanadium/m^3^. Squamous metaplasia was observed in alveolar epithelium of males and females exposed to 1.1 mg vanadium/m^3^ and in the bronchiolar epithelium of males exposed to 1.1 mg vanadium/m^3^. Chronic inflammation was observed in males exposed to 0.56 or 1.1 mg vanadium/m^3^ and females exposed to 1.1 mg vanadium/m^3^ and interstitial fibrosis was observed in males exposed to 1.1 mg vanadium/m^3^ and females exposed to 0.28 or 1.1 mg vanadium/m^3^. An increased incidence of brownish pigment in alveolar macrophages was observed in males exposed to 1.1 mg vanadium/m^3^ and females exposed to 0.56 or 1.1 mg vanadium/m^3^; this effect was considered to be of little biological relevance. Chronic inflammation, degeneration, and hyperplasia of the epiglottis were observed in the larynx of males and females exposed to ≥0.28 mg vanadium/m^3^; squamous metaplasia of the epiglottis respiratory epithelium was also observed in males exposed to ≥0.28 mg vanadium/m^3^ and in females exposed to 1.1 mg vanadium/m^3^. Goblet cell hyperplasia of the nasal respiratory epithelium was observed in males exposed to ≥0.28 mg vanadium/m^3^ and in females exposed to 1.1 mg vanadium/m^3^. A positive trend for increased incidences of uterine stromal polyp was observed; NTP did not consider it to be related to vanadium pentoxide exposure. An increased incidence of nephropathy was observed in male rats exposed to 0.56 or 1.1 mg vanadium/m^3^; NTP considered the finding to be of marginal biological significance because there was a lack of increase in severity, as compared to controls, and significant findings in female rats. No significant increases in the incidence of lung neoplasms were observed; however, the incidence of alveolar/bronchiolar adenoma in males exposed to 0.28 mg vanadium/m^3^ and alveolar/bronchiolar carcinoma or combined incidence of adenoma and carcinoma in males exposed to 0.28 or 1.1 mg vanadium/m^3^ were higher than historical controls. These increases in lung tumors were considered to be related to vanadium pentoxide exposure.

Table A-2 Selected Respiratory Tract Effects Observed in Rats Exposed to Vanadium Pentoxide 6 Hours/Day, 5 Days/Week for 2 Years

Air concentration (mg vanadium/m^3^) | 0 | 0.28 | 0.56 | 1.1
Males
Lungs
Alveolar hyperplasia | 7/50 (2.3) | 24/49^b^ (2.0) | 34/48^b^ (2.0) | 49/50^b^ (3.3)
Bronchiole hyperplasia | 3/50 (2.3) | 17/49^b^ (2.2) | 31/48^b^ (1.8) | 49/50^b^ (3.3)
Inflammation | 5/50 (1.6) | 8/49 (1.8) | 24/48^b^ (1.3) | 42/50^b^ (2.4)
Fibrosis | 7/50 (1.4) | 7/49 (2.0) | 16/48^c^ (1.6) | 38/50^b^ (2.1)
Histiocyte infiltration | 22/50 (1.3) | 40/49^b^ (2.0) | 45/48^b^ (2.3) | 50/50^b^ (3.3)
Larynx
Chronic inflammation | 3/49 (1.0) | 20/50^b^ (1.1) | 17/50^b^ (1.5) | 28/49^b^ (1.6)
Degeneration of epiglottis respiratory | 0/49 | 22/50^b^ (1.1) | 23/50^b^ (1.1) | 33/50^b^ (1.5)
epithelium
Hyperplasia of epiglottis respiratory | 0/49 | 22/50^b^ (1.1) | 23/50^b^ (1.1) | 33/49^b^ (1.5)
epithelium
Squamous metaplasia of epiglottis | 0/49 | 18/50^b^ (1.5) | 34/50^b^ (1.5) | 32/49^b^ (1.9)
respiratory epithelium
Nose
Hyperplasia of respiratory epithelium | 4/49 (1.8) | 15/50^b^ (1.8) | 12/49^c^ (2.0) | 17/48^b^ (2.1)
goblet cell
Female
Lung
Alveolar hyperplasia | 4/49 (1.0) | 8/49 (1.8) | 21/50^b^ (1.2) | 50/50^b^ (3.1)
Bronchiole hyperplasia | 6/49 (1.5) | 5/49 (1.6) | 14/50^c^ (1.3) | 48/50^b^ (3.0)
Inflammation | 10/49 (1.5) | 10/49 (1.1) | 14/50 (1.2) | 40/50^c^ (1.7)
Fibrosis | 19/49 (1.4) | 7/49 (1.3) | 12/50 (1.6) | 32/50^b^ (1.4)
Histiocyte infiltration | 26/49 (1.4) | 35/49^c^ (1.3) | 44/50^b^ (2.0) | 50/50^b^ (1.9)
Larynx
Chronic inflammation | 8/50 (1.8) | 26/49^b^ (1.5) | 27/49^b^ (1.3) | 37/50^b^ (1.4)
Degeneration of epiglottis respiratory | 2/50 (1.0) | 33/49^b^ (1.2) | 26/49^b^ (1.2) | 40/50^b^ (1.5)
epithelium
Hyperplasia of epiglottis respiratory | 0/50 | 25/49^b^ (1.4) | 26/49^b^ (1.3) | 33/50^b^ (1.5)
epithelium
Squamous metaplasia of epiglottis | 2/50 (2.0) | 7/49 (1.9) | 7/40 (1/7) | 16/50^b^ (1.4)
respiratory epithelium
Nose
Hyperplasia of respiratory epithelium | 13/50 (2.0) | 18/50 (2.0) | 16/50 (1.9) | 30/50^b^ (2.0)
goblet cell

a Average severity grade of lesions in affected animals: 1=minimal; 2=mild, 3=moderate; 4=marked

b p≤0.01

c p≤0.05

Source: NTP 2002

[underlined: Dose and end point used for MRL derivation]: The human equivalent concentration of the BMCL_10_ for degeneration of respiratory epithelium of the epiglottis, 0.003 mg vanadium/m^3^, was used as the point of departure for the chronic-duration inhalation MRL.

[ ] NOAEL [ ] LOAEL [X] BMCL_10_

BMD analysis was used to determine the point of departure for select respiratory tract lesions in rats exposed to vanadium pentoxide for 2 years. A number of lesions were observed in male and female rats exposed to 0.28 mg vanadium/m^3^ including hyperplasia of the alveolar and bronchiolar epithelium, chronic inflammation of the larynx, degeneration of the epiglottis, and hyperplasia of respiratory epithelial goblet cells. The incidence of these lesions in male rats were modeled using all available dichotomous models in the EPA BMDS (version 2.1) that were fit to the incidence data for alveolar hyperplasia, bronchial hyperplasia, using the extra risk option. The multistage model was run for all polynomial degrees up to n-1 (where n is the number of dose groups including control). Adequate model fit is judged by three criteria: goodness-of-fit p-value (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all the models providing adequate fit to the data, the lowest BMCL is selected as the point of departure when the difference between the BMCLs estimated from these models are more three-fold; otherwise, the BMCL from the model with the lowest AIC is chosen. In accordance with U.S. EPA (2000) guidance, BMCs and BMCLs associated with an extra risk of 10% are calculated for all models.

The results of the BMD analyses are presented in Table A-3 and Figures A-2 through A-6.

Table A-3 Model Predictions for Respiratory Effects in Rats Exposed to Vanadium Pentoxide for 2 Years

Model | χ^2^ Goodness of fit p-value^a^ | AIC | BMC_10_ (mg V/m^3^) | BMCL_10_ (mg V/m^3^)
Alveolar hyperplasia in male rats
Gamma^b^ | 0.25 | 183.50 | 0.12 | 0.04
Logistic | 0.52 | 181.44 | 0.11 | 0.09
Log-Logistic | 0.08 | 185.40 | NA | NA
Log-Probit | 0.13 | 184.60 | 0.15 | 0.08
Multistage^c^ | 0.21 | 184.00 | 0.05 | 0.04
Probit | 0.57 | 181.29 | 0.10 | 0.09
Weibull^b^ | 0.33 | 183.11 | 0.10 | 0.05
Quantal-Linear | 0.21 | 184.00 | 0.05 | 0.04
Bronchiolar hyperplasia in male rats
Gamma^b^ | 0.28 | 165.38 | 0.17 | 0.10
Logistic | 0.60 | 163.19 | 0.15 | 0.12
Log-Logistic | 0.08 | 167.58 | NA | NA
Log-Probit | 0.12 | 166.67 | 0.19 | 0.13
Multistage^c^ | 0.56 | 164.51 | 0.13 | 0.07
Probit | 0.71 | 162.87 | 0.14 | 0.12
Weibull^b^ | 0.45 | 164.73 | 0.15 | 0.09
Quantal-linear | 0.03 | 170.74
Chronic inflammation in larynx of male rats
Gamma^b^ | 0.04 | 230.93 | NA | NA
Logistic | 0.01 | 235.47 | NA | NA
Log-Logistic | 0.11 | 229.28 | 0.10 | 0.07
Log-Probit | 0.00 | 235.73 | NA | NA
Multistage^c^ | 0.04 | 230.93 | NA | NA
Probit | 0.01 | 235.09 | NA | NA
Weibull^b^ | 0.04 | 230.93 | NA | NA
Quantal-linear | 0.04 | 230.93 | NA | NA
Degeneration of epiglottis respiratory epithelium in male rats
Gamma^b^ | 0.06 | 210.55 | NA | NA
Logistic | 0.00 | 230.64 | NA | NA
Log-Logistic | 0.47 | 206.17 | 0.06 | 0.04
Log-Probit | 0.01 | 214.79 | NA | NA
Multistage^c^ | 0.06 | 210.55 | NA | NA
Probit | 0.00 | 229.81 | NA | NA
Weibull^b^ | 0.06 | 210.55 | NA | NA
Quantal-linear | 0.06 | 210.55 | NA | NA
Hyperplasia of nasal respiratory epithelial goblet cells in male rats
Gamma^b^ | 0.12 | 213.84 | 0.32 | 0.20
Logistic | 0.07 | 215.11 | NA | NA
Log-Logistic | 0.15 | 213.35 | 0.27 | 0.16
Log-Probit | 0.03 | 216.79 | NA | NA
Multistage^c^ | 0.12 | 213.84 | 0.32 | 0.20
Probit | 0.07 | 214.97 | NA | NA
Weibull^b^ | 0.12 | 213.84 | 0.32 | 0.20
Quantal-linear | 0.12 | 213.84 | 0.32 | 0.20

a Values <0.10 fail to meet conventional goodness-of-fit criteria

b Power restricted to ≥1

c Betas restricted to ≥0; 1-degree polynomial

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the dose/concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD; NA = not applicable

Source: NTP 2002

Figure A-2 Fit of Probit Model to Data on the Incidence of Alveolar Hyperplasia in Male Rats Exposed to Vanadium Pentoxide for 2 Years

BMCs and BMCLs indicated are associated with an extra risk of 10%, and are in units of mg vanadium/m^3^

Source: NTP 2002

Figure A-3 Fit of Probit Model to Data on the Incidence of Bronchiolar Hyperplasia in Male Rats Exposed to Vanadium Pentoxide for 2 Years

BMCs and BMCLs indicated are associated with an extra risk of 10%, and are in units of mg vanadium/m^3^

Source: NTP 2002

Figure A-4 Fit of Log-logistic Model to Data on the Incidence Chronic Inflammation in Larynx of Male Rats Exposed to Vanadium Pentoxide for 2 Years

BMCs and BMCLs indicated are associated with an extra risk of 10%, and are in units of mg vanadium/m^3^

Source: NTP 2002

Figure A-5 Fit of Log-logistic Model to Data on the Incidence of Degeneration of Epiglottis Respiratory Epithelium in Male Rats Exposed to Vanadium Pentoxide for 2 Years

BMCs and BMCLs indicated are associated with an extra risk of 10%, and are in units of mg vanadium/m^3^

Source: NTP 2002

Figure A-6 Fit of Log-logistic Model to Data on the Incidence of Hyperplasia of Nasal Respiratory Epithelial Goblet Cells in Male Rats Exposed to Vanadium Pentoxide for 2 Years

BMCs and BMCLs indicated are associated with an extra risk of 10%, and are in units of mg vanadium/m^3^

Source: NTP 2002

In summary, the lowest BMCL_10_ values for alveolar epithelial hyperplasia, bronchiolar epithelial hyperplasia, laryngeal chronic inflammation, degeneration of epiglottis epithelium, and hyperplasia of nasal goblet cells were 0.09, 0.10, 0.07, 0.04, 0.16 mg vanadium/m^3^, respectively.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustments
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]:

Human equivalent concentrations were calculated for each BMCL_10_ using the following equation:

BMCL_HEC_ = BMCL_ADJ_ × RDDR

where:

The RDDR is a multiplicative factor used to adjust an observed inhalation particulate exposure concentration of an animal to the predicted inhalation particulate exposure concentration for a human. The RDDR program (EPA 1994c) was used to calculate a multiplier for the different regions of the respiratory tract was determined using a default body weight of 0.380 kg (EPA 1994c) and a particle size MMAD of 1.2 μm with a geometric standard deviation of 1.9. The BMDL_HEC_ values are presented in Table A-4

Table A-4 Summary of Human Equivalent Concentrations of BMCL Values for Rats Exposed to Vanadium Pentoxide for 2 Years

Effect | BMCL_10_ (mg vanadium/m^3^) | BMCL_ADJ_^a^ (mg vanadium/m^3^) | RDDR | BMCL_HEC_ (mg vanadium/m^3^)
Alveolar epithelial hyperplasia | 0.09 | 0.016 | 0.502^b^ | 0.008
Bronchiolar epithelial hyperplasia | 0.10 | 0.018 | 0.971^c^ | 0.017
Laryngeal chronic inflammation | 0.07 | 0.012 | 0.423^d^ | 0.005
Degeneration of epiglottis epithelium | 0.04 | 0.0071 | 0.423^d^ | 0.003
Hyperplasia of nasal goblet cells | 0.16 | 0.029 | 0.423^d^ | 0.012

a BMCLADJ= BMCL10 × 6 hours/24 hours × 5 days/7 days

b Pulmonary region

c Thoracic region

d Extrathoracic region

BMCL = benchmark concentration, lower confidence limit RDDR = regional deposited dose ratio

Source: NTP 2002

[underlined: Was a conversion used from intermittent to continuous exposure]? The BMCL_10_ was adjusted for intermittent exposure, as noted in Table A-4.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: An increased combined incidence of alveolar/bronchiolar adenoma or carcinoma was observed in male rats (NTP 2002). Although the incidence was not significantly higher than concurrent controls, it was higher than historical controls and NTP considered it to be a vanadium-related effect.

In mice exposed to ≥0.56 mg vanadium/m^3^ for 6 hours/day, 5 days/week for 2 years, significant increases in the incidence of alveolar and bronchiolar hyperplasia, chronic lung inflammation, squamous metaplasia of the respiratory epithelium of the epiglottis, goblet cell hyperplasia in the nasal respiratory epithelium and nasal olfactory epithelial atrophy, and hyaline degeneration were observed (NTP 2002). In addition to these effects, a significant increase in alveolar/bronchiolar carcinoma incidence was also observed in mice exposed to ≥0.56 mg vanadium/m^3^.

[underlined: Agency Contacts (Chemical Managers)]: Jessilynn Taylor, Sam Keith, Larry Cseh

## Vanadium compounds Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Vanadium compounds
CAS Numbers: | 7440-62-6
Date: | July 2022
Profile Status: | Post-Public Comment, Third Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 12
Species: | Human

[underlined: Minimal Risk Level]: 0.01 [X] mg vanadium/kg/day [ ] mg vanadium/m^3^

[underlined: Reference]: Fawcett JP, Farquhar SJ, Thou T, et al. 1997. Oral vanadyl sulphate does not affect blood cells, viscosity or biochemistry in humans. Pharmacol Toxicol 80:202–206.

[underlined: Experimental design]: Groups of men and women enrolled in a weight training program for at least 1 year were administered capsules containing 0 (11 men and 4 women) or 0.5 mg/kg/day vanadyl sulfate trihydrate (0.12 mg vanadium/kg/day) (12 men and 4 women) for 12 weeks. Fasting blood samples were collected at 0 and 12 weeks and analyzed for hematological (erthyroctye count, hemoglobin, hematocrit, mean cell volume, mean cell hemoglobin, platelet count, and total and differential leukocyte count) and serum chemistry (cholesterol, high density lipoprotein, triglycerides, albumin, total protein, total and direct bilirubin, alkaline phosphatase, ALT) parameters. Body weight and blood pressure were measured at weeks 4, 8, and 12.

[underlined: Effect noted in study and corresponding doses]: No significant alterations in blood pressure, body weight, or hematological or clinical chemistry parameters were found.

[underlined: Dose and end point used for MRL derivation]: NOAEL of 0.12 mg vanadium/kg/day for hematological alterations and blood pressure.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Dimond et al. (1963) also examined healthy adults (one male and five females) administered an average daily dose of 0.19 mg vanadium/kg/day as ammonium vanadyl tartrate for 45–68 days and found no significant alterations in hematological or serum clinical chemistry parameters. Several studies have reported gastrointestinal effects in noninsulin-dependent diabetics that persisted for >2 weeks (Afkhami-Ardekani et al. 2008; Goldfine et al. 2000). The signs of gastrointestinal irritation were likely due to local irritation rather than a systemic effect and were observed at 31.3 mg vanadium (administered 3 times/day); no effects were observed at 7.8 mg vanadium (Goldfine et al. 2000).

Studies in laboratory animals have identified several sensitive effects including alterations in erythrocyte and reticulocyte levels, increased blood pressure, neurobehavioral alterations, and developmental toxicity. Significant increases in blood pressure have been observed in rats exposed to 0.12 mg vanadium/kg/day for 210 days (Boscolo et al. 1994); increases in blood pressure have been observed at higher doses in several other studies by these investigators (Carmagnani et al. 1991, 1992). In general, other studies have not found increases in blood pressure in rats exposed to doses as high as 31 mg vanadium/kg/day (Bursztyn and Mekler 1993; Sušić and Kentera 1986, 1988). Decreases in erythrocyte levels have been observed in rats exposed to 1.18 mg vanadium/kg/day as ammonium metavanadate in drinking water for 4 weeks (Zaporowska et al. 1993); at higher concentrations, decreases in hemoglobin and increases in reticulocyte levels have been observed (Ścibior 2005; Ścibior et al. 2006; Zaporowska and Wasilewski 1990, 1991, 1992a, 1992b; Zaporowska et al. 1993). Decreases in pup body weight and length have been observed in the offspring of rats administered 2.1 mg vanadium/kg/day as sodium metavanadate for 14 days prior to mating and throughout gestation and lactation (Domingo et al. 1986). At higher doses (6, 10, or 12 mg vanadium/kg/day), decreases in pup survival, and increases in the occurrence of gross, visceral, or skeletal malformations and anomalies were observed (Elfant and Keen 1987; Morgan and El-Tawil 2003; Poggioli et al. 2001).

[underlined: Agency Contacts (Chemical Managers)]: Jessilynn Taylor, Sam Keith, Larry Cseh