# 8 REFERENCES

*Cited in text

*Abdelnasser M, Hyland M, Jespersen ND. 1986. Synthesis of mutagenic compounds in crankcase oils. Environmental Science and Technology 20(2):145–149.22288801
*Adler N, Sertic-Bionda K, Rak N. 1990. Influence of weathering on oil spill identification. Int J Environ Anal Chem 39(4):381–390.
*ABC. 1974. Disposal of oil wastes by microbial assimilation. Washington, DC: U.S. Atomic Energy Commission. NTIS Report No. Y-1934.
Agarwal R, Kumar S, Mehrotra NK. 1986. Polyaromatic hydrocarbon profile of a mineral oil (JBO-P) by gas chromatography. J Chromatogr Sci 24(7):289–292.3745399
Al-Yakoob SN, Saeed T, Al-Hashash H. 1994. Polycyclic aromatic hydrocarbons in fish: Exposure assessment for Kuwaiti consumers after the Gulf oil spill of 1991. Environment International 20(2):221–227.
Anderson JW, Neff JM, Cox BA, . 1974. Characteristics of dispersions and water-soluble extracts of crude and refined oils and their toxicity to estuarine crustaceans and fish. Marine Biology 27:75–88.
Angerer J, Heinzow B, Reimann DO, . 1992. Internal exposure to organic substances in a municipal waste incinerator. Int Arch Occup Environ Health 64:265–273.1468796
AOAC. 1980. Official methods of analysis. 13th ed. Association of Official Analytical Chemists. Washington, DC. 25.068–25.073.
APHA. 1985. Standard methods for the examination of water and wastewater. 16th ed. Washington, DC: American Public Health Association.
*API. 1974. Waste oil roundup No. 3. Committee on Disposal of Waste Products. American Petroleum Institute, Division of Marketing, Washington, DC. Publication No. 1587.
*API. 1975. Energy from used lubricating oils. American Petroleum Institute. Washington, DC. Publication No. 1588.
*API. 1979. In vitro and in vivo mutagenicity studies: New oil composite. American Petroleum Institute. Washington, DC. Publication No. 27-00325.
*API. 1980a. Acute toxicity tests: API 78-1 new composite motor oil. American Petroleum Institute. Washington, DC. Publication No. 27-32131.
*API. 1980b. Acute toxicity tests: API 79-7 used composite motor oil. American Petroleum Institute. Washington, DC. Publication No. 27-32772.
*API. 1983. The carcinogenicity of new and used lubricants. American Petroleum Institute. Washington, DC. Publication No. 30-32847.
API. 1988. Motor oil guide. American Petroleum Institute. Washington, DC. Publication No. 805 15510.
Apitz SE, Borbridge LM, Bracchi K, . 1993. Fluorescent response of fuels in soils: Insights into fuel-soil interactions. Government Reports Announcements & Index Issue 15, 1993. NTIS/AD-A262 837/8.
*Apostoli P, Crippa M, Fracasso ME, . 1993. Increases in polycyclic aromatic hydrocarbon content and mutagenicity in a cutting fluid as a consequence of its use. Int Arch Occup Environ Health 64(7):473–7.8482586
Atlas RM. 1981. Microbial degradation of petroleum hydrocarbons: An environmental perspective. Microbial Rev 45:180–209.
*ATSDR. 1988. Health assessment for York Oil Company, Moira, New York, Region 2. Atlanta, GA: Agency for Toxic Substances and Disease Registry. Report No. PB90-140013:14.
*ATSDR. 1989a. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 1989b. Toxicological profile for zinc. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1990a. Health assessment for Double Eagle Refinery, Oklahoma City, Oklahoma. Atlanta, GA: Agency for Toxic Substances and Disease Registry. Govt Reports Announcements & Index 19. NTIS No. PB90-244039.
*ATSDR. 1990b. Toxicological profile for copper. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1990c. Toxicological profile for polycyclic aromatic hydrocarbons. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992a. Toxicological profile for aluminum. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992b. Toxicological profile for barium. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992c. Toxicological profile for boron. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992d. Toxicological profile for cadmium. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992e. Toxicological profile for manganese. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992f. Toxicological profile for nickel. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992g. Toxicological profile for tin. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1993a. Toxicological profile for chromium. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1993b. Toxicological profile for lead. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
Azpiazu MN, Bustamante C, Morquillas JM. 1990. Effect of air preheating on automotive emissions. Water Air Soil Pollut 51:231–237.
Babich H, Stotzky G. 1985. Heavy metal toxicity to microbe-mediated ecologic processes: A review and potential application to regulatory policies. Environ Res 36:111–137.3917912
*Back SO, Field, RA, Goldstone ME. 1991. A review of atmospheric polycyclic aromatic hydrocarbons: sources, fate and behavior. Water, Air, and Soil Pollution, 60:279–300.
*Baines TM. 1981. Nitrosamines and other hazardous emissions from engine crankcases. Government Reports Announcements & Index (GRA&I), Issue 06, 1982. NTIS/PB82-127960.
Baldwin RW, Cunningham GJ, Pratt D. 1964. Carcinogenic action of motor engine oil additives. Br J Cancer 18 (3):503–507.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Beck LS, Hepler DI, Hansen KL. 1984. The acute toxicology of selected petroleum hydrocarbons. In: MacFarland HN et al., eds. Advances in modem environmental toxicology. Volume 16: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 1–16.
*Bemgard A, Colmsjo A. 1992. Photoionization-flame ionization response ratios in capillary gas chromatography for polycyclic aromatic compounds. J Chromatogr Sci 30 (1):23–28.
Bergel F. 1974. Carcinogenic hazards in natural and man-made environments. Proc R Soc Lond 185:165–181.4149921
*Bingham E. 1988. Carcinogenicity of mineral oils. Ann N Y Acad Sci 534:452–458.3291714
Bingham E, Falk HL. 1969. Environmental carcinogens: The modifying effect of cocarcinogens on the threshold response. Arch Environ Health 19:779–783.4187174
Bingham E, Niemeier RW, Reid JB. 1976. Multiple factors in carcinogenesis. Ann N Y Acad Sci 271:14–21.1069496
Bingham E, Horton AW, Tye R. 1965. The carcinogenic potency of certain oils. Arch Environ Health 10:449–451.14247342
Binstock DA, Grohse PM, Swift PL, . 1990. Evaluation of microwave techniques to prepare solid and hazardous waste for elemental analysis. American Society for Testing and Materials Spec Tech Publication No. 1062. Waste Testing and Quality Assurance 2:312–320.
*Blackbum GR, Deitch RA, Roy TA, . 1983. Mutagenesis of used gasoline engine oil fractions. 7th Polynuclear Aromatic Hydrocarbons International Symposium, 113–122.
*Blakley BR, Brockman RP. 1976. Lead toxicosis in cattle in Saskatchewan. Can Vet J 17(1):16–18.1260635
*Bond JA, Wolff RK, Harkema JR, . 1988. Distribution of DNA adducts in the respiratory tract of rats exposed to diesel exhaust. Toxicol Appl Pharmacol 96:336–346.2461604
*Booth III GT, Odojewski SS, Rakocynski RW, . 1983. Used lubricating oil re-refining demonstration plant data acquisition. Topical Report I: Environmental considerations. U.S. Department of Energy, Washington, D.C. DOE/BC110562-5 (DE83006026).
*Borowsky B, Aitken-Ander P, Tanacredi JT. 1993. The effects of low doses of waste crankcase oil on Melita nitida Smith (Crustucea Amphipoda). Journal of Experimental Marine Biological Ecology 166:39–46.
Borowsky B, Aitken-Ander P, Tanacredi JT, . 1992. Low doses of waste crankcase oil induced morphological changes in the amphipod crustacean Melita-nitida. In: Annual meeting of the American Society of Zoologists with the Animal Behavior Society, The International Association of Astacology, Vancouver, British Columbia, December 26-30, 1992. Am Zool 32(5):71A.
Boutwell RK, Bosch DK. 1959. The tumor-promoting action of phenol and related compounds for mouse skin. Cancer Res 19:413–424.13652126
Brain JD. 1992. Short-term in vitro and in vivo bioassays: Their role in estimating the toxic potential of inhaled complex mixtures for humans. Cell Biol Toxicol 8(3):123–132.1446250
*Briden FE. 1984. X-Ray diffraction phase analysis of process and pollution control device samples. Government Reports Announcements & Index (GRA&I), Issue 11, 1984. NTIS/PB84-168632.
Brinckman FE, Blair WR. 1979. Speciation of metals in used oils: Recent progress and environmental implications of molecular lead compounds in used crankcase oils. In: National Bureau of Standards Special Publication 556. Proceedings of a Workshop on Measurements and Standards for Recycled Oil - II. National Bureau of Standards, Gaithersburg, MD, November 29–30, 1977, 25–38.
*Brinkman DW, Gottlieb M, Koelbel K. 1982. Used motor oil poses environmental problem. Oil & Gas Journal 80 (32):163–165.
*Britvic S, Lucic D, Kurelec B. 1993. Bile fluorescence and some early biological effects in fish as indicators of pollution by xenobiotics. Environmental Toxicology and Chemistry 12:765–773
*Brown RC, Pierce RH, Rice SA. 1985. Hydrocarbon contamination in sediments from urban stormwater runoff. Marine Pollution Bulletin 16(6):236–240.
Brummage KG. 1975. The source of oil entering the sea: Background papers for a workshop on inputs, fates and effects of petroleum in the marine environments. Washington, DC: National Academy of Science, 1–6.
*Buchanan MV, Wise MB, Guerin MR. 1990. Direct sampling ion trap mass spectrometry for the rapid determination of volatile organics in environmental matrices. Government Reports Announcements & Index 2. NTIS/DE-89015358.
Buck WB. 1970. Lead and organic pesticide poisonings in cattle. J Am Vet Med Assoc 156(10):1468–1472.5463043
Cajaraville MP, Uranga JA, Angulo E. 1992. Comparative effects of the water accommodated fraction of three oils on mussels-3: Quantitative histochemistry of enzymes related to the detoxification metabolism. Comp Biochem Facial 103(2):369–377.
Campbell D, Cox D, Crum J, . 1993. Initial effects of the grounding of the tanker Braer on health in Shetland. Br Med J 307(6914):1251–1255.8281057
*Canadian Environmental Protection Act. 1994. Priority substances list assessment report: Waste crankcase oils. NTIS Order No. DSS-EN40-215/36E.
Canals A, Forteza R, Cerda V. 1992. The routine determination of PCBs in waste automotive engine oils. Chromatographia 34(1–2):35–40.
*Carmichael PL, Jacob J, Grimmer G, . 1990. Analysis of the polycyclic aromatic hydrocarbon content of petrol and diesel engine lubricating oils and determination of DNA adducts in topically treated mice by phosphorus-32-postlabelling. Carcinogenesis (London) 11(11):2025–2032.2225336
*Carmichael PL, Ni She M, Hewer A, . 1992. DNA adduct formation in mice following treatment with used engine oil and identification of some of the major adducts by ^32^P-postlabelling. Cancer Lett (Ireland) 64 (2):137–144.
*Carmichael PL, Ni She M, Phillips DH. 1991. DNA adducts in human and mouse skin maintained in short-term culture and treated with petrol and diesel engine lubricating oils. Cancer Lett 57(3):229–235.2032211
*CELDS. 1993. Computer-aided Environmental Legislative Data Systems. University of Illinois, Urbana, IL. January 19, 1993.
Chen KC, Vostal JJ. 1981. Aryl hydrocarbon hydroxylase activity induced by injected diesel particulate extract vs inhalation of diluted diesel exhaust. J Appl Toxicol 1(2):127–131.6206112
*Chen CS-H, Delfino JJ, Rao PSC. 1994. Partitioning of organic and inorganic components from motor oil into water. Chemosphere 28(7):1385–1400.
Christmann W, Rotard W, Lattner A, . 1987. Analytical procedure in the analysis of mineral oils and related matrixes for PCDD and PCDF. Chemosphere 16(8–9):1649–1653.
Ciccioli P, Brancaleoni E, Cecinato A, . 1986. Fractionation of polar polynuclear aromatic hydrocarbons present in industrial emissions and atmospheric samples and their determination by gas chromatography-mass spectrometry. J Chromatogr 351:451–464.
Clark FS, Finley JS, Gibbson GC. 1974. Acute effects of outboard motor effluent on two marine shellfish. Environmental Science and Technology 8:1009–1014.
*Clausen J, Rastogi S. 1977. Heavy metal pollution among autoworkers: I. Lead. Br J Ind Med 34(3):208–215.911691
Clayton GD, Clayton FE, eds. 1981. Patty’s industrial hygiene and toxicology. Volume 2B: Toxicology. 3rd ed. New York, NY: John Wiley and Sons, 3373, 3397–3398.
*Clonfero E, Zordan M, Cottica D, . 1986. Mutagenic activity and polycyclic aromatic hydrocarbon levels in urine of humans exposed to therapeutic coal tar. Carcinogenesis 7:819–823.3698208
Clonfero E, Zordan M, Venier P, . 1989. Biological monitoring of human exposure to coal tar. Urinary excretion of total polycyclic aromatic hydrocarbons. 1-hydroxypyrene and mutagens in psoriatic patients. Int Arch Occup Environ Health 61:363–368.2744865
*Commonwealth of Kentucky. 1992. Oil recovery. Frankfort, KY: Kentucky Revised Public Health Statutes 224.
*Commonwealth of Massachusetts. 1992. Provisions for recyclable materials and for waste oil. Boston, MA: Department of Environmental Quality Engineering, Massachusetts Regulation Code 310 CMR.
*Commonwealth of Pennsylvania. 1992. Pennsylvania used oil recycling act. Harrisburg, PA: Pennsylvania Conservation Statutes P.S. 471.
*Commonwealth of Virginia. 1992. Standards for the management of specific hazardous wastes and specific types of management facilities. Richmond, VA: Department of Waste Management, Virginia Hazardous Waste Regulations VR 672-10-1.
Conaway CC, Schreiner CA, Cragg ST. 1984. Mutagenicity evaluation of petroleum hydrocarbons. Advances in Modem Environmental Toxicology 6:89–107.
*Connell DW, Miller GJ. 1981. Petroleum hydrocarbons in aquatic ecosystems - Behavior and effects of sublethal concentrations: Part 2. XI Tainting. CRC Critical Review of Environmental Control 11(2):105–162.
*Cooper JS. 1977. The lead problem associated with recycled oil. National Bureau of Standards Special Publication No. 488. Proceedings of a Workshop on Measurements and Standards for Recycled Oil held at National Bureau of Standards, Gaithersburg, MD, November 22-23, 1976, 103–104.
*Costa DL, Amdur MO. 1979a. Effect of oil mists on the irritancy of sulfur dioxide: II. Motor oil. Am Ind Hyg Assoc J 40(9):809–815.574713
*Costa DL, Amdur MO. 1979b. Respiratory response of guinea pigs to oil mists. Am Ind Hyg Assoc J 40(8):673–679.495469
Cotton FO, Whisman ML, Goetzinger JW, . 1977. Analysis of 30 used motor oils. Hydrocarbon Processing 56(9):131–140.
*Cruickshank CN, Squire JR. 1993. Skin cancer in the engineering industry from the use of mineral oil. Br J Ind Med 50(4):289–300.8494769
*Dautrebande L, Capps R. 1950. Studies on aerosols: IX. Enhancement of irritating effects of various substances on the eye, nose, and throat by particulate matter and liquid aerosols in connection with pollution of the atmosphere. Arch Int Pharmacodyn Ther 82(4):505–528.15419889
*Dautrebande L, Shaver J, Capps R. 1951. Study on aerosols: XI. Influence of particulate matter on the eye irritation produced by volatile irritants and importance of particle size in connection with atmospheric pollution. Arch Int Pharmacodyn Ther 85(1–2):17–48.14820386
Dean AL. 1948. Epithelioma of scrotum. J Urol 60:508–518.18880478
Deutsch-Wenzel RP, Herrmann H, Jungen H, . 1987. [Effects of isoparaffins on man and animals.] ISS DGMK-174-9:180.
*District of Columbia. 1992. Dust suppression and road treatment. Washington, DC: DC Code Annotated 6-713.
*DOE. 1989. Mineral base crankcase oil. In: The installation restoration program toxicology guide. Vol. 4. Wright-Patterson Air Force Base, OH: Harry G. Armstrong Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Department of Energy Interagency Agreement No. 1891-A076-Al.
Doll K. 1985. [Used motor oil poisoning in cattle.] Altolvergiftung beim Rind Fallbericht Tierarztl Prax Suppl 1:41–144.4012778
*DOT. 1983. Inhalation toxicology: III. Evaluation of thermal degradation products from aircraft and automobile engine oils, aircraft hydraulic fluid, and mineral oil. Civil Aeromedical Institute, Federal Aviation Administration, Oklahoma City, OK. Washington, DC: U.S. Department of Transportation. FAA-AM-83-12. Order No. AD-A133221:20.
Dougherty EJ, Overcash MR, McPeters AL. 1991. Estimated TCDD photodegradation in waste motor oil. Hazardous Waste and Hazardous Materials 8(4):313–317.
Dunn BP, Stich HF. 1976. Monitoring procedures for chemical carcinogenic in coastal waters. Journal of the Fisheries Research Board of Canada 33:2040–2046.
*Dutcher JS, Clark CR. 1981. Mutagenicity of used diesel crankcase oil. Annual Report of the Inhalation Toxicology Research Institute for the U.S. Department of Energy. Report No. LMF-91:248–250.
Dutcher JS, Li AP, Clark CR. 1982. Comparative mutagenicity of used crankcase oil from diesel and spark ignition powered cars. Annual Report of the Inhalation Toxicology Research Institute (Lovelace Biomedical and Environmental Research Institute, 118–121.
*Dutcher JS, Li AP, McClellan RO. 1986. Mutagenicity of used crankcase oils from diesel and spark ignition automobiles. Environ Res 40(1):155–63.3519206
*Eastin WC Jr, Hoffman DJ, O’Leary CT. 1983. Lead accumulation and depression of delta-aminolevulinic acid dehydratase (ALAD) in young birds fed automotive waste oil. Arch Environ Contam Toxicol 12(1):31–5 6830307
*Ellenhorn MJ, Barceloux DG. 1988. Hydrocarbon products: Petroleum distillates. In: Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 940–947.
*Elsavage RE, Sexstone AJ. 1989. Biodegradation of a dilute waste oil emulsion applied to soil. Journal of Industrial Microbiology 289–298.
*Entropy Inc. 1994. Metals emissions from the combustion of used fuel oil, phase I, literature search and survey. Entropy, Inc. Research Triangle Park, NC.
*EPA. 1972. Waste lube oils pose disposal dilemma. Washington, DC: U.S. Environmental Protection Agency. Environmental Science and Technology 6:25–26.
*EPA. 1974a. Waste automotive lubricating oil: Reuse as a fuel. Washington, DC: U.S. Environmental Protection Agency. EPA 600/5-74-032.
*EPA. 1974b. Waste oil recycling and disposal. Cincinnati, OH: U.S. Environmental Protection Agency. EPA 670/2-74-052.
EPA. 1977. The short-term effects of lead on domestic and wild animals. Washington, DC: U.S. Environmental Protection Agency. EPA 600/3-77-009.
*EPA. 1980a. Hazardous wastes from non-specific sources. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.3.
EPA. 1980b. Nitrosamine analysis of diesel crankcase emissions. Washington, DC: U.S. Environmental Proteetion Agency. EPA 460/3-81-008. NTIS Order No. PB81-212458:220.
EPA. 1980c. Results from repeated skin application of used motor oil to mice. Interim research reports with cover letter. Washington, DC: Office of Toxic Substances, U.S. Environmental Protection Agency. EPA/OTS No. FYI-OTS-1080-0090.
*EPA. 1980d. Salmonella/microsome mutagenicity assays of exhaust from diesel and gasoline powered motor vehicles. Ann Arbor, MI: U.S. Environmental Protection Agency. EPA 600/9-80-057a:327–344.
*EPA. 1981. Nitrosamines and other hazardous emissions from engine crankcases. US Environmental Protection Agency. EPA/AA/CTASB/PA/81-15.
EPA. 1984. Waste crankcase oil heater study: Phase 2: Organic and inorganic speciation analyses. Washington, DC: U.S. Environmental Protection Agency. EPA 600/S7-84-072. NTIS Order No. PB84-212224:66.
*EPA. 1984. X-Ray diffraction phase analysis of process and pollution control device samples. US Environmental Protection Agency. EPA-600/D-84-083.
EPA. 1986. Response to the chemical advisory entitled “Notice of potential risk - used motor oil,” with cover letter dated 04/04/86 & EPA acknowledgment letter. Ford Motor Co., Ltd. Washington, DC: Office of Toxic Substances, U.S. Environmental Protection Agency. Document No. FYI-OTS-0786-0501.
*EPA. 1989. Water quality criteria documents: Availability. U.S. Environmental Protection Agency. Federal Register 45(231):79318.
*EPA. 1990. Characteristics of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.21-261.24.
*EPA. 1992a. EPA standards for managing used oil. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 279.
*EPA. 1992b. Hazardous waste exclusions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.4.
*Eyres AR. 1981. Polycyclic aromatic hydrocarbon contents of used metalworking oils. Petrol Rev February:32–35.
Eyres AR, Molyneux MKB, Pearson JW, . 1983. Health aspects of lubricants. PB83-168674.
Fabia J, Thuy TD. 1974. Occupation of father at time of birth of children dying of malignant diseases. Br J Prev Sot Med 28:98–100.
*Falahi-Ardakani A. 1984. Contamination of environment with heavy metals emitted from automobiles. Ecotoxicol Environ Safety 8:152–161.6201332
*Fan LL, Graham LM. 1994. Radiological cases of the month: Lipoid pneumonia from mineral oil aspiration. Arch Pediatr Adolesc Med 148(2):205–6.8118542
*Farrington J, Quinn J. 1973. Petroleum hydrocarbon and fatty acids in wastewater effluents. J Water Pollut Control Fed 45:704–712.
*Fingl E. 1980. Laxatives and cathartics. In: Gilman AG, Goodman LS, Gilman A, eds. Goodman and Gilman’s: The pharmacological basis of therapeutics, 6th edition. New York, NY: MacMillan Publishing Co., 1002–1012.
*Freestone FJ. 1972. Runoff of oils from rural roads treated to suppress dust. National Environmental Research Center, U.S. Environmental Protection Agency. EPA-R2-72-054.
*Freestone FJ. 1979. Runoff of oils from rural roads treated to suppress dust. National Bureau of Standards Special Publication 556. Proceedings of a workshop on measurements and standards for recycled oil - II, National Bureau of Standards, Gaithersburg, MD, November 29-30, 1977, 72–86.
*Gallagher JE, Jackson MA, George MJ, . 1990. Dose-related differences in DNA adduct levels in rodent tissues following skin application of complex mixtures from air pollution sources. Carcinogenesis 11:63–68.2403860
*Gerarde HW. 1963. Toxicological studies on hydrocarbons: IX. The aspiration hazard and toxicity of hydrocarbons and hydrocarbons mixtures. Arch Environ Health 6:329–341.13947290
*Gish GD, Christensen RE. 1973. Cadmium, nickel, lead and zinc in earthworms from roadside soil. Environmental Science and Technology 7:1060–1062.22263952
Goff EU, Coombs JR, Fine DH, . 1980. Nitrosamine emissions from diesel engine crankcases. Society of Automotive Engineers Technical Paper Series. No. 801374:8.
Gold EB, Diener MD, Szklo M. 1982. Parental occupations and cancer in children: A case-control study and review of the methodological issues. J Occup Med 24:578–584.6750059
*Goldfrank LR, Kulberg AG, Bresnitz EA. 1990. Hydrocarbons. In: Goldfrank LR, Weisman RS, Flomenbaum NE, ., eds. Toxicologic emergencies. Norwalk, CT: Appleton and Lange, 759–768.
Goldsmith AM, Vorpahl KW, French KA, . 1976. Health hazards from oil, soot and metals at a hot forging operation. Am Ind Hyg Assoc J 37:217–226.1274841
Gordon DC, Prouse NJ. 1973. The effect of three oils on marine phytoplankton photosynthesis. Marine Biology 22:329–333.
Gosslein RE, Smith RP, Hodge HC, ., eds. 1984. Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams and Wilkins, 11–157, VI-81–VI-82.
*Gayer, RA. 1986. Toxic effects of metals. In: Klaassen CD, Amdur MO, Doull J. eds. Toxicology: The Basic Science of Poisons, Third Edition. New York, NY: Macmillan Publishing Company, 582–635.
Gradiski D, Vinot J, Zussu D, . 1983. The carcinogenic effect of a series of petroleum-derivative oils on the skin of mice. Environ Res 32:258–268.6315389
*Granella M, Clonfero E. 1991. The mutagenic activity and polycyclic aromatic hydrocarbon content of mineral oils. Int Arch Occup Environ Health 63(2):149–153.1889886
*Granella M, Clonfero E. 1993. Urinary excretion of 1-pyrenol in automotive repair workers. Int Arch Occup Environ Health 65(4):241–245.8144234
Graves RC, Flo S. 1940. Carcinoma of the scrotum. J Urol 43:309–332.
Griffin LF, Calder JA. 1977. Toxic effect of water-soluble fractions of crude, refined and weathered oils on the growth of marine bacterium. Appl Environ Microbial 33:1092–1096.
Grimmer G. 1982. Balancing the carcinogenic effects from emissions of automobiles and coal combustion by carcinogen-specific tests. Funktionelle Biologie and Medizin 1(1):29–38.
*Grimmer G, Dettbarn G, Brune H, . 1982a. Quantification of the carcinogenic effect of polycyclic aromatic hydrocarbons in used engine oil by topical application onto the skin of mice. Int Arch Occup Environ Health 50(1):95–100.7085089
Grimmer G, Jacob J, Naujack KW, . 1981a. Profile of the polycyclic aromatic hydrocarbons from used engine oil - Inventory by GCYMS - PAH in environmental materials, part 2. Fresenius’ Journal of Analytical Chemistry 309(1):13–19.
Grimmer G, Jacob J, Naujack KW. 1981b. Profile of the polycyclic aromatic hydrocarbons from lubricating oils: Inventory by GC/MS - PAH in environmental materials, part 1. Fresenius’ Journal of Analytical Chemistry 306:347–355.
*Grimmer G, Naujack KW, Dettbam G, . 1982b. Analysis of balance of carcinogenic impact from emission condensates of automobile exhaust, coal heating, and used engine oil by mouse-skin-painting as a carcinogenic-specific detector. Polynuclear Aromatic Hydrocarbons. 6th Physical and Biological Chemistry International Symposium, Columbus, OH, October 27-30, 1981. Columbus, OH: Battelle Press, 335–345.
*Grimmer G, Naujack KW, Dettbam G, . 1983. Characterization of polycyclic aromatic hydrocarbons as essential carcinogenic constituents of coal combustion and automobile exhaust using mouse-skin-painting as a carcinogen-specific detector. Toxicological and Environmental Chemistry 6(2):97–107.
Gunster DG, Gillis CA, Bonnevie NL, . 1993. Petroleum and hazardous chemical spills in Newark Bay, New Jersey, USA from 1982 to 1991. Environmental Pollution 82:245–253.15091773
Gusev MV, Koronelli TV, Linkova MA, . 1981. Study of the association between cyanobacteria and oil-oxidizing bacteria in oil spills. Mikrobiologiya 50:1092–1098.
*Haddad LM, Winchester JF, eds. 1990. Petroleum distillates and turpentine. In: Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, 1177–1186, 1222–1232.
Hakulinen T, Salonen T, Teppo L. 1976. Cancer in the offspring of fathers in hydrocarbon-related occupations. Br J Prev Sot Med 30:138–140.
*Hall RE Barbour RL, Cooke WM. 1983a. Chemical analysis of waste crankcase oil combustion samples (project summary). Research Triangle Park, NC: Environmental Protection Agency, Industrial Environmental Research Laboratory, June 1983, 3. EPA-600/S7-83-026.
*Hall RE, Cooke WM, Barbour RL. 1983b. Comparison of air pollutant emissions from vaporizing and air atomizing waste oil heaters. J Air Pollut Control Assoc 33(7):683–687.
Handa T, Yamamura T, Kato Y, . 1979. Average emission rates of polynuclear aromatic hydrocarbons and mileage accumulation of automobiles. Taiki Osen Gakkaishi 14(2):53–61.
*HAZDAT. 1995. Agency for Toxic Substance and Disease Registry (ATSDR), Atlanta, GA. October 30, 1995.
Hemminki K, Saloniemi I, Salonen T, . 1981. Childhood cancer and parental occupation in Finland. J Epidemiol Community Health 35:11–15.7264527
Henry SA. 1937. The study of fatal cases of cancer of the scrotum from 1911 to 1935 in relation to occupation, with special reference to chimney sweeping and cotton mule spinning. Am J Cancer 31:28–57.
Henry SA, Irvine ED. 1936. Cancer of the scrotum in the Blackbum registration district, 1837-1929. J Hyg 36:310–340.20475330
*Hermann M, Chaude O, Weill N, . 1980a. Adaptation of the salmonella/mammalian microsome test to the determination of the mutagenic properties of mineral oils. Mutat Res 77(4):327–339.6990250
*Hermann M, Durand JP, Charpentier JM, . 1980b. Correlation of mutagenic activity with polynuclear aromatic hydrocarbon content of various mineral oils. Polynuclear Aromatic Hydrocarbon Chemistry and Biological Effects, 4th International Symposium. Columbus, OH: Battelle Press, 899–916.
*Hewstone RK. 1994a. Environmental health aspects of lubricant additives. Sci Total Environ 156(3):243–54.7801111
Hewstone RK. 1994b. Health, safety and environmental aspects of used crankcase lubricating oils. Sci Total Environ 156:255–268.7801112
Hilfreich K, McNicol JC, Rosenfeld L. 1948. Examination of used engine lubrication oils. Journal of the Institute of Petroleum 34:147–225.
Hilmer T, Bate GC. 1983. Observation on the effect of outboard motor fuel oil on phytoplankton cultures. Environmental Pollution A32:307–316.
Hodgson G. 1970. Cutaneous hazards of lubricants. Industrial Medicine 39(2):68–73.
*Hoffman DJ, Albers PH. 1984. Evaluation of potential embryotoxicity and teratogenicity of 42 herbicides, insecticides and petroleum contaminants to mallard (Anas platyrhynchos) eggs. Arch Environ Contam Toxicol 13(1):15–28.6703782
*Hoffman DJ, Eastin WC, Gay ML. 1982a. Embryonic and biochemical effects of waste crankcase oil on bird eggs. Toxicol Appl Pharmacol 63:230–241.7201176
Hoffman DJ, Eastin WC Jr, Gay ML. 1982b. Morphological and biochemical effects of waste oil on avian development. Teratology 25(2):49A.
Hoffman EJ, Mills GL, Latimer JS, . 1984. Urban runoff as a source of polycyclic aromatic hydrocarbons to coastal waters. Environmental Science and Technology 18:580–587.22300054
Horowitz A, Atlas RM. 1977. Response of microorganisms to an accidental gasoline spillage in an arctic freshwater ecosystem. Appl Environ Microbial 33:1252–1258.
Horton AW, Bingham EL, Burton MJG, . 1965. Carcinogenesis of the skin: III. The contribution of elemental sulfur and of organic sulfur compounds. Cancer Res 25:1759–1763.5859201
*Howard AJ, Mitchell CE, Dutcher JS, . 1986. Binding of nitropyrenes and benzo[a]pyrene to mouse lung deoxyribonucleic acid after pretreatment with inducing agents. Biochem Pharamcol 35:2129–2134.
Hsieh YP, Tomson MB, Ward CH. 1980. Toxicity of water-soluble extracts of No. 2 fuel oil to the freshwater alga Selenastrum capricomutum. Developments in Industrial Microbiology 21:401–409.
Huguenin R, Fauvet J, Mazabraud M. 1950. Possible role of mineral oil aerosols in bronchopulmonary cancers pathogeny. Arch Ma1 Prof 11:48–51.
*Hunter JV, Sabatino T, Gomperts R, . 1979. Contribution of urban runoff to hydrocarbon pollution. J Water Pollut Control Fed 51:2129–2138.522215
*Hyland JL, Schneider ED. 1976. Petroleum hydrocarbons and their effects on marine organisms, populations, communities, and ecosystems. In: Sources, effects and sinks of hydrocarbons in the aquatic environment. American Institute of Biological Sciences, Washington, D.C., 463.
*IARC. 1984. Mineral oils. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Vol 33: Polynuclear aromatic hydrocarbons: Part 2: Carbon blacks, mineral oils (lubricant base oils and derived products) and some nitroarenes. Lyon, France: International Agency for Research on Cancer, World Health Organization, 87–168.
*Ingram AJ, Scammells DV, May K. 1994. An investigation of the main mutagenic components of a carcinogenic oil by fractionation and testing in the modified Ames assay. J Appl Toxicol 14(3):173–9.8083478
*Iyer V, Harris RE, Wynder RE. 1990. Diesel exhaust exposure and bladder cancer risk. Eur J Epidemiol 6:49–54.1693120
Jagger H. 1976. Comments on “Used crankcase oil as a metal-cutting fluid.” Wear 38(2):395–396.
Jenks JM, Anselmo V, Bradford C, . 1984. Waste oil use in Texas: Lead, sulfur, and chlorine in fuel oils. In: Proceedings of Air Pollution Control Association 77th Annual Meeting, San Francisco, CA, June 24-29, 1989. Pittsburgh, PA: Air Pollution Control Association, 84-1 1.4: 1–15.
Jensen V. 1977. Effects of lead on the biodegradation of hydrocarbons in soil. Oikos 28:220–224.
Jongeneelen FJ, Anzion RBM, Scheepers PTJ, . 1988a. 1-Hydroxypyrene in urine as a biological indicator of exposure to polycyclic aromatic hydrocarbons in several work environments. Ann Occup Hyg 32:35–43.3369793
Jongeneelen FJ, Anzion RBM, Theuws JLG, . 1989. Urinary 1-hydroxypyrene levels in workers handling petroleum coke. J Toxicol Environ Health 26:133–136.2913332
Jongeneelen FJ, Bos RP, Henderson PT. 1988b. Metabolites of polycyclic aromatic hydrocarbons in urine of exposed workers. Toxicol Environ Chem 16:295–307.
Jongeneelen FJ, Leijdekkers CM, Henderson PT. 1984. Urinary excretion of 3-hydroxy-benzo[a]pyrene after percutaneous penetration and oral absorption of benzo[a]pyrene in rats. Cancer Lett 25:195–201.6509438
*Jongeneelen FJ, Scheepers PIJ, Groenendijk A, . 1988c. Airborne concentration, skin contamination and urinary metabolite excretion of PAH among paving workers exposed to coal tar derived road tars. Am Ind Hyg Assoc J 49:600–607.3213813
Kadam AN, Zingde MD. 1985. Infra-red spectroscopic analysis of used crankcase oil. Research and Industry 30(4):382–385.
*Kahsnitz R, Allen RL, Collings AJ, . 1982. Precautionary advice on the handling of used engine oils. Sci Total Environ 24(2):193–198.7112100
Kamrin MA, Carney EW, Chou K, . 1994. Female reproductive and developmental toxicology: Overview and current approaches. Toxicol Lett 14(2):99–119.
Kantor AF, McCrea Cumen MG, Meigs JW, . 1979. Occupations of fathers of patients with Wilm’s tumour. J Epidemiol Community Health 33:253–256.231629
Kawamura M, Fujita K, Ninomiya K. 1982. The lubricating properties of used engine oil. Wear 77(2):195–202.
Kellerman G, Shaw CR, Luyten-Keller-man M. 1973. Aryl hydrocarbon hydroxylase inducibility and bronchogenic carcinoma. N Engl J Med 289:934–937.4126515
*Kensler TW, Egner PA, Moore KG, . 1987. Role of inflammatory cells in the metabolic activation of polycyclic aromatic hydrocarbons in mouse skin. Toxicol Appl Pharmacol 90:337–346.3629608
Kickham CJE, Dufresne M. 1967. An assessment of carcinoma of the scrotum. J Urol 98:108–110.6067877
*Kirk-Othmer, ed. 1981. Encyclopedia of chemical technology. Vol. 14, 3rd ed. New York, NY: John Wiley and Sons, 484–497, 524–526.
Klauder JV, Brill FA. 1947. Correlation of boiling ranges of some petroleum solvents with irritant action on skin. Archives of Dermatology and Syphilology 56:197.20257237
Kloepffer W. 1994. Environmental hazard: Assessment of chemicals and products: Part I. General assessment principles. Environmental Science and Pollution Research International 1(1):48–53.
Kopanica M, Stara V. 1991. Determination of amalgam-forming metals by anodic stripping voltammetry in solutions containing dissolved oxygen. Electroanalysis 3(9):925–928.
Koreeda M, Moore PD, Wislocki PG, . 1978. Binding of benzo[a]pyrene 7,8-diol-9,10-epoxides to DNA, RNA and protein of mouse skin occurs with high stereoselectivity. Science 199:778–781.622566
Kubic TA, Sheehan FX. 1983. Individualization of automobile engine oils: II. Application of variable separation synchronous excitation fluorescence to the analysis of used automobile engine oils. J Forensic Sci 28(2):345–350.
Kulikova VA, Avdonin YA, Mchedlishvili BV, . 1986. Treatment of used motor oils by means of polymeric membranes. Chemistry and Technology of Fuels and Oils 22(3–4):154–156.
*Kurelec B, Gupta RC. 1993. Biomonitoring of aquatic systems. IARC Sci Publ 124:365–372.
Kurelec B, Chacko M, Gupta RC. 1988. Postlabeling analysis of carcinogen-DNA adducts in mussel, Mytilus galloprovincialis. Mar Environ Res 24:317–320.
Kurelec B, Garg A, Krca S, . 1989. DNA adducts as biomarkers in genotoxic risk assessment in the aquatic environment. Mar Environ Res 28:317–321.
Kurelec B, Garg A, Krca S, . 1990. DNA adducts in marine mussel Mytilus galloprovincialis living in polluted and unpolluted environments. In: McCarthy, JJ & Shugart, LR, eds, Biological Markers of Environmental Contamination, Chelsea, MI, Lewis. 217–227.
Kurelec B, Garg A, Krca S, . 1992. DNA adducts in carp exposed to artificial diesel-2 oil slicks. Eur J Pharmacol 228:51–56.1397068
Kurelec B, Krca S, Garg A, . 1991. The potential of carp to bioactivate benzo[a]pyrene to metabolites that bind to DNA. Cancer Lett 57:255–260.2032212
Kwa SL, Fine LJ. 1980. The association between parental occupation and childhood malignancy. J Occup Med 22:792–794.7218055
*Lagerwerff JV, Specht AW. 1970. Contamination of roadside soil and vegetation with cadmium, nickel, lead, and zinc. Environmental Science and Technology 4:583–586.
Laires A, Borba H, Rueff J, . 1982. Urinary mutagenicity in occupational exposure to mineral oils and iron oxide particles. Carcinogenesis 3:1077–1079.7139865
Lashkhi VL, Shor GI, Skinder NI, . 1990. Standardization of parameters of the state of used engine oils. Chemistry and Technology of Fuels and Oils 26(9–10):526–530.
Lashkhi VL, Shor GI, Zolotov VA. 1992. Principles for evaluating the state of a used motor oil. Chemistry and Technology of Fuels and Oils 28(3–4):211–214.
*Latimer JS, Hoffman EJ, Hoffman G, . 1990. Sources of petroleum hydrocarbons in urban runoff. Water Air Soil Pollut 52(1–2):1–21.
Lee KP, Trochimowicz HJ, Reinhardt CF. 1985. Pulmonary response of rats exposed to titanium dioxide (TiO_2_) by inhalation for two years. Toxicol Appl Pharmacol 79:179–192.4002222
Lijinsky W. 1991. The formation and occurrence of polynuclear aromatic hydrocarbons associated with food. Mutat Res 259:251–261.2017211
Livingstone DR, Moore MN, Lowe DM, . 1985. Responses of the cytochrome P-450 monooxygenase system to diesel oil in the common mussel, Mytilus edulis L., and the periwinkle, Littorina Zittorea L. Aquatic Toxicology 7:79–91.
Lofroth G. 1981. Salmonella/microsome mutagenicity assays of exhaust from diesel and gasoline motor vehicles. Environmental International 5:255–261.
London SA, Mantel CR, Robinson JD. 1984. Microbial growth effects of petroleum and shale-derived fuels. Bull Environ Contam Toxicol 32:602–612.6733306
LoRusso JA, Kaiser EW, Lavoie GA. 1983. In-cylinder measurements of wall layer hydrocarbons in a spark ignited engine. Combustion Science and Technology 33:75–112.
*Lu FC. 1991. Basic toxicology: Fundamentals, target organs, and risk assessment. 2nd ed. New York. Hemisphere Publishing Corporation, 93–115.
Ludzack FL, Kinkead D. 1956. Persistence of oily wastes in polluted water under aerobic conditions. Industrial and Engineering Chemistry 48:263–267.
*Lushbaugh CC, Green JW, Redemann CE. 1950. Effects of prolonged inhalation of oil fogs on experimental animals. AMA Arch Ind Hyg Occup Med 1:237–247.
MacCrehan WA, May WE, Yang SD, . 1988. Determination of nitro polynuclear aromatic hydrocarbons in air and diesel particulate matter using liquid chromatography with electrochemical and fluorescence detection. Anal Chem 60:194–199.2451449
*Mackenzie MJ, Hunter JV. 1979. Sources and fates of aromatic compounds in urban stormwater runoff. Environmental Science and Technology 13(2):179–183.
Mackerer CR. 1989. Health effects of oil mists: A brief review. Toxicol Ind Health 5(3):429–440.2669232
*Mahaney PA. 1994. Effects of freshwater petroleum contamination on amphibian hatching and metamorphosis. Environmental Toxicology and Chemistry 13(2):259–265.
Mamleeva NK, Osipova EO, Gizatullina AA, . 1976. Toxicological characteristics of additives TsIATIM-339, VNIINP-354, MASK, PMS, and ANGLOMOL-99, principal components of diesel engine motor oils. Sbomik Nauchnykh Trudov Bashkirskifi Gosudarstvennyfi Mediktlsinskifi Institut 19:143–146.
*Manabe Y, Kinouchi T, Wakisaka K, . 1984. Mutagenic 1-nitropyrene in wastewater from oil-water separating tanks of gasoline stations and in used crankcase oil. Environ Mutagen 6(5):669–681.6383793
*Manahan SE. 1989. Organic pollutants and photochemical smog in the atmosphere. In: Environmental Chemistry, 3rd ed., Willard Grant Press, Boston, MA. 331–355.
*Maugh TH. 1976. Rerefined oil: An option that saves oil, minimizes pollution. Science 193:1108–1110.17792741
Mazzeo JR, Krull IS, Kissinger PT. 1991. Use of Ce(IV) oxidizing agent for the derivatization of polycyclic aromatic hydrocarbons for liquid chromatography - electrochemical detection. J Chromatogr 550(1–2):585–594.1774230
*McKee RH, Plutnick RT. 1989. Carcinogenic potential of gasoline and diesel engine oils. Fundam Appl Toxicol 13(3):545–553.2612787
Mehlman MA. 1991. Dangerous and cancer-causing properties of products and chemicals in the oil refining and petrochemical industry: Part I. Carcinogenicity of motor fuels: Gasoline. Toxicol Ind Health 7(5–6):143–152.1780852
Mehlman MA. 1992. Dangerous and cancer-causing properties of products and chemicals in the oil refining and petrochemical industry: VII. Health effects of motor fuels: Carcinogenicity of gasoline - scientific update. Environ Res 59(1):238–249.1425514
*Moore SF, Dwyer RL. 1974. Effects of oil on marine organisms: A critical assessment of published data. Water Res 8:819.
Moriya K, Horikoshi K. 1993. A benzene-tolerant bacterium utilizing sulfur compounds isolated from deep sea. Journal of Fermentation and Bioengineering 76(5):397–399.
Mortensen KS. 1974. Used crankcase oil as a cutting fluid. Wear 29(1):136–138.
Mortensen KS. 1976. Reply to comments on “Used crankcase oil as a metal-cutting fluid.” Wear 38(2):396.
*Motto HL. 1970. Lead in soil and plants: Its relationship to traffic volume and proximity to highways. Environmental Science and Technology 4:231–237.
*Mueller Associates Inc. 1987. “Waste oil: Technology, economics, and environmental, health, and safety considerations.” U.S. Department of Energy. Washington, DC, January. DE87-009536.
*Mumford JL, Hatch GE, Hall RE, . 1986. Toxicity of particles emitted from combustion of waste crankcase oil: in vitro and in vivo studies. Fundam Appl Toxicol 7(1):49–57.3732672
*Nachtman JP. 1986. Superoxide generation by 1-nitropyrene in rat lung microsomes. Res Commun Chem Pathol Pharmacol 51:73–80.3006195
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
National Petroleum Refiners Association. 1981. Report on US Lubricating Oil Sales. Washington, DC: National Petroleum Refiners Association.
*NATO. 1981. NATO-CCMS pilot study of disposal of hazardous waste: Project: Thermal treatment. North Atlantic Treaty Organization, Committee on the Challenges of Modern Society, Brussels, Belgium. NTIS No. PB82-114521.
*Naughton ABJ, Jespersen ND. 1991. Detection of nitroaromatics as mutagenic components of used motor oils. Anal Chim Acta 251(1–2):95–99.
*Neal DM, Glover RL, Moe PG. 1977. Land disposal of oily wastewater by means of spray irrigation. In: Proceedings of the 1976 Cornell Agricultural Waste Management Conference, Ithaca, NY, 1976, 757–767.
Nelson BK. 1994. Interactions in developmental toxicology: A literature review and terminology proposal. Teratology 49(1):33–71.8171395
*Newborn JS, Preston JS. 1991. Analytical field screening of soil by thin layer chromatography. Hazard Mater Control 4(5):56–59.
*Newton CD, Shepard WW, Coleman MS. 1974. Street runoff as a source of lead pollution. J Water Pollut Control Fed 46:999–1000.4134472
Nicholson M, Taylor J. 1975. The determination of hydraulic oil in the concast plant cooling water using IR spectrometry. General Steels Division, British Steel Corporation, Sheffield, UK. GS/EX/35/74/C. NTIS No. PB 245 060.
NIOSH. 1976. Occupational mortality in Washington State, 1950-1971, Vol. 1. Cincinnati, OH: National Institute for Occupational Safety and Health, 23–24,26,28,33. Contract No. CDC-99-74-26.
*NIOSH. 1977. NIOSH manual of analytical methods. 2nd ed. Vol. 3, method S272. Cincinnati, OH: U.S. Department of Health, Education and Welfare, National Institute of Occupational Safety and Health.
*NIOSH. 1978. NIOSH Manual of analytical methods. 2nd ed., Vol. 4, Method 283, Cincinnati OH: U.S. Department of Health, Education and Welfare, National Institute of Occupational Safety and Health.
*NIOSH. 1984. NIOSH manual of analytical methods. 2nd Vol. Method 5026. Cincinnati, OH: U.S. Department of Health and Human Services, Centers for Disease Control, National Institute of Occupational Safety and Health.
NOAA. 1984. Contamination of populated estuaries and adjacent coastal ocean -- a global review.
NOAA technical memo OMA 11. Stony Brook, NY: National Oceanic Atmospheric Administration, U.S. Department of Commerce.
Ostman CE, Colmsjo AL, Zebuhr YU. 1986. Polycyclic aromatic compounds in lubricating oil: A study of gasoline/methanol, gas and diesel fueled engines. In: Cooke M, Denis AJ, eds. Polynuclear aromatic hydrocarbons: Chemistry, characterization, and carcinogenesis. Proceedings of the Ninth International Symposium, Columbus, Ohio. Batelle Press, 729–744.
*Osweiler GD, Buck WB, Lloyd WE. 1973. Epidemiology of lead poisoning in cattle - a five-year study in Iowa. Clin Toxicol 6(3):367–376.4757380
Palmer JM, Rush MW. 1982. Direct determination of lead in used engine oils by atomic-absorption spectrophotometry. Analyst (London) 107(1278):994–999.
*Pasquini R, Monarca S. 1983. Detection of mutagenic/carcinogenic compounds in unused and used motor oils. Sci Total Environ 32(1):55–64.6665555
*Payne JF, Martins I, Rahimtula A. 1978. Crankcase oils: Are they a major mutagenic burden in the aquatic environment? Science 200:329–330.635591
*Peake E, Parker K. 1980. Polynuclear aromatic hydrocarbons and the mutagenicity of used crankcase oils. Polynuclear aromatic hydrocarbons, Chemistry and Biological Effects, 4th International Symposium. Columbus, OH: Battelle Press, 1025–1039.
Peters JM, Preston-Martin S, Yu MC. 1981. Brain tumors in children and occupational exposure of parents. Science 213:235–237.7244631
Petrilli FL, De Renzi GP, De Flora S. 1980. Interaction between polycyclic aromatic hydrocarbons, crude oil, and oil dispersants in the Salmonella mutagenesis assay. Carcinogenesis 1:51–56.22282980
*Phillips DH, Schoket BA, Hewer A, . 1990. DNA adduct formation in human and mouse skin by mixtures of polycyclic aromatic hydrocarbons. IARC Scientific Publications 104:223–229.
Pruell RJ, Quinn JG. 1988. Accumulation of polycyclic aromatic hydrocarbons in crankcase oil. Environmental Pollution 49:89–97.15092665
Pryor P, Whorton D. 1981. Health hazard evaluation report. Ford Motor Company, San Jose, CA, USA. Report No. HHE-80-094-840. NTIS Order No. PB82-172214:22.
Putinier RA, Norris TA, Moore FP. 1975. Determination of water and ethylene-glycol in used crankcase oils by gas-chromatography. Anal Chem 47(8):1412–1414.
*Rahimtula AD, O’Brien PJ, Payne JF. 1984. Induction of xenobiotic metabolism in rats on exposure to hydrocarbon-based oils. In: MacFarland HN ., eds. Advances in modem environmental toxicology. Volume 16: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 71–79.
*Rahimtula AD, Payne JF, Martins I. 1982. Hydrocarbon-based oils as inducers of cutaneous aryl hydrocarbon hydroxylase. Toxicol Lett 10(2):213–217.7080087
Raymond RL, Hudson JO, Jamison VW. 1975. Assimilation of oil by soil bacteria. Proceedings of the American Petroleum Institute Refining Department 54:429–55.
*Raymond RL, Hudson JO, Jamison VW. 1976. Oil degradation in soil. Environmental Microbiology 31(4):522–535.
Raymond RL, Hudson JO, Jamison VW. 1979. Land application of oil. American Institute of Chemical Engineers Symposium Series 75(190):340–356.
*Rittmann BE, Johnson NM. 1989. Rapid biological clean-up of soils contaminated with lubricating oil. Water and Science and Technology 21:209–219.
Rotard W, Christmann W, Lattner A, . 1987. Occurrence of PCDD and PCDF in motor oils, rerefined oils and contaminated soils. Chemosphere 16(8–9):1847–1849.
*Roy TA, Johnson SW, Blackburn GR, . 1988. Correlation of mutagenic and dermal carcinogenic activities of mineral oils with polycyclic aromatic compound content. Fundam Appl Toxicol 10:466–476.3286347
*Rozman KK, Klaassen CD. 1996. Absorption, distribution, and excretion of toxicants. In: Klaassen CD, ed. Casarett & Doull’s Toxicology: The Basic Science of Poisons, Fifth Edition. New York, NY: Macmillan Publishing Company, 91–112.
*Rudolph MS. 1980. Road oiling - an example of environmental mismanagement. Alternatives 9:32–34.
Ruvinskaya SE. 1975. Toxicological evaluation of the additive BFK (barium salt of formaldehyde condensation). Trudy Azerbafidzhanskogo Nauchno-Issledovatel’skogo Instituta Gigieny Truda I Professional’nykh Zabolevanifi 10:106–108.
Sanders BM, White GC, Draper GJ. 1981. Occupations of fathers of children dying from neoplasms. J Epidemiol Community Health 35:245–250.7338698
*Sas B. 1989. Secondary copper deficiency in cattle caused by molybdenum contamination of fodder: A case history. Vet Hum Toxicol 31(1):29–33.2711604
*Sawyer RF. 1993. Trends in auto emissions and gasoline composition. Environ Health Persp Suppl 101(Supp16):5–12.
Saxton WL, Newton RT, Rorberg J, . 1993. Polycyclic aromatic hydrocarbons in seafood from the Gulf of Alaska following a major crude oil spill. Bull Environ Contam Toxicol 51(4):515–522.8400653
*Scheepers PTJ, Bos RP. 1992. Combustion of diesel fuel from a toxicological perspective. I. Origin of incomplete combustion products. Int Arch Occup Environ Health 64:149–161.1383162
*Schenker MB, Smith T, Munoz A, . 1984. Diesel exposure and mortality among railway workers: Results of a pilot study. Br J Ind Med 41:320–327.6743578
*Schoket B, Hewer A, Grover PL, . 1989. ^32^P-Postlabelling analysis of DNA adducts in the skin of mice treated with petrol and diesel engine lubricating oils and exhaust condensates. Carcinogenesis 10(8):1485–1490.2473852
*Schreiner CA, Mackerer CR. 1982. Mutagenesis testing of gasoline engine oils. Polynuclear Aromatic Hydrocarbons. Physical and Biological Chemistry, 6th International Symposium, Columbus, OH, October 27-30, 1981, 705–712.
Shore PR, Tesh JM, Bootman J. 1987. Applications of short-term bio-assays to the assessment of engine exhaust emissions. Society of Automotive Engineers. Paper 870627. International Congress and Exposition, Detroit, MI, February 23-27, 1987. Detroit, MI: Society of Automotive Engineers.
*Shoshkes M, Banfield WG, Rosenbraum SJ, . 1950. Distribution, effect and fate of oil aerosol particles retained in the lungs of mice. AMA Arch Ind Hyg Occup Med 1:20–35.
Shu H, Teitelbaum P, Webb AS, . 1988. Bioavailability of soil-bound TCDD: Dermal bioavailability in the rat. Fundam Appl Toxicol 10(2):335–343.3356321
Siegel JA, Fisher J, Gilna C, . 1985. Fluorescence of petroleum products: I. Three-dimensional fluorescence plots of motor oils and lubricants. J Forensic Sci 30(3):741–759.
*Siemiatycki J, Germ M, Stewart P, . 1988. Association between several sites of cancer and ten types of exhaust and combustion products. Stand J Work Environ Health 14:79–90.
Sikka HC, Rutkowski JP, Kandaswami C, . 1990. Formation and persistence of DNA adducts in the liver of brown bullhead exposed to benzo[a]pyrene. Cancer Lett 49:81–87.2105836
Slims P, Grover PL, Swaisland A, . 1974. Metabolic activation of benzo[a]pyrene proceeds by a diol-epoxide. Nature 252:326–328.4473724
Southam AH, Wilson SR. 1922. Cancer of the scrotum: The etiology, clinical features, and treatment of the disease. Br Med J 4:971–973.
*Spickard A 3rd, Hirschmann JV. 1994. Exogenous lipoid pneumonia. Arch Intern Med 154(6):686–92.8129503
Starek A, Cembala D. 1974. [Toxicity of petrochemical dielectrics used in electroerosive treatment (of metals) on cutaneous application to rats.] Med Pr 25 (2):187–192.
*State of Alabama. 1991. Alabama standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Montgomery, AL: Alabama Administrative Code 335-14-7.
*State of Alaska. 1992. Standards applicable to an owner or operator of a hazardous waste treatment, storage, or disposal facility. Juneau, AK: Alaska Administrative Code 18 AAC 62.410.
*State of Arizona. 1992. Management of used oil-the environment. Phoenix, AZ: Department of Environmental Quality, Arizona Regulatory Statutes 49:767–813.
*State of Arkansas. 1992. Regulations promulgated under the Arkansas Hazardous Waste Management Act of administration of the state RCRA program. Little Rock, AR: Arkansas Hazardous Waste Management Code, Title 8, Chapter 2.
*State of California. 1992. California oil recycling enhancement, management of used oil health and safety code. Sacramento, CA: California Public Resources Code Title 26.
*State of Colorado. 1992. Standards applicable to users of hazardous waste that are used in a manner that constitutes disposal. Denver, CO: Colorado Code of Regulations 267.23, sections 5 and 6.
*State of Connecticut. 1991. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Hartford, CT: Department of Environmental Protection, Connecticut Agencies Regulations Section 22a.
*State of Delaware. 1992. Solid waste management standards and standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Dover, DE: Delaware Hazardous Waste Rules and Conservation Statutes 6450-6460, and part 266.
*State of Florida. 1992. Used oil management. Tallahassee, FL: Florida Administrative Code Chapter 17-710.
*State of Georgia. 1992. Standards applicable to hazardous waste management. Atlanta, GA: Georgia Rules and Regulations Chapter 391-3-11.
*State of Hawaii. 1992. Used oil control: transport, recycling, and disposal. Honolulu, HI: Hawaii Revised Statutes Chapter 342N.
*State of Idaho. 1992. Hazardous waste management regulations: Oils. Statutes. Boise, ID: Idaho Code Chapter 25:37.2500.
*State of Illinois. 1992. Standards for the management of specific hazardous waste and specific types of hazardous waste management facilities. Springfield, IL: Title 35: Environmental Protection, Illinois Administrative Code Subtitle G.
*State of Indiana. 1992. Hazardous waste management permit program. Indianapolis, IN: Indiana Administrative Code 329 IAC 3-57-6.
*State of Iowa. 1992. Reduction and recycling. Des Moines, IA: Iowa Code 455D.
*State of Kansas. 1992. Hazardous waste management. Topeka, KS: Kansas Department of Health and Environment, Kansas Administrative Regulations 28-31-4.
*State of Louisiana. 1992. Used motor oil recycling-standards; prohibited practices; penalties; liability; used oil recycling trust fund. Baton Rouge, LA: LA Sess Law Serv Act No. 964.
*State of Maine. 1992. Waste oil management rules. Augusta, ME: Maine Waste Oil Management Rules Chapter 860.
*State of Maryland. 1992. Used oil recycling. Annapolis, MD: Maryland Natural Resources Code 8-1401.
*State of Michigan. 1992. Used oil recycling act. Lansing, MI: Michigan Compiled Laws Annotated 319.
*State of Minnesota. 1992. Waste management and hazardous waste. St. Paul, MN: Minnesota Statutes 115A, 7045.
*State of Mississippi. 1992. Hazardous waste management regulations and Bureau of Pollution Control regulations. Jackson, MS: Mississippi Hazardous Waste Management Regulations Part 266.
*State of Missouri. 1992. Waste oil. Jefferson City, MO: Chapter 1110 CSR 25-11.
*State of Montana. 1992. Waste oil. Helena, MT: Montana Administrative Rules ALS 623, Montana HB 145.
*State of Nebraska. 1992. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Lincoln, NB: Nebraska Department of Environmental Control, Nebraska Rules and Regulations Title 128.
*State of Nevada. 1992. Disposal of special wastes: Waste oils. Carson City, NV: Nevada Administrative Code 44.86.
*State of New Hampshire. 1992. Requirements for management of used oil being recycled. Concord, NH: New Hampshire Code of Administrative Regulations Env-Wm Part 807.
*State of New Jersey. 1992. Conservation and development and waste management. Trenton, NJ: New Jersey Revised Statutes 13:1E-99 and 7:26.
*State of New Mexico. 1991. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Santa Fe, NM: Part VII, New Mexico Hazardous Waste Regulations.
*State of New York. 1992. Rerefining of used oil. Albany, NY:1991 New York Environmental Conservation Law Title 23.
*State of North Carolina. 1992. Solid waste management. Raleigh, NC: North Carolina General Statutes EHNR T15A:13A.
*State of North Dakota. 1992. Disposal regulations. Bismarck, ND: North Dakota Administrative Code 23-29-05.2 and 33-24-05-204.
*State of Ohio. 1992. Miscellaneous methods of waste treatment. Columbus, OH: Ohio Administrative Code Chapter 3745-58.
*State of Oklahoma. 1991. Industrial waste management regulations. Oklahoma City, OK: Oklahoma Industrial Waste Regulations Part 266.
*State of Oregon. 1992. Pollution control: Used oil recycling and hazardous waste management. Salem, OR: Department of Environmental Quality, Oregon Revised Statutes Part 468 and Chapter 340, Division 100.
*State of Rhode Island. 1992. Used oil recycling. Providence, RI: Rhode Island General Laws Chapter 19.6.
*State of South Carolina. 1992. Solid waste disposal. Columbia, SC: South Carolina Code Annotated Section 44-96 and Health and Environmental Control R 61-79.266.
*State of South Dakota. 1992. Management of specific hazardous wastes. Pierre, SD: South Dakota Administrative Regulations Section 74:28:27:01.
*State of Tennessee. 1992. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Nashville, TN: Tennessee Compiled Rules and Regulations Chapter 1200-1-11.
*State of Texas. 1992. Used oil collection, management and recycling. Austin, TX: Texas General Laws Chapter 371.
*State of Utah. 1992. Gas processing and waste crude oil treatment, oil re-refining, oil, gas and mining; oil and gas. Salt Lake City, UT: Natural Resources Utah Administrative Regulations R615-5-6.
*State of Vermont. 1992. Waste oil report. Montpelier, VT: Vermont Admin Proc Comp Natural Resources and Laws 75, Sec. 3A.
*State of Washington. 1992. Used oil recycling. Olympia, WA:1991 Washington Laws Part III, section 301.
*State of West Virginia. 1992. Solid waste management regulation. Charleston, WV: West Virginia Solid Waste Management Regulations Title 47.
*State of Wisconsin. 1992. Hazardous waste burned for energy recovery. Madison, WI: Wisconsin Statutes Annotated-Solid Waste 159, 600.04, 625.07.
*State of Wyoming. 1992. Solid waste management rules and regulations. Cheyenne, WY: Wyoming Department of Environmental Quality (DEQ), Solid Waste Management Rules and Regulations Chapter I, Section L.
*Stehouwer DM. 1980. An assessment of used engine oil recycling. Society of Automotive Engineers. Fuels and Lubricants Meeting, Baltimore, MD, October 20-23, 1980.
*Steineck G, Plato N, Alfredsson L, . 1989. Industry-related urothelial carcinogens: Application of a job-exposure matrix to census data. Am J Ind Med 16(2):209–224.2773949
Sternberg, J. 1992. Oil recycling: Used lubricants to gasoline. Biocycle 33(5):80.
Stenberg U, Alsberg T, Westerholm R. 1983. Emission of carcinogenic components with automobile exhausts. Environ Health Perspect 47:53–63.6186483
*Sun Y. 1990. Free radicals, antioxidant enzymes, and carcinogenesis. Free Rad Biol Med 8:583–599.2193855
*Suprenant NF, Battye WH, Fennelly PF, . 1983. The fate of hazardous and nonhazardous wastes in used-oil disposal and recycling. U.S. Department of Energy, Washington, DC. DE-AC19-81BC10375.
Takagi Y, Endoh O, Goto S, . 1986. [Mutagenicities of engine oils of gasoline and diesel cars.] Taiki Osen Gakkaishi 21(4):312–321.
*Tanacredi JT. 1977. Petroleum hydrocarbons from effluents: Detection in marine environment. J Water Pollut Control Fed 49:216–226.
*Tanacredi JT, Cardenas RR. 1991. Biodepuration of polynuclear aromatic hydrocarbons from a bivalve mollusk, Mercenaria mercenaria L. Environmental Science and Technology 25(8):1453–1461.
Thakker DR, Yagi H, Akagi H, . 1977. Metabolism of benzo[a]pyrene: VI. Stereoselective metabolism of benzo[a]pyrene and benzo[a]pyrene-7,8-dihydrodiol to diol-epoxides. Chem Biol Interact 16:281–300.862130
Thomas DH, Delfino JJ. 1991. Ground Water Monitoring Review 11(4):90–100.
Tolos WP, Shaw PB, Lowry LK, . 1990. 1-pyrenol: a biomarker for occupational exposure to polycyclic aromatic hydrocarbons. Appl Occup Environ Hyg 5:303–309.
*TRI93. 1995. Toxic Chemical Release Inventory. U.S. Environmental Protection Agency, Office of Toxic Substances, Washington, DC.
Trivalle C, Profit P, Bonnet B, . 1991. [Liver lipogranulomas with log-term fever caused by paraffinoil.] Gastroenterologie Clinique et Biologique 15(6–7):551–3.1916135
*Upshall C, Payne JF, Hellou J. 1993. Induction of MFO enzymes and production of bile metabolites in rainbow trout (Oncorhynchus mykiss) exposed to waste crankcase oil. Environmental Toxicology and Chemistry 12:2105–2112.
*Van Donkelaar P. 1990. Environmental effects of crankcase- and mixed-lubrication. Sci Total Environ 92:165–179.
Vanderlaan M, Stanker LH, Watkins BE, . 1988. Improvement and application of an immunoassay for screening environmental samples for dioxin contamination. Environ Toxicol Chem 7(11):859–870.
*Vandermeulen JH, Foda A, Stuttard C. 1985. Toxicity vs mutagenicity of some crude oils, distillates and their water-soluble fractions. Water Res 19(10):1283–1289.
*Vazquez-Duhalt R. 1989. Environmental impact of used motor oil. Sci Total Environ 79(1):1–23.2648567
*Vazquez-Duhalt R, Greppin H. 1986. Biodegradation of used motor oil by bacteria promotes the solubilization of heavy metals. Sci Total Environ 52(1–2):109–121.
*Vermont Agency of Natural Resources Department of Environmental Conservation. 1994. Vermont Used Oil Analysis and Waste Oil Furnace Emissions Study.
*Vemot EH Drew RT, Kane ML. 1990. Acute toxicologic evaluation of used motor oil. Acute Toxic Data 1(2):167.
*Vogl G, Elstner EF. 1989. Diesel soot particles catalyze the production of oxy-radicals. Toxicol Lett 47:12–23.
Wachs B, Wagner H, van Donkelaar P. 1992. Two-stroke engine lubricant emissions in a body of water subjected to intensive outboard motor operation. Sci Total Environ 116(1–2):59–81.
Wahlberg JE. 1972. Oil and scrotal cancer (Swed.). Lakartidningen 69:3044–3048.5064392
Wahlberg JE. 1974. Occupational and non-occupational scrotal cancer in Sweden, 1958-1970. Acta Dermatovener 54:471–474.
*Wakeham SG. 1977. A characterization of the sources of petroleum hydrocarbons in Lake Washington. J Water Pollut Control Fed 49:1680–1687.
*Wakeham SG, Carpenter R. 1976. Aliphatic hydrocarbons in sediments of Lake Washington. Limnology and Oceanography 21:711.
Walker JD, Colwell RR. 1974. Microbial petroleum degradation: Use of mixed hydrocarbon substrates. Appl Microbial 27:1053–1060.
Walker JD, Colwell RR, Petrakis. 1975. Bacterial degradation of motor oil. J Water Pollut Control Fed 47:2058–2066.1177351
Wallace GM. 1988. Polychlorinated-biphenyls and chlorine levels in fresh and used engine oils. Erdol and Kohle Erdgas Petrochemie 41(4):169–170.
Wang YY, Rappaport SM, Sawyer RF, . 1978. Direct-acting mutagens in automobile exhaust. Cancer Lett 5(1):39–47.80258
Ward DM, Brock TD. 1976. Environmental factors influencing the rate of hydrocarbon oxidation in temperature lakes. Appl Environ Microbial 31:764–772.
Wardley-Smith J. 1985. Discharge of automobile crank-case oil into the environment. Oil and Petrochemical Pollution 2(4):305–307.
*Warshawsky D, Barkley W, Bingham E. 1993. Factors affecting carcinogenic potential of mixtures. Fundam Appl Toxicol 20:376–382.8504912
*Weinstein NJ. 1974. Oil crunch spurs waste oil reclaiming. Chemical and Engineering News 25:25.
*Weinstein KD, Myers TD, Craft DR. 1982. Enhanced utilization of used lubricating oil recycling process by-products. Booz, Allen & Hamilton Inc. for U.S. Department of Energy, Washington, D.C. DOE/BC/10059-19 (DE82007671).
*Wheeler LA, Saperstein MD, Lowe NJ. 1981. Mutagenicity of urine from psoriatic patients undergoing treatment with coal tar and ultra-violet light. J Invest Dermatol 77:181–185.7276613
Whipple W, Hunter JV, Yu SL. 1974. Unrecorded pollution from urban runoff. J Water Poll Control Fed 46:873–885.
Willcock M, Tidmarsh D, Foss P. 1991. Exhaust hydrocarbon emissions during the running-in period of a spark ignited engine. In: Seminar for the Combustion Engines Group, Institution of Mechanical Engineers, December 11-12, 1991. London, England: Mechanical Engineering Publications Limited, 8:121–126.
*Williams DJ, Milne JW, Roberts DB, . 1989a. Particulate emissions from “in-use” motor vehicles. I. Spark ignition vehicles. Atmos Environ 23(12):2639–2645.
Williams PT, Bartle KD, Andrews GE. 1986. Polycyclic aromatic compounds in diesel fuels and particulates. In: Cooke M and Dennis AJ, ed. Polynuclear aromatic hydrocarbons: Chemistry, characterization and carcinogenesis. Ninth International Symposium. Columbus, Ohio: Battelle Press, 1011–1027.
*Williams UP, Kiceniuk JW, Fancey LL, . 1989b. Tainting and depuration of taint by lobsters (Homarus americanus) exposed to water contaminated with a no. 2 fuel oil: Relationship with aromatic hydrocarbon content in tissue. Journal of Food Science 54(2):240–243.
*Witschi HP, Smith LH, . 1987. Skin tumorigenic potential of crude and refined coal liquids and analogous petroleum products. Fundam Appl Toxicol 9:297–303.3653572
*Wolff MS, Taffe RR, Boesch RR, . 1982. Detection of polycyclic aromatic hydrocarbons in skin oil obtained from roofing workers. Chemosphere 11:337–347.
Wood GP. 1969. How crankcase oil additives function. J Inst Petrol 55:194–204.
*Woskie SR, Smith TJ, Hammond SK, . 1988. Estimation of the diesel exhaust exposures of railroad workers: I. Current Exposures. Am J Ind Med 13:381–394.3354586
Yagi H, Thakker DR, Hernandez O, . 1977. Synthesis and reactions of the highly mutagenic 7,8-diol-9,10-epoxides of the carcinogen benzo[a]pyrene. J Am Chem Sot 99:1604–1611.
Zack M, Cannon S, Loyd D, . 1980. Cancer in children of parents exposed to hydrocarbon-related industries and occupations. Am J Epidemiol 111:329–336.7361757
*Zieba J. 1985. Examination of lubricating oils by infrared spectroscopy. Forensic Sci Int 27(1):31–39.
Zweidinger RB. 1982. Emission factors from diesel and gasoline powered vehicles: Correlation with the Ames test. Developments in Toxicology and Environmental Science, Vol 10, Toxicological Effects of Emissions from Diesel Engines, 83–96.