# 7 REGULATIONS AND ADVISORIES

National and state regulations and guidelines pertinent to human exposure to used mineral-based crankcase oil are summarized in Table 7-1. No international regulations were found.

MRLs have not been derived. Reference dose (RfD) and reference concentration (RfC) data were not found for used mineral-based crankcase oil.

The information in the following table indicates that used crankcase oil regulations are still being revised and created. Few water quality standards were found for used mineral-based crankcase oil. This may be because few states recognize or define used mineral-based crankcase oil as a hazardous waste.

The primary state regulations listed in Table 7-1 are adaptations of the federal regulations. It is important to note that Colorado, the District of Columbia, and West Virginia have no or very few regulations for used mineral-based crankcase oil. Also, all states, with the exception of West Virginia, recognize road oiling and dust suppression as the primary route of environmental exposure and have enacted regulations to address this release. Further regulations are expected as the category of used mineral-based crankcase oil becomes more clearly defined.

TABLE 7-1 Regulations and Guidelines Applicable to Used Mineral-based Crankcase Oil

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | NS^a^ | IARC 1984
[underlined: NATIONAL]
Regulations:
a. Air:
EPA | Used oil burned for energy recovery is subject to regulation if the allowable levels of any of the following constituents are exceeded: | Yes | EPA 1992a (40 CFR 279.11); EPA 1992a (40 CFR 279 Subpart G)
EPA | Arsenic-maximum | 5 ppm
EPA | Cadmium-maximum | 2 ppm
EPA | Chromium-maximum | 10 ppm
EPA | Lead-maximum | 100 ppm
EPA | Flashpoint-maximum | 100°F
EPA | Total halogens-maximum | 4000 ppm
b. Water:
EPA | EPA water quality criteria for human health and aquatic life (mineral-based crankcase oils) | No | EPA 1989 (FR 45:79318)
EPA | Priority pollutant listing | No | EPA 1989 (FR 45:79318)
c. Other:
EPA | Disposal regulations for nonhazardous used oil | No | EPA 1990 (40 CFR 261.21); EPA 1992b (40 CFR 261.4)
EPA | Standard for used oil application in dust suppression and the disposal of used oil | Yes | EPA 1992a (40 CFR 279 Subpart I)
EPA | Standards for used oil collection centers and aggregation points | Yes | EPA 1992a (40 CFR 279 Subpart D)
EPA | Standards for used oil processors and re-refining including facility standards, rebuttable presumption, notification requirements, management requirements, tracking, operating standards and offsite shipment standards | Yes | EPA 1992a (40 CFR 279 Subpart F)
EPA | Standard for used oil transport and transfer facilities including restrictions on nonprocessing transporters, notification requirements under RCRA, storage, transport, and tracking | Yes | EPA 1992a (40 CFR 279 Subpart E)
EPA | Used oil regulated as a hazardous waste if it contains greater than 1,000 ppm total halogens and/or is mixed with a hazardous waste | Yes | EPA 1980a (40 CFR 261.33); EPA 1992a (40 CFR 279.10)
[underlined: STATE]
Regulations and Guidelines
a. Air: | Regulations on the burning and blending of used oil for the purpose of energy recovery (end-use regulation):
Alabama | | Yes^b^ | State of Alabama 1991
Alaska | | Yes^b^ | State of Alaska 1992
Arizona | | Yes | State of Arizona 1992
Arkansas | | Yes^b^ | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | No | State of Colorado 1992
Connecticut | | Yes^b^ | State of Connecticut 1991
Delaware | | Yes^b^ | State of Delaware 1992
Washington, DC | | No | District of Columbia 1992
Florida | | Yes^b^ | State of Florida 1992
Georgia | | Yes^b^ | State of Georgia 1992
Hawaii | | Yes^b^ | State of Hawaii 1992
Idaho | | Yes^b^ | State of Idaho 1992
Illinois | | Yes^b^ | State of Illinois 1992
Indiana | | Yes^b^ | State of Indiana 1992
Iowa | | Yes^b^ | State of Iowa 1992
Kansas | | Yes^b^ | State of Kansas 1992
Kentucky | | Yes^b^ | Commonwealth of Kentucky 1992
Louisiana | | Yes | State of Louisiana 1992
Maine | | Yes | State of Maine 1992
Maryland | | Yes^b^ | State of Maryland 1992
Massachusetts | | Yes | Commonwealth of Massachusetts 1992
Michigan | | Yes^b^ | State of Michigan 1992
Minnesota | | Yes^b^ | State of Minnesota 1992
Mississippi | | Yes^b^ | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | Yes | State of Montana 1992
Nebraska | | Yes^b^ | State of Nebraska 1992
Nevada | | Yes^b^ | State of Nevada 1992
New Hampshire | | Yes^b^ | State of New Hampshire 1992
New Jersey | | Yes | State of New Jersey 1992
New Mexico | | Yes^b^ | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | Yes^b^ | State of North Carolina 1992
North Dakota | | No | State of North Dakota 1992
Ohio | | Yes^b^ | State of Ohio 1992
Oklahoma | | Yes^b^ | Stale of Oklahoma 1991
Oregon | | Yes^b^ | State of Oregon 1992
Pennsylvania | | Yes^b^ | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes^b^ | State of Rhode Island 1992
South Carolina | | Yes^b^ | State of South Carolina 1992
South Dakota | | Yes^b^ | State of South Dakota 1992
Tennessee | | No | State of Tennessee 1992
Texas | | No | State of Texas 1992
Utah | | Yes^b^ | State of Utah 1992
Vermont | | Yes | State of Vermont 1992
Virginia | | Yes | Commonwealth of Virginia 1992
Washington | | Yes^b^ | State of Washington 1992
West Virginia | | No | State of West Virginia 1992
Wisconsin | | Yes^b^ | State of Wisconsin 1992
Wyoming | | No | State of Wyoming 1992
b. Other:
Connecticut | The use of reasonably available control technologies to limit the discharge of used oil (VOC) | Yes | CELDS 1993
Connecticut | Regulations affecting marketers, generators, storers, and disposers of used oil and used oil burned for energy recovery (recycling collection/storage):
Alabama | | Yes | State of Alabama 1991
Alaska | | Yes | State of Alaska 1992
Arizona | | No | State of Arizona 1992
Arkansas | | Yes | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | No | State of Colorado 1992
Connecticut | | Yes | State of Connecticut 1991
Delaware | | Yes | State of Delaware 1992
Washington, DC | | No | District of Columbia 1992
Florida | | Yes | State of Florida 1992
Georgia | | Yes | State of Georgia 1992
Hawaii | | No | State of Hawaii 1992
Idaho | | Yes | State of Idaho 1992
Illinois | | Yes | State of Illinois 1992
Indiana | | Yes | State of Indiana 1992
Iowa | | Yes | State of Iowa 1992
Kansas | | Yes | State of Kansas 1992
Kentucky | | Yes | Commonwealth of Kentucky 1992
Louisiana | | Yes | State of Louisiana 1992
Maine | | Yes | State of Maine 1992
Maryland | | Yes | State of Maryland 1992
Massachusetts | | Yes | Commonwealth of Massachusetts 1992
Michigan | | Yes | State of Michigan 1992
Minnesota | | Yes | State of Minnesota 1992
Mississippi | | Yes | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | Yes | State of Montana 1992
Nebraska | | Yes | State of Nebraska 1992
Nevada | | Yes | State of Nevada 1992
New Hampshire | | Yes | State of New Hampshire 1992
New Jersey | | Yes | State of New Jersey 1992
New Mexico | | Yes | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | Yes | State of North Carolina 1992
North Dakota | | No | State of North Dakota 1992
Ohio | | Yes | State of Ohio 1992
Oklahoma | | Yes | State of Oklahoma 1991
Oregon | | Yes | State of Oregon 1992
Pennsylvania | | Yes | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes | State of Rhode Island 1992
South Carolina | | Yes | State of South Carolina 1992
South Dakota | | Yes | State of South Dakota 1992
Tennessee | | No | State of Tennessee 1992
Texas | | Yes | State of Texas 1992
Utah | | Yes | State of Utah 1992
Vermont | | Yes | State of Vermont 1992
Virginia | | Yes | Commonwealth of Virginia 1992
Washington | | Yes | State of Washington 1992
West Virginia | | No | State of West Virginia 1992
Wisconsin | | Yes | State of Wisconsin 1992
Wyoming | | Yes | State of Wyoming 1992
| Labeling requirement regulations (recycling)
Alabama | | No | State of Alabama 1991
Alaska | | No | State of Alaska 1992
Arizona | | No | State of Arizona 1992
Arkansas | | No | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | No | State of Colorado 1992
Connecticut | | No | State of Connecticut 1991
Delaware | | No | State of Delaware 1992
Washington, DC | | No | District of Columbia 1992
Florida | | No | State of Florida 1992
Georgia | | No | State of Georgia 1992
Hawaii | | No | State of Hawaii 1992
Idaho | | Yes | State of Idaho 1992
Illinois | | No | State of Illinois 1992
Indiana | | Yes | State of Indiana 1992
Iowa | | No | State of Iowa 1992
Kansas | | No | State of Kansas 1992
Kentucky | | Yes (guideline) | Commonwealth of Kentucky 1992
Louisiana | | No | State of Louisiana 1992
Maine | | No | State of Maine 1992
Maryland | | Yes (guideline) | State of Maryland 1992
Massachusetts | | No | Commonwealth of Massachusetts 1992
Michigan | | No | State of Michigan 1992
Minnesota | | No | State of Minnesota 1992
Mississippi | | No | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | No | State of Montana 1992
Nebraska | | No | State of Nebraska 1992
Nevada | | No | State of Nevada 1992
New Hampshire | | Yes | State of New Hampshire 1992
New Jersey | | Yes (hazardous waste) | State of New Jersey 1992
New Mexico | | No | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | No | State of North Carolina 1992
North Dakota | | No | State of North Dakota 1992
Ohio | | No | State of Ohio 1992
Oklahoma | | No | State of Oklahoma 1991
Oregon | | No | State of Oregon 1992
Pennsylvania | | Yes | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes | State of Rhode Island 1992
South Carolina | | Yes | State of South Carolina 1992
South Dakota | | No | State of South Dakota 1992
Tennessee | | No | State of Tennessee 1992
Texas | | No | State of Texas 1992
Utah | | No | State of Utah 1992
Vermont | | No | State of Vermont 1992
Virginia | | No | Commonwealth of Virginia 1992
Washington | | No | State of Washington 1992
West Virginia | | No | State of West Virginia 1992
Wisconsin | | Yes | State of Wisconsin 1992
Wyoming | | Yes | State of Wyoming 1992
| Liability protection statute for collectors (recycling)
Alabama | | No^c^ | State of Alabama 1991
Alaska | | No^c^ | State of Alaska 1992
Arizona | | Yes | State of Arizona 1992
Arkansas | | No^c^ | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | No^c^ | State of Colorado 1992
Connecticut | | No^c^ | State of Connecticut 1991
Delaware | | Yes | State of Delaware 1992
Washington, DC | | No^c^ | District of Columbia 1992
Florida | | Yes | State of Florida 1992
Georgia | | No^c^ | State of Georgia 1992
Hawaii | | No^c^ | State of Hawaii 1992
Idaho | | No^c^ | State of Idaho 1992
Illinois | | No^c^ | State of Illinois 1992
Indiana | | No^c^ | State of Indiana 1992
Iowa | | No^c^ | State of Iowa 1992
Kansas | | No^c^ | State of Kansas 1992
Kentucky | | No^c^ | Commonwealth of Kentucky 1992
Louisiana | | Yes | State of Louisiana 1992
Maine | | No^c^ | State of Maine 1992
Maryland | | Yes (guideline) | State of Maryland 1992
Massachusetts | | No^c^ | Commonwealth of Massachusetts 1992
Michigan | | No^c^ | State of Michigan 1992
Minnesota | | No^c^ | State of Minnesota 1992
Mississippi | | Yes | State of Mississippi 1992
Missouri | | No^c^ | State of Missouri 1992
Montana | | No^c^ | State of Montana 1992
Nebraska | | No^c^ | State of Nebraska 1992
Nevada | | No^c^ | State of Nevada 1992
New Hampshire | | No^c^ | State of New Hampshire 1992
New Jersey | | No^c^ | State of New Jersey 1992
New Mexico | | No^c^ | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | No^c^ | State of North Carolina 1992
North Dakota | | No^c^ | State of North Dakota 1992
Ohio | | No^c^ | State of Ohio 1992
Oklahoma | | No^c^ | State of Oklahoma 1991
Oregon | | No^c^ | State of Oregon 1992
Pennsylvania | | Yes | Commonwealth of Pennsylvania 1992
Rhode Island | | No^c^ | State of Rhode Island 1992
South Carolina | | Yes | State of South Carolina 1992
South Dakota | | No^c^ | State of South Dakota 1992
Tennessee | | No^c^ | State of Tennessee 1992
Texas | | Yes | State of Texas 1992
Utah | | No^c^ | State of Utah 1992
Vermont | | No^c^ | State of Vermont 1992
Virginia | | No^c^ | Commonwealth of Virginia 1992
Washington | | Yes | State of Washington 1992
West Virginia | | No^c^ | State of West Virginia 1992
Wisconsin | | No^c^ | State of Wisconsin 1992
Wyoming | | No^c^ | State of Wyoming 1992
| Transportation requirements for used oil burned for energy recovery (recycling)
Alabama | | Yes | State of Alabama 1991
Alaska | | Yes | State of Alaska 1992
Arizona | | Yes | State of Arizona 1992
Arkansas | | Yes | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | No | State of Colorado 1992
Connecticut | | Yes | State of Connecticut 1991
Delaware | | Yes | State of Delaware 1992
Washington, DC | | No | District of Columbia 1992
Florida | | Yes | State of Florida 1992
Georgia | | Yes | State of Georgia 1992
Hawaii | | Yes | State of Hawaii 1992
Idaho | | Yes | State of Idaho 1992
Illinois | | Yes | State of Illinois 1992
Indiana | | Yes | State of Indiana 1992
Iowa | | No | State of Iowa 1992
Kansas | | Yes | State of Kansas 1992
Kentucky | | Yes | Commonwealth of Kentucky 1992
Louisiana | | Yes | State of Louisiana 1992
Maine | | Yes | State of Maine 1992
Maryland | | Yes | State of Maryland 1992
Massachusetts | | Yes | Commonwealth of Massachusetts 1992
Michigan | | Yes | State of Michigan 1992
Minnesota | | Yes | State of Minnesota 1992
Mississippi | | Yes | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | Yes | State of Montana 1992
Nebraska | | Yes | State of Nebraska 1992
Nevada | | Yes | State of Nevada 1992
New Hampshire | | Yes | State of New Hampshire 1992
New Jersey | | Yes | State of New Jersey 1992
New Mexico | | Yes | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | Yes | State of North Carolina 1992
North Dakota | | Yes | State of North Dakota 1992
Ohio | | Yes | State of Ohio 1992
Oklahoma | | Yes | State of Oklahoma 1991
Oregon | | Yes | State of Oregon 1992
Pennsylvania | | Yes | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes | State of Rhode Island 1992
South Carolina | | Yes | State of South Carolina 1992
South Dakota | | Yes | State of South Dakota 1992
Tennessee | | No | State of Tennessee 1992
Texas | | Yes | State of Texas 1992
Utah | | Yes | State of Utah 1992
Vermont | | Yes | State of Vermont 1992
Virginia | | Yes | Commonwealth of Virginia 1992
Washington | | Yes | State of Washington 1992
West Virginia | | No | State of West Virginia 1992
Wisconsin | | Yes | State of Wisconsin 1992
Wyoming | | Yes | State of Wyoming 1992
| Used oil landfill disposal regulations (disposal)
Alabama | | No | State of Alabama 1991
Alaska | | No | State of Alaska 1992
Arizona | | Yes | State of Arizona 1992
Arkansas | | No | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | Yes (liquid waste) | State of Colorado 1992
Connecticut | | Yes | State of Connecticut 1991
Delaware | | No | State of Delaware 1992
Washington, DC | | No | District of Columbia 1992
Florida | | Yes | State of Florida 1992
Georgia | | Yes | State of Georgia 1992
Hawaii | | Yes | State of Hawaii 1992
Idaho | | Yes | State of Idaho 1992
Illinois | | Yes | State of Illinois 1992
Indiana | | Yes | State of Indiana 1992
Iowa | | Yes | State of Iowa 1992
Kansas | | Yes | State of Kansas 1992
Kentucky | | Yes | Commonwealth of Kentucky 1992
Louisiana | | Yes | State of Louisiana 1992
Maine | | Yes | State of Maine 1992
Maryland | | Yes | State of Maryland 1992
Massachusetts | | Yes | Commonwealth of Massachusetts 1992
Michigan | | Yes | State of Michigan 1992
Minnesota | | Yes | State of Minnesota 1992
Mississippi | | Yes (liquid waste) | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | No | State of Montana 1992
Nebraska | | No | State of Nebraska 1992
Nevada | | Yes | State of Nevada 1992
New Hampshire | | Yes | State of New Hampshire 1992
New Jersey | | Yes | State of New Jersey 1992
New Mexico | | No | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | Yes | State of North Carolina 1992
North Dakota | | Yes | State of North Dakota 1992
Ohio | | No | State of Ohio 1992
Oklahoma | | No | State of Oklahoma 1991
Oregon | | Yes | State of Oregon 1992
Pennsylvania | | Yes | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes | State of Rhode Island 1992
South Carolina | | Yes | State of South Carolina 1992
South Dakota | | No | State of South Dakota 1992
Tennessee | | No | State of Tennessee 1992
Texas | | Yes | State of Texas 1992
Utah | | Yes | State of Utah 1992
Vermont | | Yes | State of Vermont 1992
Virginia | | Yes (free liquid) | Commonwealth of Virginia 1992
Washington | | Yes | State of Washington 1992
West Virginia | | Yes (free liquid) | State of West Virginia 1992
Wisconsin | | Yes | State of Wisconsin 1992
Wyoming | | Yes | State of Wyoming 1992
| Regulations on used oil as a dustsuppressant and as used for road oiling (disposal)
Alabama | | Yes | State of Alabama 1991
Alaska | | Yes | State of Alaska 1992
Arizona | | Yes | State of Arizona 1992
Arkansas | | Yes | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | Yes | State of Colorado 1992
Connecticut | | Yes | State of Connecticut 1991
Delaware | | Yes | State of Delaware 1992
Washington, DC | | Yes | District of Columbia 1992
Florida | | Yes | State of Florida 1992
Georgia | | Yes | State of Georgia 1992
Hawaii | | Yes | State of Hawaii 1992
Idaho | | Yes | State of Idaho 1992
Illinois | | Yes | State of Illinois 1992
Indiana | | Yes | State of Indiana 1992
Iowa | | Yes | State of Iowa 1992
Kansas | | Yes | State of Kansas 1992
Kentucky | | Yes | Commonwealth of Kentucky 1992
Louisiana | | Yes | State of Louisiana 1992
Maine | | Yes | State of Maine 1992
Maryland | | Yes | State of Maryland 1992
Massachusetts | | Yes | Commonwealth of Massachusetts 1992
Michigan | | Yes | State of Michigan 1992
Minnesota | | Yes | State of Minnesota 1992
Mississippi | | Yes | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | Yes | State of Montana 1992
Nebraska | | Yes | State of Nebraska 1992
Nevada | | Yes | State of Nevada 1992
New Hampshire | | Yes | State of New Hampshire 1992
New Jersey | | Yes | State of New Jersey 1992
New Mexico | | Yes | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | Yes | State of North Carolina 1992
North Dakota | | Yes | State of North Dakota 1992
Ohio | | Yes | State of Ohio 1992
Oklahoma | | Yes | State of Oklahoma 1991
Oregon | | Yes | State of Oregon 1992
Pennsylvania | | Yes | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes | State of Rhode Island 1992
South Carolina | | Yes | State of South Carolina 1992
South Dakota | | Yes | State of South Dakota 1992
Tennessee | | Yes | State of Tennessee 1992
Texas | | Yes | State of Texas 1992
Utah | | Yes | State of Utah 1992
Vermont | | Yes | State of Vermont 1992
Virginia | | Yes | Commonwealth of Virginia 1992
Washington | | Yes | State of Washington 1992
West Virginia | | No | State of West Virginia 1992
Wisconsin | | Yes | State of Wisconsin 1992
Wyoming | | Yes | State of Wyoming 1992
| Used oil classification as a hazardous waste by the state
Alabama | | No | State of Alabama 1991
Alaska | | No | State of Alaska 1992
Arizona | | No | State of Arizona 1992
Arkansas | | No | State of Arkansas 1992
California | | Yes^d^ | State of California 1992
Colorado | | No | State of Colorado 1992
Connecticut | | No | State of Connecticut 1991
Delaware | | No | State of Delaware 1992
Washington, DC | | No | District of Columbia 1992
Florida | | Yes^d^ | State of Florida 1992
Georgia | | No | State of Georgia 1992
Hawaii | | No | State of Hawaii 1992
Idaho | | No | State of Idaho 1992
Illinois | | Yes^d^ | State of Illinois 1992
Indiana | | No | State of Indiana 1992
Iowa | | No | State of Iowa 1992
Kansas | | No | State of Kansas 1992
Kentucky | | No | Commonwealth of Kentucky 1992
Louisiana | | No | State of Louisiana 1992
Maine | | No | State of Maine 1992
Maryland | | No | State of Maryland 1992
Massachusetts | | Yes | Commonwealth of Massachusetts 1992
Michigan | | No | State of Michigan 1992
Minnesota | | Yes (non-recycled) | State of Minnesota 1992
Mississippi | | No | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | No | State of Montana 1992
Nebraska | | No | State of Nebraska 1992
Nevada | | No | State of Nevada 1992
New Hampshire | | Yes | State of New Hampshire 1992
New Jersey | | Yes | State of New Jersey 1992
New Mexico | | No | State of New Mexico 1991
New York | | No | State of New York 1992
North Carolina | | No | State of North Carolina 1992
North Dakota | | No | State of North Dakota 1992
Ohio | | No | State of Ohio 1992
Oklahoma | | No | State of Oklahoma 1991
Oregon | | No | State of Oregon 1992
Pennsylvania | | No | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes | State of Rhode Island 1992
South Carolina | | No | State of South Carolina 1992
South Dakota | | No | State of South Dakota 1992
Tennessee | | No | State of Tennessee 1992
Texas | | No | State of Texas 1992
Utah | | No | State of Utah 1992
Vermont | | Yes | State of Vermont 1992
Virginia | | No | Commonwealth of Virginia 1992
Washington | | No | State of Washington 1992
West Virginia | | No | State of West Virginia 1992
Wisconsin | | No | State of Wisconsin 1992
Wyoming | | Yes | State of Wyoming 1992
| State regulation concerning the tracking of used oil (end-use regulation)
Alabama | | Yes | State of Alabama 1991
Alaska | | Yes | State of Alaska 1992
Arizona | | Yes | State of Arizona 1992
Arkansas | | Yes | State of Arkansas 1992
California | | Yes | State of California 1992
Colorado | | No | State of Colorado 1992
Connecticut | | Yes | State of Connecticut 1991
Delaware | | Yes | State of Delaware 1992
Washington, DC | | No | District of Columbia 1992
Florida | | Yes | State of Florida 1992
Georgia | | Yes | State of Georgia 1992
Hawaii | | Yes | State of Hawaii 1992
Idaho | | No | State of Idaho 1992
Illinois | | Yes | State of Illinois 1992
Indiana | | Yes | State of Indiana 1992
Iowa | | No | State of Iowa 1992
Kansas | | Yes | State of Kansas 1992
Kentucky | | Yes | Commonwealth of Kentucky 1992
Louisiana | | Yes | State of Louisiana 1992
Maine | | Yes | State of Maine 1992
Maryland | | Yes | State of Maryland 1992
Massachusetts | | Yes | Commonwealth of Massachusetts 1992
Michigan | | Yes | State of Michigan 1992
Minnesota | | Yes | State of Minnesota 1992
Mississippi | | Yes | State of Mississippi 1992
Missouri | | Yes | State of Missouri 1992
Montana | | Yes | State of Montana 1992
Nebraska | | Yes | State of Nebraska 1992
Nevada | | Yes | State of Nevada 1992
New Hampshire | | Yes | State of New Hampshire 1992
New Jersey | | Yes | State of New Jersey 1992
New Mexico | | Yes | State of New Mexico 1991
New York | | Yes | State of New York 1992
North Carolina | | Yes | State of North Carolina 1992
North Dakota | | No | State of North Dakota 1992
Ohio | | Yes | State of Ohio 1992
Oklahoma | | Yes | State of Oklahoma 1991
Oregon | | Yes | State of Oregon 1992
Pennsylvania | | Yes | Commonwealth of Pennsylvania 1992
Rhode Island | | Yes | State of Rhode Island 1992
South Carolina | | Yes | State of South Carolina 1992
South Dakota | | Yes | State of South Dakota 1992
Tennessee | | No | State of Tennessee 1992
Texas | | Yes | State of Texas 1992
Utah | | Yes | State of Utah 1992
Vermont | | Yes | State of Vermont 1992
Virginia | | Yes | Commonwealth of Virginia 1992
Washington | | Yes | State of Washington 1992
West Virginia | | No | State of West Virginia 1992
Wisconsin | | Yes | State of Wisconsin 1992
Wyoming | | No | State of Wyoming 1992

a There is sufficient evidence for the carcinogenicity of one sample of used gasoline-engine oil [class 7.2] and limited evidence for the carcinogenicity of some cutting oils [classes 7.1 and 7.2] to experimental animals. There is sufficient evidence from studies in humans that mineral oils (containing various additives and impurities) which have been used in occupations such a mulespinning, metal machining and jute processing are carcinogenic to humans.

b The state has adopted the Federal Regulation found in 40 CFR 266.30-266.44.

c The “No” indicates that the state does not specifically recognize used oil, so the liability regulations may or may not apply.

d Used crankcase oil is not a hazardous waste, but is regulated as a hazardous waste.

EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; NS = not specified; RCRA = ResourceConservation and Recovery Act; VOC = Volatile Organic Compound