# PEER REVIEW

A peer review panel was assembled for tungsten. The panel consisted of the following members:

1. Finis Cavender, Ph.D., DABT, CEI, Consultant in Toxicology, 310 Lightwood Knot Road, Greer, South Carolina 29651;
2. Richard Leggett, Ph.D., Life Sciences Division, Oak Ridge National Laboratory, 11401 Glen Iris Lane, Knoxville, Tennessee 37922-1744;
3. Robert Michaels, Ph.D., President, RAM TRAC Corporation, Toxicology & Risk Assessment Consulting, 3100 Rosendale Road, Schenectady, New York 12309; and
4. Raghubir Sharma, Ph.D., Fred C. Davison Distinguished Chair in Toxicology, Department of Physiology and Pharmacology, The University of Georgia, Athens, Georgia 30602.

These experts collectively have knowledge of tungsten’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.