# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding tungsten in air, water, and other media are summarized in Table 8-1.

No MRLs were derived for inhalation or oral exposure to tungsten or tungsten compounds.

EPA has not classified tungsten or tungsten compounds for carcinogenicity, nor has the EPA derived reference concentrations (RfCs) or reference doses (RfDs) for tungsten or tungsten compounds (IRIS 2005). EPA regulates the effluent discharge of tungsten at primary tungsten facilities (EPA 2005a) and tungsten or cobalt at secondary tungsten and cobalt facilities processing tungsten or tungsten carbide scrap raw materials (EPA 2005b).

The American Conference of Governmental Industrial Hygienists (ACGIH), National Institute of Occupational Safety and Health (NIOSH), and Occupational Safety and Health Administration (OSHA) regulate tungsten for occupational exposures.

Table 8-1 Regulations and Guidelines Applicable to Tungsten

Agency | Description | Information | | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data
WHO | Drinking water and air quality guidelines | No data
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air:
ACGIH | TLV (8-hour TWA) | | | ACGIH 2003
ACGIH | Tungsten (as W) | | | ACGIH 2003
ACGIH | Metal and insoluble compounds | 5 mg/m^3^ | | ACGIH 2003
ACGIH | STEL | 10 mg/m^3^ | | ACGIH 2003
ACGIH | Soluble compounds | 1 mg/m^3^ | | ACGIH 2003
ACGIH | STEL | 3 mg/m^3^ | | ACGIH 2003
NIOSH | REL (10-hour TWA) | | | NIOSH 2005
NIOSH | Tungsten (also applies to insoluble tungsten compounds [as W]) | 5 mg/m^3^ | | NIOSH 2005
NIOSH | STEL (15-minute TWA) | 10 mg/m^3^ | | NIOSH 2005
OSHA | PEL (8-hour TWA) for general industry | No data
OSHA | PEL (8-hour TWA) for construction industry | | | OSHA 2005b; 29 CFR 1926.55, Appendix A
OSHA | Tungsten (as W) | | | OSHA 2005b; 29 CFR 1926.55, Appendix A
OSHA | Insoluble compounds | 5 mg/m^3^ | | OSHA 2005b; 29 CFR 1926.55, Appendix A
OSHA | Soluble compounds | 1 mg/m^3^ | | OSHA 2005b; 29 CFR 1926.55, Appendix A
OSHA | PEL (8-hour TWA) for shipyard industry | | | OSHA 2005a; 29 CFR 1915.1000
OSHA | Tungsten | | | OSHA 2005a; 29 CFR 1915.1000
OSHA | Insoluble compounds | 5 mg/m^3^ | | OSHA 2005a; 29 CFR 1915.1000
OSHA | Soluble compounds | 1 mg/m^3^ | | OSHA 2005a; 29 CFR 1915.1000
USNRC | Occupational values | | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | Oral ingestion | [underlined: ALI (μCi)] ^a^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^176^W | 1.0×10^4^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^177^W | 2.0×10^4^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^178^W | 5.0×10^3^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^179^W | 5.0×10^5^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^181^W | 2.0×10^4^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^185^W (LLI wall) | 2.0×10^3^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^185^W | 3.0×10^3^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^187^W | 2.0×10^3^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^188^W (LLI wall) | 4.0×10^2^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^188^W | 5.0×10^2^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | Inhalation^b^ | [underlined: ALI (μCi)] ^a^ | [underlined: DAC (μCi/mL)] ^c^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^176^W | 5.0×10^4^ | 2.0×10^−5^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^177^W | 9.0×10^4^ | 4.0×10^−5^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^178^W | 2.0×10^4^ | 8.0×10^−6^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^179^W | 2.0×10^6^ | 7.0×10^−4^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^181^W | 3.0×10^4^ | 1.0×10^−5^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^185^W (LLI wall) | 7.0×10^3^ | 3.0×10^−6^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^187^W | 9.0×10^3^ | 4.0×10^−6^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^188^W (LLI wall) | 1.0×10^3^ | 5.0×10^−7^ | USNRC 2005; 10 CFR 20, Appendix B
b. Water | No data
c. Food | No data
d. Other
ACGIH | Carcinogenicity classification | No data | | ACGIH 2003
EPA | Carcinogenicity classification | No data | | IRIS 2005
EPA | RfC | No data
EPA | RfD | No data
EPA | Effluent guidelines and standards; nonferrous metals manufacturing point source category applicable to discharges resulting from the production of tungsten at primary tungsten facilities | Yes | | EPA 2005a; 40 CFR 421.100
EPA | Effluent guidelines and standards; nonferrous metals manufacturing point source category applicable to discharges resulting from the production of tungsten or cobalt at secondary tungsten and cobalt facilities processing tungsten or tungsten carbide scrap raw materials | Yes | | EPA 2005b; 40 CFR 421.310
USNRC | Effluent concentrations^d^ | [underlined: Air (μCi/mL)] ^e^ | [underlined: Water (μCi/mL)] ^f^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^176^W | 7.0×10^−8^ | 1.0×10^−4^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^177^W | 1.0×10^−7^ | 3.0×10^−4^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^178^W | 3.0×10^−8^ | 7.0×10^−5^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^179^W | 2.0×10^−6^ | 7.0×10^−3^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^181^W | 5.0×10^−8^ | 2.0×10^−4^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^185^W (LLI wall) | 9.0×10^−9^ | No data | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^185^W | No data | 4.0×10^−5^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^187^W | 1.0×10^−8^ | 3.0×10^−5^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^188^W (LLI wall) | 2.0×10^−9^ | No data | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^188^W | No data | 7.0×10^−6^ | USNRC 2005; 10 CFR 20, Appendix B
USNRC | Release to sewers^g^ | [underlined: Monthly average concentration (μCi/mL)] | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^176^W | 1.0×10^−3^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^177^W | 3.0×10^−3^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^178^W | 7.0×10^−4^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^179^W | 7.0×10^−2^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^181^W | 2.0×10^−3^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^185^W | 4.0×10^−4^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^187^W | 3.0×10^−4^ | | USNRC 2005; 10 CFR 20, Appendix B
USNRC | ^188^W | 7.0×10^−5^ | | USNRC 2005; 10 CFR 20, Appendix B
[underlined: STATE]
a. Air | No data
b. Water | No data
c. Food | No data
d. Other | No data

a The ALIs in this table are the annual intakes of a given radionuclide by “Reference Man”, which would result in either (1) a committed effective dose equivalent of 5 rems (stochastic ALI) or (2) a committed dose equivalent of 50 rems to an organ or tissue (non-stochastic ALI). The stochastic ALIs were derived to result in a risk, due to irradiation of organs and tissues, comparable to the risk associated with deep dose equivalent to the whole body of 5 rems. The derivation includes multiplying the committed dose equivalent to an organ or tissue by a weighting factor, w_T_. This weighting factor is the proportion of the risk of stochastic effects resulting from irradiation of the organ or tissue, T, to the total risk of stochastic effects when the whole body is irradiated uniformly. The non-stochastic ALIs were derived to avoid non-stochastic effects, such as prompt damage to tissue or reduction in organ function.

b The ALIs and DACs for inhalation are given for an aerosol with an activity median aerodynamic diameter (AMAD) of 1 µm and for class D of radioactive material, which refers to their retention (clearance half-times of <10 days) in the pulmonary region of the lung.

c The DAC values are derived limits intended to control chronic occupational exposures. The relationship between the DAC and the ALI is given by: DAC=ALI(in µCi)/(2,000 hours per working year × 60 minutes/hour × 2×10^4^ mL per minute)=[ALI/2.4×10^9^] µCi/mL, where 2x10^4^ mL is the volume of air breathed per minute at work by “Reference Man” under working conditions of “light work.” The DAC values relate to one of two modes of exposure: either external submersion or the internal committed dose equivalents resulting from inhalation of radioactive materials. Derived air concentrations based upon submersion are for immersion in a semi-infinite cloud of uniform concentration and apply to each radionuclide separately.

d Applicable to the assessment and control of dose to the public. The concentration values given are equivalent to the radionuclide concentrations that, if inhaled or ingested continuously over the course of a year, would produce a total effective dose equivalent of 0.05 rem (50 millirem or 0.5 millisievert).

e The air concentration values were derived by one of two methods. For those radionuclides for which the stochastic limit is governing, the occupational stochastic inhalation ALI was divided by 2.4x10^9^mL, relating the inhalation ALI to the DAC, as explained above, and then divided by a factor of 300. The factor of 300 includes the following components: a factor of 50 to relate the 5-rem annual occupational dose limit to the 0.1-rem limit for members of the public, a factor of 3 to adjust for the difference in exposure time and the inhalation rate for a worker and that for members of the public, and a factor of 2 to adjust the occupational values (derived for adults) so that they are applicable to other age groups. For those radionuclides for which submersion (external dose) is limiting, the occupational DAC in Table 1, Column 3 of USNRC (2005), was divided by 219. The factor of 219 is composed of a factor of 50, as described above, and a factor of 4.38 relating occupational exposure for 2,000 hours per year to full-time exposure (8,760 hours/year). Note that an additional factor of 2 for age considerations is not warranted in the submersion case.

f The water concentrations were derived by taking the most restrictive occupational stochastic oral ingestion ALI and dividing by 7.3x10^7^. The factor of 7.3x10^7^ (mL) includes the following components: the factors of 50 and 2 described above and a factor of 7.3x10^5^ (mL), which is the annual water intake of “Reference Man.”

g The monthly average concentrations for release to sanitary sewers are applicable to the provisions in § 20.2003. The concentration values were derived by taking the most restrictive occupational stochastic oral ingestion ALI and dividing by 7.3x10^6^(mL). The factor of 7.3x10^6^(mL) is composed of a factor of 7.3x10^5^(mL), the annual water intake by “Reference Man,” and a factor of 10, such that the concentrations, if the sewage released by the licensee were the only source of water ingested by a reference man during a year, would result in a committed effective dose equivalent of 0.5 rem.

ACGIH = American Conference of Governmental Industrial Hygienists; ALI = annual limits on intakes; CFR = Code of Federal Regulations; DAC = derived air concentrations; EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; LLI = lower large intestine; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TLV = threshold limit values; TWA = time-weighted average; USNRC = U.S. Nuclear Regulatory Commission; WHO = World Health Organization