# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Tungsten is a naturally occurring element found in the earth=s surface rocks. Tungsten metal typically does not occur as the free element in nature. Of the more than 20 tungsten-bearing minerals, some of the commonly used commercial ones include feberite (iron tungstate), huebnerite (manganese tungstate), wolframite (iron-manganese tungstate), and scheelite (calcium tungstate). Tungsten appears in Group VIB of the periodic table. Natural tungsten is composed of five stable isotopes: ^180^W (0.12%), ^182^W (26.5%), ^183^W (14.3%), ^184^W (30.6%), and ^186^W (28.4%). Twenty-eight radioactive isotopes of tungsten are known; most of these isotopes have short half-lives. Tungsten forms a variety of different compounds, such as tungsten trioxide, tungsten carbide, and ammonium paratungstate (Penrice 1997a). Information regarding the chemical identity of elemental tungsten and tungsten compounds is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Tungsten has several common oxidation states (e.g., W[0], W[2+], W[3+], W[4+], W[5+], and W[6+]). However, tungsten alone has not been observed as a cation. Tungsten is stable, and therefore its most common valence state is +6. The naturally occurring isotopes of tungsten are 180 (0.135%), 182 (26.4%), 183 (14.4%), 184 (30.6%), and 186 (28.4%). Artificial radioactive isotopes of tungsten are 173–179, 181, 185, and 187–189 (O’Neil et al. 2001). Elemental tungsten metal is stable in dry air at room temperature. Above 400 °C, tungsten is susceptible to oxidation. Tungsten is resistant to many chemicals and is also a good electrical conductor (Penrice 1997a). Information regarding the physical and chemical properties of elemental tungsten is located in Table 4-2.

Tungsten compounds differ widely in stereochemistry and oxidation states. Tungsten forms binary halide compounds for all oxidation states between +2 and +6. Oxyhalide compounds are only known for oxidation states +5 and +6. In general, tungsten halogen compounds are reactive toward water and oxygen in air. These compounds are all solid, colored compounds at room temperature, except the fluorides, and many decompose on heating before melting. Tungsten oxides form a series of well-defined ordered phases to which precise stoichiometric formulas can be assigned. The composition of the tungsten oxide may also vary over a fixed range without change in crystalline structure (Penrice 1997b). A unique characteristic of tungsten is its ability to form condensed complex ions of polytungstates in acid solution (e.g., ammonium paratungstate, [NH_4_]_10_[H_2_W_12_O_42_]·4H_2_O). The tungstate anion (WO_4_^2-^) exists in monomeric form only in strongly alkaline solutions. In mildly alkaline solution, the tungstate anions begin to polymerize, and this progresses with decreasing pH (Lassner et al. 1996). Tungstate complexes (WO_4_^2-^) of the alkali metals and magnesium are soluble in water. Tungsten forms hard, refractory, and chemically stable interstitial compounds with nonmetals, particularly carbon, nitrogen, boron, and silicon (Penrice 1997b). Information regarding the physical and chemical properties of tungsten compounds is located in Table 4-2.

Table 4-1 Chemical Identity of Tungsten and Tungsten Compounds^a^

Characteristic | Tungsten | Tungsten oxide | Tungsten trioxide
Synonyms | Wolfram; VA (tungsten) | Tungsten oxide; tungsten dioxide | Tungsten blue; tungsten oxide (WO_3_); tungsten trioxide; tungsten(VI) oxide; tungstic acid; tungstic acid anhydride; tungstic anhydride; tungstic oxide; wolframic acid, anhydride
Registered trade name(s) | Tungsten; Wolfram | No data | No data
Chemical formula | W | O_2_W | O_3_W
Chemical structure | W | [image] | [image]
Identification numbers:
CAS registry | 7440-33-7 | 12036-22-5 | 1314-35-8
NIOSH RTECS | YO7175000 | No data | Y07760000
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | 5036 | No data | 5800
NCI | No data | No data | 77901

Characteristic | Tungsten carbide | Ditungsten carbide | Tungsten carbonyl
Synonyms | Tungsten carbide; tungsten monocarbide | Tungsten carbide | Hexacarbonyltungsten; tungsten carbonyl; tungsten hexacarbonyl
Registered trade name(s) | Tungsten carbide | No data | No data
Chemical formula | CW | CW_2_ | C_6_O_6_W
Chemical structure | WC | W_2_C | [image]
Identification numbers:
CAS registry | 12070-12-1; 11130-73-7 | 12070-13-2 | 14040-11-0
NIOSH RTECS | YO7250000 | No data | YO7705000
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | 2932 | No data | No data
NCI | 61198 | No data | No data

Characteristic | Tungsten chloride | Sodium tungstate, dihydride | Sodium phosphotungstate
Synonyms | Hexa-chlorotungsten; tungsten hexachloride; wolfram hexachloride | Disodium tetraoxatungstate (2-), dihydrate; tetraoxo-tungstate (2-); disodium tungstate, dihydrate; sodium tungsten oxide, dihydrate; sodium wolframate, dihydrate; tungstic acid, disodium salt, dihydrate | Sodium tungstophosphate; tungstophosphoric acid, sodium salt; sodium-12-tungstophosphate
Registered trade name(s) | No data | No data | No data
Chemical formula | CI_6_W | O_4_ NaW_2_ • 2H_2_O (dihydrate) | ca. 2Na_2_OP_2_O_5_ • 12WO_3_ • 18H_2_O
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 13283-01-7 | 10213-10-2 (dihydride); 13472-45-2 (anhydrous) | 51312-42-6
NIOSH RTECS | Y07710000 | YO7900000; YO7875000 | TH5775000
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/ IMCO shipping | No data | No data | No data
HSDB | No data | No data | No data
NCI | No data | No data | No data

Characteristic | Ammonium paratungstate | Tungstate hexafluoride
Synonyms | APT | Tungsten hexafluoride; tungsten fluoride
Registered trade name(s) | No data | No data
Chemical formula | H_24_N_6_O_24_W_7_ | F_6_W
Chemical structure | (NH_4_)_6_W_7_O_24_ | [image]
Identification numbers:
CAS registry | 12028-06-7 (anhydrous); 12208-54-7 (hexahydrate) | 7783-82-6
NIOSH RTECS | No data; BS0480000 | YO7720000
EPA hazardous waste | No data | No data
OHM/TADS | No data | No data
DOT/UN/NA/IMCO shipping | No data | UN 2196
HSDB | No data | No data
NCI | No data | No data

a Sources: Chemfinder 2004; ChemID 2004; HSDB 2004; NIOSH 1990; RTECS 2004

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Tungsten and Tungsten Compounds^a^

Property | Tungsten | Tungsten oxide | Tungsten trioxide
Molecular weight | 183.85 | 215.84^b^ | 231.85
Color | Steel-gray to tin-white | Blue^b^ | Canary yellow; dark orange when heated^c^
Physical state | Solid metal | Solid^b^ | Solid
Melting point | 3,410 °C | 1,500–1,700 °C (decomposes) | 1,472 °C
Boiling point | 5,900 °C at 760 mm Hg | Not applicable | No data
Density (g/cm^3^) | 18.7–19.3 at 20 °C/4 °C | 10.82 (theoretical) | 7.2
Odor | No data | No data | No data
Odor threshold:
Water (mL/g) | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | No data | Insoluble^b^ | Insoluble
Other solvent(s) | Soluble in mixture of nitric acid and hydrofluoric acid | Insoluble in organic solvents^b^ | Caustic alkalies; very slightly soluble in acids; slightly soluble in hydrofluoric acid
Partition coefficients:
K_d_ (mL/g) | Not applicable | Not applicable | Not applicable
K_ow_ | Not applicable | Not applicable | Not applicable
K_oc_ | Not applicable | Not applicable | Not applicable
Vapor pressure | 1.97×10^−7^ mm Hg at 2,327 °C | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | Not applicable | Not applicable | Not applicable
Flashpoint | Not applicable | Not applicable | Not applicable
Flammability limits | Not applicable | Not applicable | Not applicable
Conversion factor | Not applicable | Not applicable | Not applicable
Explosive limits | Not applicable | Not applicable | Not applicable

Property | Tungsten carbide | Ditungsten carbide | Tungsten carbonyl
Molecular weight | 195.85 | 379.69^b^ | 351.90^b^
Color | Gray | No data | White^b^
Physical state | Solid | Solid^b^ | Solid^b^
Melting point | 2,785 °C | ~2,800 °C^b^ | 170 °C (decomposes)^b^
Boiling point | 6,000 °C | No data^b^ | Sublimes in vacuo^b,d^
Density (g/cm_3_) | 15.6 | 14.8^b^ | 2.65^b^
Odor | No data | No data | No data
Odor threshold:
Water (mL/g) | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | Insoluble | Insoluble^b^ | Insoluble^b^
Other solvent(s) | Soluble in nitric acid/hydrogen fluoride; aqua regia | No data | Soluble in organic solvents^b^
Partition coefficients:
K_d_ (mL/g) | Not applicable | Not applicable | No data
K_ow_ | Not applicable | Not applicable | No data
K_oc_ | Not applicable | Not applicable | No data
Vapor pressure | 7.5×10^−3^ mm Hg at 3,204 °C^b^ | No data | 0.1 mm Hg at 20 °C^c^; 1.20 mm Hg at 67 °C^c^
Henry’s law constant | No data | No data | No data
Autoignition temperature | Not applicable | Not applicable | No data
Flashpoint | Not applicable | Not applicable | No data
Flammability limits | Not applicable | Not applicable | No data
Conversion factor | Not applicable | Not applicable | No data
Explosive limits | Not applicable | Not applicable | No data

Property | Tungsten chloride | Sodium tungstate, dihydrate | Sodium phosphotungstate
Molecular weight | 396.56^b^ | 329.85^b^ | No data
Color | Purple^b^ | White^b^; colorless^e^ | White^c^
Physical state | Solid^b^ | Solid^b^ | Solid^d^
Melting point | 275 °C | Decomposes at 100 °C with loss of water^d^ and then melts at 692 °C^f^ | No data
Boiling point | 346.75 °C | Not applicable | No data
Density (g/cm^3^) | 3.52 | 3.25^b^ | No data
Odor | No data | Odorless | Odorless
Odor threshold:
Water (mL/g) | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | Decomposes^d^ | Very soluble^b^; about 1.1 parts water (ca. 1×10^6^ mg/L)^c^ | Very soluble^e^
Other solvent(s) | Soluble in ethanol, organic solvents^b^, lingroin^e^ | Insoluble in alcohol and acids^e^ | Very soluble in alcohols^e^
Partition coefficients:
K_d_ (mL/g) | No data | No data | No data
K_ow_ | No data | No data | No data
K_oc_ | No data | No data | No data
Vapor pressure | 43 mm Hg at 215 °C^e^ | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | Not applicable | No data
Flashpoint | No data | Not applicable | No data
Flammability limits | No data | Not applicable | No data
Conversion factor | No data | Not applicable | No data
Explosive limits | No data | Not applicable | No data

Property | Ammonium paratungstate | Tungstate hexafluoride
Molecular weight | 1779.16^f^ | 297.83^b^
Color | White^e^ | Colorless^b^; Pale yellow (liquid)^c^
Physical state | Solid^e^ | Gas at room temperature^b^
Melting point | No data | 2.3 °C^b^
Boiling point | No data | 17 °C^b^
Density (g/cm^3^) | No data | 12.173^b^
Odor | No data | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water | Soluble^e^ | Reacts with water^b^
Other solvent(s) | Insoluble in alcohol^e^ | Dissolves in benzene, cyclohexane, or dioxane; soluble in anhydrous hydrogen fluoride^e^
Partition coefficients:
K_d_ (mL/g) | No data | No data
K_ow_ | No data | No data
K_oc_ | No data | No data
Vapor pressure (mm Hg) | No data | Gas at room temperature^b^
Henry’s law constant | No data | No data
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factor | No data | No data
Explosive limits | No data | No data

a Information obtained from HSDB 2004, except where noted.

b Lide 2000

c O’Neil et al. 2001

d Penrice 1997b

e Lewis 1997

f Ashford 1994