# CHAPTER 8 REFERENCES

Alpert JR. 1982. Acute toxicity studies with 1,2,3-trichloropropane. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515726.
Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Int J Chem Kinet 19(9):799–828. 10.1002/kin.550190903.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634. https://www.loc.gov/item/fr054174/. July 27, 2020.
ATSDR. 1992. Toxicological profile for 1,2,3-trichloropropane. Agency for Toxic Substances and Disease Registry. PB93110872AS.
ATSDR. 2019. 1,2,3-Trichloropropane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Baier JH, Benjamin WL, Fronk CA, 1987. Using reverse osmosis to remove agricultural chemicals from groundwater. J Am Water Works Assoc 79(8):55–60. 10.1002/j.1551-8833.1987.tb02894.x.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Brender JD, Shinde MU, Zhan FB, 2014. Maternal residential proximity to chlorinated solvent emissions and birth defects in offspring: a case-control study. Environ Health 13:96. 10.1186/1476-069X-13-96.25406847
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
California Water Boards. 2017. Groundwater information sheet: 1,2,3-trichloropropane (TCP). California State Water Resources Control Board. https://www.waterboards.ca.gov/gama/docs/coc_tcp123.pdf. December 18, 2020.
Chroust K, Pavlova M, Prokop Z, 2007. Quantitative structure-activity relationships for toxicity and genotoxicity of halogenated aliphatic compounds: wing spot test of Drosophila melanogaster. Chemosphere 67(1):152–159. 10.1016/j.chemosphere.2006.09.020.17113125
Clark DG. 1977. Acute toxicity, skin and eye irritancy and skin sensitizing potential of 1,2,3trichloropropane. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515731. 86-870001655. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0515731.xhtml. May 19, 2020.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cohen SZ, Eiden C, Lorber MN. 1986. Monitoring ground water for pesticides. ACS Symp Ser 315:170–196. 10.1021/bk-1986-0315.ch010.
Cohen SZ, Eiden C, Lorber MN. 1987. Monitoring ground water for pesticides in the U.S.A. Schriftenr Ver Wasser Boden Lufthyg 68:265–295.3589541
Crebelli R, Carere A, Leopardi P, 1999. Evaluation of 10 aliphatic halogenated hydrocarbons in the mouse bone marrow micronucleus test. Mutagenesis 14(2):207–215. 10.1093/mutage/14.2.207.10229923
DeWalle FB, Chian ESK. 1978. Presence of trace organics in the Delaware River and their discharge by municipal and industrial sources. Proc Ind Waste Conf 32:908–919.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloro methanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11(4):405–409. 10.1021/es60127a009.
Dix KM. 1979. Toxicity of fine chemicals: Preliminary studies for the detection of testicular changes in rats. Shell Oil Company. Submitted to the U.S. Environmental Agency under TSCA Section 8D. OTS0510352. 878216424. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0510352.xhtml. May 19, 2020.
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
DOI. 1977. Coal mine combustion products: Ingredients of conveyor belts. Bureau of mines report of investigations. U.S. Department of the Interior. PB271240. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB271240.xhtml. May 19, 2020.
Drew RT, Patel JM, Lin FN. 1978. Changes in serum enzymes in rats after inhalation of organic solvents singly and in combination. Toxicol Appl Pharmacol 45(3):809–819. 10.1016/0041-008x(78)90172-2.214898
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
Ellerstein SM, Bertozzi ER. 1982. Polysulfides. In: Kirk-Othmer encyclopedia of chemical technology. 3^rd^ ed. New York, NY: John Wiley and Sons, 814–815.
EPA. 1984. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates. Vol. 2. Computer-printed tabulations of compound identification results for large volume concentrates. Columbus, OH: U.S. Environmental Protection Agency. PB85128239. EPA600184020B. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100C266.txt. May 19, 2020.
EPA. 1985a. Exposure analysis modeling system: Reference manual for EXAMS II. Athens, GA: U.S. Environmental Protection Agency. PB85228138. EPA600385038. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB85228138.xhtml. May 19, 2020.
EPA. 1985b. Removal of agricultural contaminants from ground water. Washington, DC: U.S. Environmental Protection Agency. EPA600D85136.
EPA. 1986a. Method for the determination of organic compounds in finished drinking water and raw source water. Method Nos. 502.1, 524.1 and 524.2. Cincinnati, OH: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=940034LY.txt. May 19, 2020.
EPA. 1986b. Test method for evaluating solid waste, physical/chemical methods, SW-846, Methods Nos. 5030 and 8010. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1987. Health and environmental effects document for trichloropropanes. Cincinnati, OH: U.S. Environmental Protection Agency. ECAOCIN010. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100RGHE.txt. July 27, 2020.
EPA. 1988a. List of halogenated organic compounds regulated under 268.32. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268 Appendix III. https://www.govinfo.gov/content/pkg/CFR-2013-title40-vol28/pdf/CFR-2013-title40-vol28-part268-appIII.pdf. May 19, 2020.
EPA. 1988b. Measurement of hydrolysis rate constants for evaluation of hazardous waste land disposal: Volume 3. Data on 70 chemicals. Washington, DC: U.S. Environmental Protection Agency. PB88234042AS. EPA600S388028. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TILE.txt. July 27, 2020.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F. https://www.epa.gov/sites/production/files/2014-11/documents/rfc_methodology.pdf. May 19, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009a. Toxicological review of 1,2,3-trichloropropane in support of summary information on the Integrated Risk Information System (IRIS). Washington, DC: U.S. Environmental Protection Agency. EPA635R08010F. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0200tr.pdf. August 31, 2017.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
FDA. 2020. Substances Added to Food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Gangal SV. 1980. Fluorinated ethylene-propylene copolymers. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 11. 3^rd^ ed. New York, NY: John Wiley and Sons, 24–25.
Gushow TS, Quast JF. 1984. 1,2,3-Trichloropropane: Acute inhalation toxicity evaluation in male rats and mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510175. 868600023. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0510175.xhtml. May 19, 2020.
Han H. 2010. Acute 1,2,3-trichloropane poisoning: a case report and literature review. Basic Clin Pharmacol Toxicol 107(6):988–990. 10.1111/j.1742-7843.2010.00624.x.20825388
Hawley GG. 1981. 1,2,3-Trichloropropane. In: Hawley’s condensed chemical dictionary. 10^th^ ed. New York, NY: Van Nostrand Reinhold Co., 1043.
Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):1–142. 10.1002/em.2860050703.
Heikes DL, Jensen SR, Fleming-Jones ME. 1995. Purge and trap extraction with GC-MS determination of volatile organic compounds in table-ready foods. J Agric Food Chem 43:2869–2875. 10.1021/jf00059a018.
Ho JS. 1989. A sequential analysis for volatile organics in water by purge-and-trap capillary column gas chromatography with photoionization and electrolytic conductivity detectors in series. J Chromatogr Sci 27(2):91–98. 10.1093/chromsci/27.2.91.
IARC. 1995. 1,2,3-Trichloropropane. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 63. Dry cleaning, some chlorinated solvents and other industrial chemicals. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/81. May 18, 2020.
IRIS. 2009. 1,2,3-Trichloropropane; CASRN 96-18-4. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0200_summary.pdf. June 15, 2017.
Ivanetich KM, Lucas S, Marsh JA, 1978. Organic compounds. Their interaction with and degradation of hepatic microsomal drug-metabolizing enzymes in vitro. Drug Metab Dispos 6(3):218–225.26540
Jensen S, Lange R, Berge G, 1975. On the chemistry of EDC-tar and its biological significance in the sea. Proc R Soc Edinb [Biol] 189(1096):333–343. 10.1098/rspb.1975.0060.
Johannsen FR, Levinskas GJ, Rusch GM, 1988. Evaluation of the subchronic and reproductive effects of a series of chlorinated propanes in the rat. I. Toxicity of 1,2,3-trichloropropane. J Toxicol Environ Health 25(3):299–315. 10.1080/15287398809531211.3184199
Kawasaki M. 1980. Experiences with the test scheme under the chemical control law of Japan: an approach to structure-activity correlations. Ecotoxicol Environ Saf 4(4):444–454. 10.1016/0147-6513(80)90046-9.7472248
Keith LH, Garrison AW, Allen FR, 1976. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Press, 329–373.
Kimura M, Mizukami S, Watanabe Y, 2016. Disruption of spindle checkpoint function in rats following 28 days of repeated administration of renal carcinogens. J Toxicol Sci 41(1):91–104. 10.2131/jts.41.91.26763396
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554. 10.1248/jhs.48.545.
Lag M, Omichinski JG, Dybing E, 1994. Mutagenic activity of halogenated propanes and propenes: effect of bromine and chlorine positioning. Chem Biol Interact 93(1):73–84. 10.1016/0009-2797(94)90087-6.8069951
Lewis RJ. 2007. 1,2,3-Trichloropropane. In: Hawley’s condensed chemical dictionary. 15^th^ ed. New York, NY: John Wiley & Sons, Inc., 1268.
Lopez-Avila V, Heath N, Hu A. 1987. Determination of purgeable halocarbons and aromatics by photoionization and hall electrolytic conductivity detectors connected in series. J Chromatogr Sci 25(8):356–363. 10.1093/chromsci/25.8.356.
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. 1,2,3-Trichloropropane. In: Handbook of chemical property estimation methods. Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Co., 4–9, 5–5, 15–19 to 15–31.
Mackay D, Bobra A, Chan DW, 1982. Vapor-pressure correlations for low-volatility environmental chemicals. Environ Sci Technol 16(10):645–649. 10.1021/es00104a004.
Mahmood NA, Overstreet D, Burka LT. 1991. Comparative disposition and metabolism of 1,2,3-trichloropropane in rats and mice. Drug Metab Dispos 19(2):411–418.1676646
McNeill WC. 1979. Trichloroethylene. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 5. 3^rd^ ed. New York, NY: John Wiley and Sons, 745.
McOmie WA, Barnes TR. 1949. Acute and subacute toxicity of 1,2,3-trichloropropane in mice and rabbits. Fed Proc 8:319.
Merrick BA, Robinson M, Condie LW. 1991. Cardiopathic effect of 1,2,3-trichloropropane after subacute and subchronic exposure in rats. J Appl Toxicol 11(3):179–187. 10.1002/jat.2550110305.1918791
Mersch-Sundermann V, Schneider U, Klopman G, 1994. SOS induction in Escherichia coli and Salmonella mutagenicity: a comparison using 330 compounds. Mutagenesis 9(3):205–224. 10.1093/mutage/9.3.205 7934961
Mi T, Han C, Wang Y, 2013. Acute toxic leukoencephalopathy in migrant workers exposed to organic solvents in construction materials. Occup Environ Med 70(6):435–436. 10.1136/oemed-2012-101302.23390197
Miller RR, Quast JF, Gushow TS. 1986a. 1,2,3-Trichloropropane: 2-Week vapor inhalation study in rats and mice. Dow Chemical Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517050. 85870002250. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0517050.xhtml. May 19, 2020.
Miller RR, Quast JF, Momany-Pfruender JJ. 1986b. 1,2,3-Trichloropropane: 2-Week vapor inhalation study to determine the no-adverse-effect level in rats and mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517055. 86870002265. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0517055.xhtml. May 19, 2020.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
NIOSH. 1981. Trichloropropanes. Report 4. Cincinnati, OH: National Institute for Occupational Safety and Health. PB83112870. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB83112870.xhtml. May 19, 2020.
NIOSH. 1987. Manual of analytical methods. Cincinnati, OH: National Institute for Occupational Safety and Health. PB88204722.
NIOSH. 1994. 1,2,3-Trichloropropane. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/96184.html. May 18, 2020.
NIOSH. 2019. 1,2,3-Trichloropropane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0631.html. May 18, 2020.
NLM. 2020. Pubchem: 1,2,3-Trichloropropane. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7285. May 20, 2020.
NTP. 1990. 1,2,3-Trichloropropane reproduction and fertility assessment in Swiss CD-1 mice when administered via gavage. Final report. National Toxicology Program. PB129676. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB91129676.xhtml. May 19, 2020.
NTP. 1993. Toxicology and carcinogenesis of 1,2,3-trichloropropane (CAS No. 96-18-4) in F344/N rats and B6C3F1 mice (gavage studies). National Toxicology Program. TR384. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr384.pdf. May 19, 2020.
NTP. 2016. 1,2,3-Trichloropropane. CAS No. 96-18-4. Report on carcinogens. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/trichloropropane.pdf. June 15, 2017.
NYDOH. 2013. Letter health consultation Mackenzie Chemical Works, Inc. Central Islip, Suffolk County, New York, EPA facility ID: NYD980753420. Atlanta, GA: New York State Department of Health. Agency for Toxic Substances and Disease Registry. https://www.health.ny.gov/environmental/investigations/mackenzie/health_consult_2013.pdf. May 26, 2019.
Oki DS, Giambelluca TW. 1987. DBCP, EDB, and TCP contamination of ground water in Hawaii. Ground Water Man 25:693–702. 10.1111/j.1745-6584.1987.tb02210.x.
OSHA. 2019a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Ratpan F, Plaumann H. 1988. Mutagenicity of halogenated propanes and their methylated derivatives. Environ Mol Mutagen 12(2):253–259. 10.1002/em.2860120211.3044786
RePORTER. 2020. 1,2,3-Trichloropropane. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. April 30, 2020.
Riddick JA, Bunger WB, Sakano TK. 1986. Organic solvents. In: Physical properties and methods of purification. Techniques of chemistry. 4^th^ ed. New York, NY: Wiley-Interscience, 524.
Roberts TR, Stoydin G. 1976. The degradation of (Z)- and (E)-,1,3dichloropropenes and 1,2dichloropropane in soil. Pestic Sci 7:325–335. 10.1002/ps.2780070402.
Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: a review. Am Ind Hyg Assoc J 47(3):A142–151. 10.1080/15298668691389595.3706135
Saito-Suzuki R, Teramoto S, Shirasu Y. 1982. Dominant lethal studies in rats with 1,2-dibromo-3-chloropropane and its structurally related compounds. Mutat Res 101(4):321–327. 10.1016/0165-1218(82)90125-2.7110159
Sakazaki H, Ueno H, Umetani K, 2001. Immunotoxicological evaluation of environmental chemicals utilizing mouse lymphocyte mitogenesis test. J Health Sci 47(3):258–271. 10.1248/jhs.47.258.
Salmon AG, Jones RB, Mackrodt WC. 1981. Microsomal dechlorination of chloroethanes: structure-reactivity relationships. Xenobiotica 11(11):723–734. 10.3109/00498258109045876.7336754
Shell Oil. 1983a. 120-Day toxicity gavage study of 1,2,3-trichloropropane in Fischer 344 rats. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515720. 86870001644.
Shell Oil. 1983b. Final report. 120-Day gavage toxicity study in B6C3Fl mice. 1,2,3-Trichloropropane. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0516158. 86-870001577.
Silverman L, Schulte HF, First MW. 1946. Further studies on sensory response to certain industrial solvent vapors. J Ind Hyg Toxicol 28(6):262–266.21002364
Silverstein RM, Bassler GC, Merrill TC. 1974. 1,2,3-Trichloropropane. In: Spectrometric identification of organic compounds. 3^rd^ ed. New York, NY: John Wiley and Sons, 239.
Sipes IG, Carter DE, Volp RF. 1982. Pharmacokinetics of xenobiotics: 1,2,3-Trichloropropane. Submitted to the National Institute of Environmental Health Sciences.
Smyth HF, Carpenter CP, Weil CS, 1962. Range-finding toxicity data: List VI. Am Ind Hyg Assoc J 23(2):95–107. 10.1080/00028896209343211.13914538
Stolzenberg SJ, Hine CH. 1980. Mutagenicity of 2- and 3-carbon halogenated compounds in the Salmonella/mammalian-microsome test. Environ Mutagen 2(1):59–66. 10.1002/em.2860020109.7035158
Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28. 10.1007/978-1-4612-5462-1_3.
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53(10):1503–1518.
Tafazoli M, Kirsch-Volders M. 1996. In vitro mutagenicity and genotoxicity study of 1,2-dichloroethylene, 1,1,2-trichloroethane, 1,3-dichloropropane, 1,2,3-trichloropropane and 1,1,3-trichloropropene, using the micronucleus test and the alkaline single cell gel electrophoresis technique (comet assay) in human lymphocytes. Mutat Res 371(3–4):185–202. 10.1016/s0165-1218(96)90107-x.9008720
Tonogai Y, Ito Y, Ogawa S, 1986. Determination of dibromochloropropane and related fumigants in citrus fruit. J Food Prot 49(11):909–913. 10.4315/0362-028X-49.11.909.30965502
TRI18. 2020. 1,2,3-Trichloropropane. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. May 11, 2020.
Union Carbide. 1958. Range finding tests on 1,2,3-trichloropropane. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515585. 86870001423. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0515585.xhtml. May 19, 2020.
Van Dyke RA, Wineman CG. 1971. Enzymatic dechlorination. Dechlorination of chloroethanes and propanes in vitro. Biochem Pharmacol 20(2):463–470. 10.1016/0006-2952(71)90082-7.4402457
Villeneuve DC, Chu I, Secours VE, 1985. Results of a 90-day toxicity study on 1,2,3- and 1,1,2-trichloropropane administered via the drinking water. Sci Total Environ 47:421–426. 10.1016/0048-9697(85)90346-8.4089609
Volp RF, Sipes IG, Falcoz C, 1984. Disposition of 1,2,3-trichloropropane in the Fischer 344 rat: conventional and physiological pharmacokinetics. Toxicol Appl Pharmacol 75(1):8–17. 10.1016/0041-008x(84)90070-x.6431641
von der Hude W, Scheutwinkel M, Gramlich U, 1987. Genotoxicity of three-carbon compounds evaluated in the SCE test in vitro. Environ Mutagen 9(4):401–410. 10.1002/em.2860090406.3582297
Wakeham SG, Goodwin JT, Davis AC. 1983. Distributions and fate of volatile organic compounds in Narragansett Bay, Rhode Island. Can J Fish Aquat Sci 40(S2):s304–s321. 10.1139/f83-336.
Weast RC. 1985. 1,2,3-Trichloropropane. In: CRC handbook of chemistry and physics. 66^th^ ed. Boca Raton, FL: CRC Press, Inc., C-444.
Weber GL, Sipes IG. 1992. In vitro metabolism and bioactivation of 1,2,3-trichloropropane. Toxicol Appl Pharmacol 113(1):152–158. 10.1016/0041-008x(92)90020-s.1553750
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Williams PH. 1949. Chlorine compounds, organic. In: Kirk RE, Othmer DF, eds. Kirk-Othmer encyclopedia of chemical technology. 1^st^ ed. New York NY: Interscience Encyclopedia, Inc., 775–776, 838.
WQP. 2020. 1,2,3-trichloropropane: Water quality data. Sampling parameter characteristics. Water Quality Portal. United States Geological Survey, Environmental Protection Agency, National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/#characteristicName=1%2C2%2C3-Trichloropropane&mimeType=csv. May 11, 2020.