# VERSION HISTORY

Date | Description
August 2021 | Final toxicological profile released
May 2019 | Draft for public comment toxicological profile released
August 2011 | Addendum to the toxicological profile released
September 1992 | Draft for public comment toxicological profile released