# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 1,2,3-trichloropropane are listed in Table 4-1.

Table 4-1 Chemical Identity of 1,2,3-Trichloropropane

Characteristic | Information | Reference
Chemical name | 1,2,3-Trichloropropane | NLM 2020
Synonym(s) and registered trade name(s) | Allyl trichloride; glycerol trichlorohydrin; trichlorohydrin | NLM 2020
Chemical formula | C_3_H_5_Cl_3_ | NLM 2020
Chemical structure | Chemical structure
CAS Registry Number | 96-18-4 | NLM 2020

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 1,2,3-trichloropropane are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of 1,2,3-Trichloropropane

Property | Information | Reference
Molecular weight | 147.43 | Weast 1985
Color | Colorless | Hawley 1981
Physical state | Liquid | Hawley 1981
Melting point | −14.7°C | Williams 1949
Boiling point | 156.8°C | Riddick et al. 1986
Density at 20 °C | 1.3888 g/cm^2^ | Riddick et al. 1986
Odor | Strong, acrid; trichloroethylene-like; “sweet smelling” | McNeill 1979; NLM 2020; Ruth 1986
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20 °C | 1,750 mg/L | Riddick et al. 1986
Organic solvents | Soluble in ethyl alcohol and higher alcohols, chloroform and other chlorinated hydrocarbons, ethyl ether, benzene | Weast 1985; Williams 1949
Partition coefficients:
Log K_ow_ | 2.27 | NLM 2020
Log K_oc_^a^ | 1.99 (estimated) | Lyman et al. 1982
Bioconcentration factor^b^ | 9.2 (estimated) | Lyman et al. 1982
Vapor pressure at 20°C | 3.1 mmHg | Mackay et al. 1982
Henry’s law constant at 25°C | 3.17×10^−4^ atm-m^3^/mol (calculated) | Lyman et al. 1982
Autoignition temperature | 304°C (580°F) | Hawley 1981
Flashpoint
Open cup | 82.2°C | Hawley 1981
Open cup | 78.9°C | Williams 1949
Closed cup | 73.3°C | Williams 1949
Flammability limits | No data
Conversion factors | 1 ppm (v/v)×6.03 = mg/m^2^; 1 mg/m^3^×0.166 = ppm (v/v)
Explosive limits | No data

a Calculated from water solubility using equation 4–7 (Lyman et al. 1982).

b Calculated from log K_ow_ using equation 5–2 (Lyman et al. 1982).