# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3-Trichloropropane
CAS Numbers: | 96-18-4
Date: | August 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.001 ppm
Critical Effect: | Decreased thickness of nasal olfactory epithelium
Reference: | Miller et al. 1986b
Point of Departure: | NOAEL of 1 ppm (NOAEL_HEC_ of 0.03 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 5
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 0.001 ppm was derived for 1,2,3-trichloropropane based on decreased thickness of the nasal olfactory epithelium of rats exposed 6 hours/day for 9 days over an 11-day period (Miller et al. 1986b). The MRL is based on a NOAEL of 1 ppm, which was adjusted to continuous duration exposure and converted to a human equivalent concentration (NOAEL_HEC_) of 0.03 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: A small number of studies have evaluated the toxicity of 1,2,3-trichloro-propane following acute-duration inhalation exposure. In humans, a 15-minute exposure to 100 ppm 1,2,3-trichloropropane resulted in eye and throat irritation (Silverman et al. 1946). Acute inhalation studies in experimental animals (rats and mice) identify the respiratory tract and liver as the most sensitive targets of 1,2,3-trichloropropane toxicity; a summary of relevant NOAEL and LOAEL values for respiratory and hepatic effects is presented in Table A-1. The respiratory effects consisted of decreases in the thickness of nasal olfactory epithelium at the lowest adverse effect levels (3 ppm in rats and 10 ppm in mice) (Miller et al. 1986b), degeneration and inflammation of olfactory epithelium at 13 ppm in rats (Miller et al. 1986a), subacute inflammation of olfactory epithelium at 40 ppm in mice (Miller et al. 1986b), and multifocal fibrosis of nasal submucosa at 132 ppm in rats (Miller et al. 1986a). The Miller et al. (1986a) rat study demonstrated that the severity of the nasal lesions increased with concentration; the degeneration of olfactory epithelium was graded as slight at 13 ppm, moderate at 40 ppm, and severe at 132 ppm. The liver effects consisted of increases in absolute and relative liver weights in rats and mice exposed to 132 ppm (Miller et al. 1986a), very slight individual cell hepatocellular necrosis in male rats exposed to 132 ppm (Miller et al. 1986a), and very slight hepatocellular vacuolization at 132 ppm in mice (Miller et al. 1986a). Other acute-duration studies have primarily focused on lethality (Gushow and Quast 1984; Johannsen et al. 1988; Smyth et al. 1962; Union Carbide 1958). Based on the available data, the nasal olfactory epithelium appears to be the most sensitive target of toxicity following acute-duration inhalation exposure.

Table A-1 Summary of Relevant LOAEL Values Following Acute Inhalation Exposure to 1,2,3-Trichloropropane^a^

Species | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Nasal effects
F344 rat | | 13 | Degeneration and inflammation of nasal olfactory epithelium | Miller et al. 1986a
F344 rat | 1 | 3 | Decreased thickness of olfactory epithelium | Miller et al. 1986b
B6C3F1 mouse | | 13 | Decreased thickness of olfactory epithelium | Miller et al. 1986a
B6C3F1 mouse | 3 | 10 | Nasal olfactory inflammation | Miller et al. 1986b
Hepatic effects
F344 rat | 40 | 132 | Very slight hepatocellular necrosis | Miller et al. 1986a
B6C3F1 mouse | 40 | 132 | Hepatocellular vacuolization | Miller et al. 1986a

a Rats and mice were exposed 6 hours/day for 9 exposures in an 11-day period.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: Based on a comparison of NOAEL and LOAEL values and the observed effects, rats appear to be more sensitive than mice to 1,2,3-trichloropropane-induced nasal toxicity. The Miller et al. (1986b) rat study, which identified a NOAEL of 1 ppm and a LOAEL of 3 ppm, was selected as the principal study.

Summary of the Principal Study:

Miller RR, Quast JF, Momany-Pfruender JJ. 1986b. 1,2,3-Trichloropropane: 2-Week vapor inhalation study to determine the no-adverse-effect level in rats and mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517055. 86870002265. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0517055.xhtml. May 19, 2020.

Groups of five male and five female Fischer 344 rats were exposed to 0, 1, 3, or 10 ppm 1,2,3-trichloro-propane 6 hours/day, 5 days/week for 9 exposures in an 11-day period. The following parameters were used to assess toxicity: observations after each exposure period, body weight measurements prior to 1^st^, 3^rd^, 5^th^, and 7^th^ exposure, urinalysis (bilirubin, glucose, ketones, occult blood, pH, protein, urobilinogen, and specific gravity), organ weights (brain, heart, liver, kidneys, thymus, and testes), gross necropsy of major tissues and organs, and histopathological examination of nasal tissue.

There were no deaths or alterations in body weight gain, or urinalysis, or organ weights. A very slight decrease in olfactory epithelial thickness was observed in 10/10 rats exposed to 3 ppm, but was not observed in controls or other groups of exposed rats. The investigators did not suggest a reason why these lesions were only observed at 3 ppm, but did not consider this an adverse effect level. Very slight olfactory epithelial degeneration was observed in 10/10 rats at 10 ppm and in 0/10 control rats. Very slight multifocal, bilateral subacute inflammation of olfactory epithelium was observed in 6/10, 4/10, 2/10, and 10/10 rats in the 0, 1, 3, and 10 ppm groups, respectively. No alterations were observed on gross necropsy.

Selection of the Point of Departure for the MRL: The NOAEL/LOAEL approach was used to select the point of departure (POD) for the MRL. The incidence data for olfactory epithelial alterations were not considered suitable for benchmark dose (BMD) modeling due to the lack of concentration-response data, 0% incidence in controls and 1 ppm groups and 100% in the 3 ppm group. Thus, the NOAEL of 1 ppm was selected as the POD for the MRL.

Intermittent Exposure: The NOAEL of 1 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

NOAEL_ADJ_ = 1 ppm × (6 hours/24 hours) × (9 exp osures/11 days) = 0.20 ppm .

Human Equivalent Concentration: A human equivalent concentration (HEC) was calculated by multiplying the duration-adjusted NOAEL by the regional gas dose ratio (RDGR). The RGDR for extrathoracic respiratory tract effects was calculated using the following equation:

RDGR_ET_ = ([V_E_ / SA_ET_]_A_) / ([V_E_ / SA_ET_]_H_)

Where:

- V_e_ is the minute volume and SAET is the surface area of the extrathoracic (ET) region of the respiratory tract.
- Minute volume (V_e_)
  - Human: 13.8 L/minute (EPA 1994)
  - Rat: 0.138 L/minute; calculated using the following EPA equation:
    ln (V_e_) = b_0_ + b_1_ ln (BW)
  - For rats, b_0_ equals −0.578 and b_1_ equals 0.821.
- An average body weight for male and female rats of 0.181 kg was used.
- EPA (1994) rat and human respiratory surface area reference values for the extrathoracic region:
  - Human: 200 cm^2^
  - Rat: 15.0 cm^2^
- RGDRET = (0.138 L / min / 15.0 cm^2^) ÷ (13.8 L / min / 200 cm^2^) = 0.133

NOAEL_HEC_ = NOAEL_ADJ_ × RGDR_ET_ NOAEL_HEC_ = 0.20 ppm × 0.133 = 0.03 ppm

Uncertainty Factor: The NOAEL_HEC_ of 0.03 ppm was divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

MRL = NOAEL_HEC_ ÷ UFs 0.03 ppm ÷ (3 × 10) = 0.001 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Although the principal study only included histological examination of the nasal cavity, a companion study (Miller et al. 1986a) examined a wide range of endpoints and demonstrated that the olfactory epithelium was the most sensitive target of toxicity.

Agency Contact (Chemical Manager): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3-Trichloropropane
CAS Numbers: | 96-18-4
Date: | August 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: The available intermediate inhalation data were not considered adequate for derivation of an intermediate-duration inhalation MRL for 1,2,3-trichloropropane.

Rationale for Not Deriving an MRL: An intermediate-duration inhalation MRL was not derived for 1,2,3-trichloropropane because derivation of an MRL based on the available intermediate studies resulted in an MRL that was higher than the acute-duration inhalation MRL and the only available study did not examine nasal tissue (the most sensitive target following acute exposure).

Reliable information on the intermediate-duration toxicity of 1,2,3-trichlorochloropropane is limited to a series of studies in rats conducted by Johannsen et al. (1988). These studies identified several sensitive targets of toxicity including the respiratory tract, liver, and the hematological system. In a 4-week preliminary study (6 hours/day, 5 days/week), increases in liver weight were observed at ≥95 ppm; the study did not include histological examinations. In a more extensive 13-week study (6 hours/day, 5 days/week), exposure to 4.5 ppm resulted in peribronchial lymphoid hyperplasia, midzonal hepatocellular hypertrophy, and extramedullary hematopoiesis in the spleen. At 15 ppm, decreases in body weight gain and excessive lacrimation were observed. No adverse effects were observed at the two lowest test concentrations (0.05 and 1.54 ppm). It is noted that the Johannsen et al. (1988) study did not include examination of nasal tissue, which was the most sensitive target of toxicity following acute inhalation exposure. In a reproductive/developmental toxicity study, no alterations in mating, fertility, histopathology of reproductive tissues, gestation length, number of live births, litter size at birth or postnatal days 4–21, birth weight, pup body weight, or pup survival through postnatal day 21 were observed in male and female rats exposed to concentrations as high as 15 ppm for a 10-week pre-mating period, 30–40-day mating period, and gestation days 0–14.

Based on the available data, an MRL could be derived based on the lung, liver, and spleen effects observed in rats exposed to ≥4.5 ppm; the NOAEL for these effects is 1.54 ppm. Adjusting the NOAEL concentration for intermittent exposure results in a NOAEL_ADJ_ of 0.275 ppm. A NOAEL_HEC_ of 0.275 ppm is calculated by multiplying the NOAEL_ADJ_ by an extra-respiratory RGDR of 1. Because blood:gas partition coefficients are not available for rats or humans, the default ratio of 1 was used for the RGDR_ER_. It is noted that the peribronchial lymphoid hyperplasia observed in the lungs was not considered a portal-of-entry effect since the effect occurred in lymphoid tissue rather than lung tissue. Dividing the NOAEL_HEC_ POD of 0.275 ppm by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability) results in a candidate MRL of 0.009 ppm. This value is higher than the acute-duration inhalation MRL of 0.001 ppm based on nasal lesions observed in rats exposed to 1,2,3-trichloropropane for 11 exposures (Miller et al. 1986b). Thus, an intermediate-duration inhalation MRL was not derived for 1,2,3-trichloropropane.

Agency Contact (Chemical Manager): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3-Trichloropropane
CAS Numbers: | 96-18-4
Date: | August 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: The available chronic inhalation data were not considered adequate for derivation of chronic-duration inhalation MRL for 1,2,3-trichloropropane.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for 1,2,3-trichloropropane.

Agency Contact (Chemical Manager): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3-Trichloropropane
CAS Numbers: | 96-18-4
Date: | August 2021
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: The available acute oral data were not considered adequate for derivation of an acuteduration oral MRL for 1,2,3-trichloropropane.

Rationale for Not Deriving an MRL: A small number of studies have examined the toxicity of 1,2,3-tri-chloropropane following acute oral exposure. Increases in mortality were observed at ≥150 mg/kg (Albert 1982; NTP 1993; Smyth et al. 1962). The most sensitive effect identified in the available database was an increase in relative liver weights observed in rats administered via gavage ≥29.5 mg/kg/day for 10 days (Merrick et al. 1991). At 118 mg/kg/day, decreases in body weight gain; myocardial inflammation, degeneration, and necrosis; and thymic atrophy were observed in rats administered 1,2,3-trichloropropane via gavage for 10 days (Merrick et al. 1991). Two studies examining reproductive effects in male rats did not find increases in the incidence of histological alterations at 60 mg/kg/day for 10 days (Dix 1979) or 80 mg/kg/day for 5 days (Saito-Suzuki et al. 1982) or dominant lethality at 80 mg/kg/day (Saito-Suzuki et al. 1982).

Although the available acute-duration studies identified several effects, the database was not considered suitable for MRL derivation. The increase in liver weight was considered a LOAEL based on intermediate and chronic studies that reported histological alterations in the liver. However, no significant increases in liver lesions were observed in the Merrick et al. (1991) study, although centrilobular hepatic necrosis was observed in 3/20 animals at 118 mg/kg/day. Heart lesions were observed in acute- and intermediate-duration studies conducted by Merrick et al. (1991), but no cardiovascular effects have been observed in other acute, intermediate, or chronic oral studies; this endpoint was not considered suitable for MRL derivation due to the lack of corroborative data. Interpretation of the thymic atrophy observed at 118 mg/kg/day is difficult given that a 22–25% decrease in body weight gain was also observed at this dose level.

Agency Contact (Chemical Manager): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3-Trichloropropane
CAS Numbers: | 96-18-4
Date: | August 2021
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.03 mg/kg/day
Critical Effect: | Decreased hematocrit
Reference: | NTP 1993
Point of Departure: | BMDL_1SD_ of 4.03 mg/kg (BMDL_ADJ_ of 2.9 mg/kg/day)
Uncertainty Factor: | 100
LSE Graph Key: | 9
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.03 mg/kg/day was derived for 1,2,3-trichloro-propane based on decreased hematocrit levels observed in female rats administered via gavage 1,2,3-tri-chloropropane 5 days/week for 8 weeks (NTP 1993). The MRL is based on a BMDL_1SD_ of 4.03 mg/kg, which was adjusted to a continuous duration exposure to a BMDL_ADJ_ of 2.9 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Four studies have evaluated the intermediate-duration oral toxicity of 1,2,3-trichloropropane. These studies identified a number of targets of toxicity: body weight, respiratory tract, heart, forestomach, hematological system, liver, kidney, and reproductive/developmental systems. The NOAEL and LOAEL values for these effects are summarized in Table A-2.

Table A-2 Summary of NOAEL and LOAEL Values Following Intermediate-Duration Oral Exposure to 1,2,3-Trichloropropane

Species | Exposure | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight effects
Sprague-Dawley rat | 30 days (GO) | 14.7 | 58.9 | 14–20% decrease in body weight gain 1991 | Merrick et al. 1991
F344 rat | 17 weeks, 5 days/week (GO) | 23^a^ | 45^a^ | 11% decreases in body weight gain in males (females at 89 mg/kg/day) | NTP 1993
Sprague-Dawley rat | 13 weeks (W) | 17 | 113 | Reduced body weight gain | Villeneuve et al. 1985
B6C3F1 mouse | 17 weeks, 5 days/week (GO) | 179^a^ | | No effect on body weight gain | NTP 1993
Respiratory effects
F344 rat | 17 weeks, 5 days/week (GO) | 45^a^ | 89^a^ | Necrosis in nasal turbinates | NTP 1993
B6C3F1 mouse | 17 weeks, 5 days/week (GO) | 23^a^ | 45a | Regeneration of bronchiolar epithelium in the lungs in females (males at ≥89 mg/kg/day) | NTP 1993
Cardiovascular effects
Sprague-Dawley rat | 30 days (GO) | 14.7 | 58.9 | Myocardial inflammation, degeneration, and necrosis | Merrick et al. 1991
F344 rat | 17 weeks, 5 days/week (GO) | 89^a^ | | No histological alterations | NTP 1993
Sprague-Dawley rat | 13 weeks (W) | 113 | | No histological alterations | Villeneuve et al. 1985
B6C3F1 mouse | 17 weeks, 5 days/week (GO) | 179^a^ | | No histological alterations | NTP 1993
Gastrointestinal effects
F344 rat | 17 weeks, 5 days/week (GO) | 89^a^ | | No histological alterations | NTP 1993
B6C3F1 | 17 weeks, mouse 5 days/week (GO) | 23^a^ | 45^a^ | Hyperkeratosis and acanthosis of forestomach | NTP 1993
Hematological effects
F344 rat | 17 weeks, 5 days/week (GO) | 5.7^a^ | 11^a^ | Decreases in hematocrit, hemoglobin, and erythrocyte levels after 8 and 17 weeks | NTP 1993
Sprague-Dawley rat | 13 weeks (W) | 113 | | No hematological alterations | Villeneuve et al. 1985
B6C3F1 mouse | 17 weeks, 5 days/week (GO) | 179^a^ | | No hematological alterations | NTP 1993
Hepatic effects
Sprague-Dawley rat | 30 days (GO) | 7.4 | 14.7 | Increased relative liver weight | Merrick et al. 1991
Sprague-Dawley rat | 30 days (GO) | 14.7 | 58.9 | Bile duct hyperplasia | Merrick et al. 1991
F344 rat | 17 weeks, 5 days/week (GO) | 5.7^a^ | 11^a^ | Increased absolute liver weight | NTP 1993
F344 rat | 17 weeks, 5 days/week (GO) | | 89^a^ | Hepatocellular necrosis and hemorrhage, bile duct hyperplasia | NTP 1993
Sprague-Dawley rat | 13 weeks (W) | 17 | 113 | Anisokaryosis, accentuated zonation and fatty vacuolation | Villeneuve et al. 1985
Sprague-Dawley rat | 13 weeks (W) | | 149 | Biliary hyperplasia (females only) | Villeneuve et al. 1985
B6C3F1 mouse | 17 weeks, 5 days/week (GO) | 45^a^ | 89^a^ | Increased liver weights | NTP 1993
B6C3F1 mouse | 17 weeks, 5 days/week (GO) | | 179^a^ | Focal hepatocellular necrosis | NTP 1993
Renal effects
F344 rat | 17 weeks, 5 days/week (GO) | 11^a^ | 23^a^ | Increased absolute and relative liver weight in males | NTP 1993
F344 rat | 17 weeks, 5 days/week (GO) | | 45^a^ | Regenerative hyperplasia after 8 weeks of exposure; not observed after 17 weeks of exposure | NTP 1993
Sprague-Dawley rat | 13 weeks 17 (W) | 113 | | Eosinophilic inclusions, pyknosis, nuclear displacement, fine glomerular adhesions, interstitial reactions, and histologic proteinuria | Villeneuve et al. 1985
B6C3F1 mouse | 17 weeks, 5 days/week (GO) | | 179^a^ | Multifocal tubular necrosis in animals dying early | NTP 1993
Reproductive/developmental effects
Swiss mice | 98 days (GO) | 30 | 60 | Decreased number of live pups per litter | NTP 1990
Swiss mice | 98 days (GO) | 120 | | No alterations in epididymal sperm motility, count, or morphology or estrous cycle length | NTP 1990
Swiss mice | 98 days (GO) | | 120 | Ovarian amyloidosis | NTP 1990
Swiss mice | Prenatal exposure, post weaning, mating, and gestation exposure | 60 | 120 | Decreases in mating, fertility, and pregnancy indices | NTP 1990

a Administered doses of 8, 16, 32, 63, 125, or 250 mg/kg were adjusted for intermittent exposure (5 days/week) resulting in continuous doses of 5.7, 11, 23, 45, 89, and 179 mg/kg/day.

GO = gavage in oil; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; W = drinking water administration

Based on a comparison of the lowest LOAEL values for each endpoint, the liver appears to be one of the most sensitive targets of toxicity. At gavage doses ≥11 mg/kg/day, >10% increases in absolute liver weight were observed in rats (NTP 1993); a similar LOAEL of 14.7 mg/kg/day was identified in another rat gavage study (Merrick et al. 1991). An increase in liver weight was also observed in mice administered ≥89 mg/kg/day (NTP 1993). Serum clinical chemistry alterations have also been observed at lower doses; decreases in pseudocholinesterase levels, likely due to decreased synthesis in the liver, were observed at ≥5.7 mg/kg/day (NTP 1993) and increases in serum total bilirubin and alanine aminotransferase were observed at ≥58.9 mg/kg/day (NTP 1993). At higher doses, hepatocellular necrosis was observed in rats and mice administered 89 and 179 mg/kg/day, respectively (NTP 1993), and anisokaryosis and fatty vacuolation were observed in rats at 113 mg/kg/day (Villeneuve et al. 1985). Additionally, bile duct hyperplasia was observed in rats at 58.9 mg/kg/day (Merrick et al. 1991), 89 mg/kg/day (NTP 1993), and 149 mg/kg/day (Villeneuve et al. 1985).

The lowest LOAEL for hematological effects is also 11 mg/kg/day identified in the NTP (1993) rat study. The hematological effects consisted of decreases in hematocrit, hemoglobin, and erythrocyte levels in female rats. NTP noted that the observed anemia was nonregenerative and possibly associated with depressed erythropoiesis. No hematological effects were observed in a 13-week rat drinking water study (Villeneuve et al. 1985) or in a 17-week gavage mouse study (NTP 1993).

At the next highest LOAEL of 23 mg/kg/day, increases in kidney weights were observed in male rats (NTP 1993); the adversity of this finding is supported by histological alterations in the kidney observed at ≥45 mg/kg/day (NTP 1993; Villeneuve et al. 1985). Other effects that have been observed in rats and mice at higher LOAELs included decreases in body weight gain (lowest LOAEL of 45 mg/kg/day) (Merrick et al. 1991; NTP 1993; Villeneuve et al. 1985), regeneration of bronchiolar epithelium (45 mg/kg/day) (NTP 1993), hyperkeratosis and acanthosis of the forestomach, myocardial inflammation, degeneration, and necrosis (58.9 mg/kg/day) (Merrick et al. 1991), decreases in reproductive function (60 mg/kg/day) (NTP 1990), and necrosis in nasal turbinates (89 mg/kg/day) (NTP 1993).

Selection of the Principal Study: NTP (1993) was selected as the principal study because it identified the lowest LOAEL (11 mg/kg/day) for liver and hematological effects.

Summary of the Principal Study:

NTP. 1993. Toxicology and carcinogenesis of 1,2,3-trichloropropane (CAS No. 96-18-4) in F344/N rats and B6C3F1 mice (gavage studies). National Toxicology Program. TR384. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr384.pdf. May 19, 2020.

Groups of 20 male and 20 female F344/N rats were administered 8, 16, 32, 63, 125, or 250 mg/kg 1,2,3-trichloropropane in corn oil 5 days/week for 17 weeks; a vehicle control group consisted of 30 males and 30 females. After 8 weeks of exposure, 10 rats/sex/group were sacrificed. The following parameters were used to assess toxicity: weekly clinical observations, weekly body weights, organ weights (brain, epididymis, heart, kidney, liver, lung, testis, thymus), urinalysis, hematology, serum clinical chemistry, and histopathology of major tissues and organs (control and 125 mg/kg groups and other groups as needed).

A number of adverse effects have been observed in animals exposed for 8 or 17 weeks; these effects are described below and summarized in Table A-3.

- Death. Deaths were observed in all male and female rats in the 250 mg/kg group by week 5 and 2, respectively, and in 1/10 males and 4/10 females at 125 mg/kg. The cause of death in the 250 mg/kg group was kidney or hepatic toxicity. There was no mortality at lower doses.
- Body weight. Body weight gain was reduced in males at 63 mg/kg (11% lower than controls) and in males (21%) and females (24%) at 125 mg/kg. Food consumption was markedly reduced at 250 mg/kg prior to death.
- Respiratory. There was a significant increase in relative lung weight after 17 weeks in males at 125 mg/kg. Epithelial necrosis and attenuation of epithelial lining of the dorsal portion of nasal turbinates was observed at 125 mg/kg; in females, the lesions were observed after 8 and 17 weeks of exposure.
- Hematological. Significant decreases in hematocrit, hemoglobin, and erythrocyte levels were observed at 63 and 125 mg/kg after 17 weeks of exposure; decreases in hemoglobin levels were also observed in females at 16 and 32 mg/kg. After 8 weeks of exposure, decreases in hematocrit, hemoglobin, and erythrocyte levels were observed at ≥16 mg/kg and hematocrit and erythrocyte levels were also decreased in females at ≥8 mg/kg.
- Hepatic. After 8 weeks of exposure, significant increases were observed in total bilirubin at ≥63 mg/kg, ALT in females at ≥63 mg/kg, aspartate aminotransferase (AST) in females at ≥125 mg/kg, lactic acid dehydrogenase (LDH) at ≥63 mg/kg in females and 125 mg/kg in males, and sorbitol dehydrogenase (SDH) at 125 mg/kg. Pseudocholinesterase levels were significantly decreased in males 32 and 125 mg/kg after 8 weeks and ≥32 mg/kg in males at 17 weeks, and ≥8 mg/kg in females at 8 and 17 weeks. The investigators suggested that the decrease in pseudocholinesterase levels suggest a decrease in synthesis due to hepatocellular damage. Significant increases in absolute liver weight were observed in males after 17 weeks of exposure at ≥8 mg/kg and in females at ≥16 mg/kg; the increases in absolute liver weight in the males did not appear to be dose-related. Significantly increased relative liver weights were observed at ≥32 mg/kg in males and ≥16 mg/kg in females. In the liver, necrosis, hemorrhage, and bile duct hyperplasia were observed in females at 125 mg/kg after 8 or 17 weeks of exposure; degeneration and hemorrhage were observed in males at 250 mg/kg after 8 weeks of exposure. There were no treatment-related effects in lower dose groups after 17 weeks.
- Renal. Blood urea nitrogen (BUN) levels were decreased in females at 16, 63, and 125 mg/kg after 8 weeks of exposure and in males at 125 mg/kg and females at ≥32 mg/kg after 17 weeks. Absolute and relative kidney weights were increased (p<0.05) after 17 weeks at ≥32 mg/kg in males and at ≥63 mg/kg in females. Renal regenerative hyperplasia was observed at ≥63 mg/kg after 8 weeks of exposure and at 125 mg/kg after 17 weeks of exposure in males; necrosis and karyomegaly (males only) were also observed at 250 mg/kg after 8 weeks of exposure.
- Other Effects. The investigators noted that thymic lymphoid depletion, hypocellularity of sternal bone marrow, splenic atrophy, uterine hypoplasia, adrenal cortical cell vacuolation, and myocardial chronic inflammation occurred less frequently in animals dying during the study; however, incidence data were not provided and NOAEL and LOAEL values could not be identified for these effects.

Table A-3 NOAEL and LOAEL Values for Adverse Health Effects Observed in Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 17 Weeks

Endpoint | NOAEL (mg/kg) | LOAEL (mg/kg) | Effect | AEL (mg/kg)
Death | | 250
Body weight | 32 M | 63 M | Decreased body weight gain (11%) | 63 M
Respiratory | 63 M | 125 M | Increased relative lung weight (13%) | 125 M
Respiratory | 63 M | 125 M | Epithelial necrosis in nasal turbinates | 125 M
Hematological | | 8 F | Decreases in hemoglobin (5%) and erythrocytes 8 F (19%) at 8 weeks | 8 F
Hepatic | 8F | 16 F | Increased absolute liver weight (11% in males at 8 mg/kg and 18% in females at 16 mg/kg) | 8 M; 16 F
Hepatic | 8F | 16 F | Increased relative liver weight (24% in males at 32 mg/kg and 12% in females at 16 mg/kg) | 32 M; 16 F
Hepatic | 8F | 16 F | Necrosis, hemorrhage, and bile duct hyperplasia (females only) | 250 M; 125 F
Renal effects | 16 M | 32 M | Increased absolute (15%) and relative (12%) kidney weight | 32 M
Renal effects | 16 M | 32 M | Regenerative hyperplasia | 63 M

AEL = adverse-effect level; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Source: NTP 1993

Selection of the Point of Departure for the MRL: The BMDL_1SD_ of 6.91 mg/kg for decreases in hemoglobin levels in female rats estimated from the frequentist restricted Hill model was selected as the point of departure for the intermediate-duration oral MRL for 1,2,3-trichloropropane.

The lowest LOAEL identified in the NTP (1993) rat study was 8 mg/kg. At this dose level, decreases in hematocrit and erythrocyte levels were observed in female rats administered 1,2,3-trichloropropane for 8 weeks. The lowest LOAEL identified in rats administered 1,2,3-trichloropropane for 17 weeks was 16 mg/kg for increases in absolute and relative liver weight in females and decreases in hemoglobin and erythrocyte levels in females. The absolute and relative liver weights in females exposed for 17 weeks (Table A-4) and hematocrit and erythrocyte levels in females exposed for 8 weeks (Table A-5) were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.2) using the extra risk option. The 8-week hematological data were selected over the 17 week data since a lower LOAEL was identified at 8 weeks and the magnitude of change was greater at 8 weeks compared to 17 weeks. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR), BMDL that is not 10 times lower than the lowest non-zero dose, and visual inspection of the dose-response curve. A BMR of 10% change from the control was used for liver weights and 1 standard deviation change relative to controls was used for hemoglobin and erythrocyte levels.

Table A-4 Summary of Absolute and Relative Liver Weights in Female Rats Administered via Gavage 1,2,3-Trichloropropane for 17 Weeks

| | Mean±standard deviation^a^
Dose (mg/kg)^b^ | Number of rats | Absolute liver weight (g) | Relative liver weight (mg/g BW)
0 | 10 | 5.14±0.32 | 25.7±1.26
8 | 10 | 5.49±0.28 | 27.5±1.90
16 | 10 | 6.07±0.51^c^ | 28.9±1.26^c^
32 | 10 | 6.00±0.28^d^ | 30.2±1.90^c^
63 | 10 | 6.79±0.54^c^ | 35.2±2.53^c^
125 | 6 | 8.25±0.49^c^ | 52.6±5.63^c^

a Mean±standard deviation; standard deviations estimated from reported SEM.

b Animals administered 1,2,3-trichloropropane via gavage 5 days/week.

c Significantly different from controls, p≤0.01.

d Significantly different from controls, p≤0.05.

BW = body weight; SEM = standard error of the mean

Source: NTP 1993

Table A-5 Summary of Hematocrit and Erythrocyte Levels in Female Rats Administered via Gavage 1,2,3-Trichloropropane for 8 Weeks

| | Mean±standard deviation^a^
Dose (mg/kg)^b^ | Number of rats | Absolute liver weight (g) | Relative liver weight (mg/g BW)
0 | 10 | 46.7±1.26 | 8.59±0.25
8 | 10 | 45.0±1.26^c^ | 8.31±0.22^c^
16 | 10 | 42.1±1.58^d^ | 7.77±0.32^d^
32 | 10 | 41.3±2.21^c^ | 7.60±10.41^d^
63 | 10 | 39.9±1.58^d^ | 7.39±0.25^d^
125 | 9 | 38.7±2.40^d^ | 7.60±0.48^d^

a Mean±standard deviation; standard deviations estimated from reported standard error of the mean (SEM).

b Animals administered 1,2,3-trichloropropane via gavage 5 days/week.

c Significantly different from controls, p≤0.05.

d Significantly different from controls, p≤0.01.

Source: NTP 1993

None of the models provided adequate fit to the absolute liver weight data with constant or nonconstant variance and after dropping the highest dose. BMD modeling provided adequate fit for the relative liver weight, hematocrit, and erythrocyte data. The model predictions for relative liver weight, are presented in Table A-6. All of the models except Exponential 4 and Exponential 5 models provided adequate fit to the data with the assumption of nonconstant variance; the 4-degree Polynomial had the lowest Akaike Information Criterion (AIC) and is the recommended model. This model estimated a BMD_1SD_ of 19.11 mg/kg and a BMDL_1SD_ of 15.99 mg/kg. For the hematocrit data after 8 weeks of exposure, only the Exponential 5 and Hill models (constant variance) provided adequate fit; model predictions are presented in Table A-7. The Exponential 5 model had the lowest AIC and is the recommended model; this model estimated BMD_1SD_ and BMDL_1SD_ values of 5.97 and 4.03 mg/kg, respectively. The model predictions (constant variance) for erythrocyte levels are presented in Table A-8. Three models provided adequate fit; the Hill model was recommended because it had the lowest AIC. The Hill model estimated a BMD_1SD_ of 8.44 mg/kg and a BMDL_1SD_ of 5.57 mg/kg.

Table A-6 Results from BMD Analysis (Nonconstant Variance) of Relative Liver Weight in Female Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 17 Weeks (NTP 1993)

Model | BMD_RD10_^a^ (mg/kg) | BMDL_RD10_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_RD10_^a^ (mg/kg) | BMDL_RD10_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Dose near BMD | Control group
Exponential 2^d^ | 18.14 | 16.58 | 0.157 | 243.99 | 1.20 | −0.71
Exponential 3^d^ | 20.80 | 16.89 | 0.103 | 245.55 | 1.42 | −1.16
Exponential 4^d^ | | | 0.014 | 249.85 | 0.78 | −0.30
Exponential 5^d^ | | | 0.009 | 250.76 | 1.69 | −1.60
Hill^d^ | 23.70 | 16.28 | 0.008 | 251.14 | 1.69 | −1.62
Polynomial Degree 5^d^ | 18.56 | 15.73 | 0.227 | 244.33 | 1.08 | −0.92
Polynomial Degree 4 ^d^ ^,^ ^e^ | 19.11 | 15.99 | 0.375 | 242.48 | 1.14 | −0.99
Polynomial Degree 3^d^ | 20.21 | 16.43 | 0.292 | 243.10 | 1.26 | −1.12
Polynomial Degree 2^d^ | 21.69 | 16.68 | 0.117 | 245.25 | 1.46 | −1.29
Power^d^ | | | 0.026 | 248.60 | 1.65 | −1.55
Linear | | | 0.015 | 249.77 | 0.79 | −0.31

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming nonconstant variance. Of the models providing adequate fit, the BMDLs were sufficiently close (differed by <3-fold); therefore, the model with the lowest AIC was selected (Polynomial 4 degree).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _RD10_ = exposure dose associated with a 10% relative deviation from control)

Table A-7 Results from BMD Analysis (Constant Variance) of Hematocrit Levels in Female Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 8 Weeks (NTP 1993)

Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Dose near BMD | Control group
Exponential 2^d^ | | | <0.0001 | 265.21 | −2.04 | 2.94
Exponential 3^d^ | | | <0.0001 | 265.21 | −2.04 | 2.94
Exponential 4^d^ | | | <0.0001 | 267.19 | −2.04 | 2.94
Exponential 5 ^d^ ^,^ ^e^ | 5.97 | 4.03 | 0.225 | 239.95 | 0.90 | −0.06
Hill^d^ | 6.16 | 3.21 | 0.200 | 240.81 | 0.82 | −0.16
Polynomial Degree 5^d^ | | | <0.0001 | 266.92 | −2.08 | 3.07
Polynomial Degree 4^d^ | | | <0.0001 | 266.92 | −2.08 | 3.07
Polynomial Degree 3^d^ | | | <0.0001 | 266.92 | −2.08 | 3.07
Polynomial Degree 2^d^ | | | <0.0001 | 266.92 | −2.08 | 3.07
Power^d^ | | | <0.0001 | 266.92 | −2.08 | 3.07
Linear | | | <0.0001 | 266.92 | −2.08 | 3.07

a BMD and BMDL values for models that do not provide adequate are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the two models providing adequate fit, the Exponential 5 model had the lowest AIC.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

Table A-8 Results from BMD Analysis (Constant Variance) of Erythrocyte Levels in Female Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 8 Weeks (NTP 1993)

Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Dose near BMD | Control group
Exponential 2^d^ | | | <0.0001 | 78.61 | −2.24 | 3.02
Exponential 3^d^ | | | <0.0001 | 78.61 | −2.24 | 3.02
Exponential 4^d^ | 5.00 | 3.33 | 0.117 | 44.86 | 1.45 | −0.48
Exponential 5^d^ | 8.57 | 4.69 | 0.242 | 43.80 | 0.02 | −0.01
Hill ^d^ ^,^ ^e^ | 8.44 | 5.57 | 0.285 | 43.47 | 0.04 | −0.02
Polynomial Degree 5^d^ | | | <0.0001 | 79.39 | −2.31 | 3.10
Polynomial Degree 4^d^ | | | <0.0001 | 79.39 | −2.31 | 3.10
Polynomial Degree 3^d^ | | | <0.0001 | 79.39 | −2.31 | 3.10
Polynomial Degree 2^d^ | | | <0.0001 | 79.39 | −2.31 | 3.10
Power^d^ | | | <0.0001 | 79.39 | −2.31 | 3.10
Linear | | | <0.0001 | 79.39 | −2.31 | 3.10

a BMD and BMDL values for models that do not provide adequate are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the two models providing adequate fit, the Hill model had the lowest AIC.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

To identify the POD for MRL derivation, a comparison was made of the BMD values (relative liver weight, hematocrit, and erythrocyte levels) and the NOAEL value (absolute liver weight):

- NOAEL of 8 mg/kg for absolute liver weight increases in female rats
- BMD_RD10_ of 19.11 mg/kg for relative liver weight increases in female rats
- BMD_1SD_ of 5.97 mg/kg for decreases in hematocrit levels in female rats
- BMD_1SD_ of 8.44 mg/kg for decreases in erythrocyte levels in female rats

The BMD_1SD_ for hematocrit alterations was selected as the critical endpoint because it was the lowest point estimate. The BMDL_1SD_ value of 4.03 mg/kg for decreased hematocrit levels in female rats administered 1,2,3-trichloropropane for 8 weeks was selected as the basis of the POD for the MRL. The BMDL_1SD_ was estimated by the Exponential 5 model (with constant variance) which is presented in Figure A-1.

Figure A-1 Fit of Exponential 5 Model (with Constant Variance) for Hematocrit Levels in Female Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 8 Weeks (NTP 1993)

Figure A-1 description

Intermittent Exposure: The BMDL_1SD_ of 4.03 mg/kg was adjusted from intermittent exposure to account for a continuous exposure scenario:

BMDL_ADJ_ = 4.03 mg / kg × (5 days / 7 days) = 2.9 mg / kg / day .

Uncertainty Factor: The BMDL_ADJ_ was divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_ADJ_ ÷ UFs 2.9 mg / kg / day ÷ (10 × 10) = 0.029 mg / kg / day ≈ 0.03 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Similar liver and erythrocyte effects have been observed in rats administered 1,2,3-trichloropropane for 15 months (NTP 1993).

Agency Contact (Chemical Manager): Malcolm Williams

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3-Trichloropropane
CAS Numbers: | 96-18-4
Date: | August 2021
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.01 mg/kg/day
Critical Effect: | Bile duct hyperplasia
Reference: | NTP 1993
Point of Departure: | BMDL_10_ of 1.94 mg/kg (BMDL_ADJ_ of 1.38 mg/kg/day)
Uncertainty Factor: | 100
LSE Graph Key: | 14
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.01 mg/kg/day was derived for 1,2,3-trichloropropane based on an increased incidence of bile duct hyperplasia in male rats administered gavage doses 5 days/week for 15 months (NTP 1993). The MRL is based on a BMDL_10_ of 1.94 mg/kg, which was adjusted to continuous duration exposure to a BMDL_ADJ_ of 1.38 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: The oral toxicity of 1,2,3-trichloropropane following chronic-duration exposure has been investigated in rats and mice (NTP 1993). The rats and mice were administered via gavage 1,2,3-trichloropropane in corn oil 5 days/week for up to 2 years. Decreased survival was observed in rats administered 10 or 30 mg/kg and a decrease in body weight gain (15%) was observed in females at 30 mg/kg. A number of non-neoplastic and neoplastic alterations were observed. Neoplastic lesions were observed at ≥3 mg/kg and included squamous cell papillomas or carcinomas in the forestomach and adenomas of the pancreas at ≥3 mg/kg; squamous cell papillomas or carcinomas in oral mucosa, adenoma in renal tubules, adenoma or carcinoma of the clitoral gland, and adenocarcinoma of the mammary gland (females only) at ≥10 mg/kg; and adenoma or carcinoma in preputial gland and carcinoma in Zymbal’s gland (females only) at 30 mg/kg. Non-neoplastic target tissues included esophagus, tongue, hematopoietic tissues, liver and bile duct, kidney, pancreas, and testis; however, some of observed lesions were considered precancerous or were secondary to cancerous lesions. A summary of the effects and NOAEL and LOAEL values for the non-neoplastic lesions is presented in Table A-9. NTP (1993) considered the hematological effects to likely be due to depressed hematopoiesis or by blood loss from neoplasms in the forestomach or oral mucosa. NTP (1993) noted that hyperplasia observed in the pancreas was part of the morphological continuum to adenoma to adenocarcinoma, and focal hyperplasia in the kidney and renal adenomas constituted a morphological continuum. The bile duct hyperplasia and nephropathy effects do not appear to be associated with carcinogenicity and were considered as possible critical effects for the MRL.

Table A-9 Summary of the Results of the NTP (1993) Chronic-Duration Rat Study^a^

| NOAEL (mg/kg) | LOAEL (mg/kg) | Effect
Body weight | 3 | 10 | 15% decrease in body weight gain in females
Gastrointestinal | 3 | 10 | Hyperkeratosis of esophagus Acute inflammation of tongue in females (males at 30 mg/kg)
Hematological | 3 | 10 | Hematopoietic cell proliferation in spleen at ≥10 mg/kg Decreased hemoglobin, increased leukocytes, increased segmented neutrophils (measured after 15 months) at 30 mg/kg
Hepatic | 3 | 10 | Increased liver weight at ≥10 mg/kg; Bile duct hyperplasia in males at 10 mg/kg at 15 months, 30 mg/kg at 2 years
Renal | 3 | 10 | Renal tubular hyperplasia and increased severity of nephropathy (males only)
Endocrine | | 3 | Focal hyperplasia of pancreatic acini
Reproductive | 10 | 30 | Interstitial cell hyperplasia in testes

a Rats were administered 1,2,3-trichloropropane 5 days/week for up to 2 years.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

A summary of the hepatic and renal effects observed in rats in the NTP (1993) study are presented in Table A-10. These data clearly demonstrate a LOAEL of 10 mg/kg for increases in the incidences of bile duct hyperplasia in male rats and an increased severity of nephropathy in male rats. The increases in absolute liver and kidney weights in male rats administered 3 mg/kg were considered minimally adverse because the liver and kidney are target tissues and the increases in organ weight may be representative of early-stage adverse effects.

Table A-10 Summary of Hepatic and Renal Effects Observed in Rats Administered 1,2,3-Trichloropropane for 2 Years

| Dose (mg/kg, 5 days/week)
| 0 | 3 | 10 | 30
Hepatic effects
Serum alanine aminotransferase (IU/L)
Males | 99 | 91 (−8.1%)^a^ | 90 (−9.1%) | 68 (−31%)^b^
Females | 58 | 57 (−1.7%) | 65 (12%) | 66 (14%)
Absolute liver weight at 15 months (g)
Males | 14.27 | 15.63^b^ (9.5%) | 16.8^b^ (17.7%) | 18.23^b^ (27.7%)
Females | 7.79 | 8.87^b^ (13.9%) | 9.00^b^ (15.5%) | 10.4^b^ (33.5%)
Relative liver weight at 15 months (mg organ weight/g body weight)
Males | 31.2 | 33.1 (6.1%) | 36^b^ (15.4%) | 39.8^b^ (27.6%)
Females | 30.8 | 30.9 (0.32%) | 34.6^b^ (12.3%) | 43.2^b^ (40.3%)
Bile duct hyperplasia at 15 months
Males | 1/10 | 2/10 | 5/10^c^ | 8/10^c^
Females | 0/10 | 0/10 | 1/8 | 3/8
Bile duct hyperplasia at 2 years
Males | 0/50 | 0/50 | 1/49 | 12/52^c^
Females | 0/50 | 0/49 | 0/52 | 2/52
Renal effects
Absolute kidney weight at 15 months (g)
Males | 1.35 | 1.46^b^ (8.1%) | 1.51^b^ (11.8%) | 1.75^b^ (29.6%)
Females | 0.786 | 0.839 (6.7%) | 0.869^b^ (10.6%) | 0.971^b^ (23.5%)
Relative kidney weight at 15 months (mg organ weight/g body weight)
Males | 2.96 | 3.09 (4.4%) | 3.25^b^ (9.8%) | 3.82^b^ (29.0%)
Females | 3.08 | 2.93 (−4.9%) | 3.34^b^ (8.4%) | 4.04^b^ (31.2%)
Nephropathy at 2 years
Males | 48/50 (2.0)^d^ | 50/50 (2.0) | 48/49 (2.6) | 52/52 (2.4)
Females | 18/50 | 21/47 | 17/52 | 5/51

a Percent differences from controls.

b Significantly different (p≤0.05) from controls.

c Significantly different (p≤0.05) from controls; Fisher Exact Test performed by ATSDR.

d Mean severity score; 1=minimal (<25% renal tubules involved), 2=mild (25–50% involvement), 3=moderate (50– 75% involvement) and 4=marked (>75% involvement).

Source: NTP 1993

The toxicity of 1,2,3-trichloropropane appears to differ in mice, as compared to rats. A decrease in survival was observed in mice administered ≥6 mg/kg 5 days/week for 2 years (NTP 1993); a 12–18% decrease in body weight gain was observed at 60 mg/kg. Non-neoplastic effects observed in mice included bronchiole hyperplasia at 60 mg/kg and hepatocellular necrosis at 60 mg/kg. Squamous cell hyperplasia was also observed in the forestomach, but this was part of the continuum to forestomach adenocarcinomas. Likewise, the hematopoietic cell proliferation observed in the spleen at ≥6 mg/kg may have been due to bleeding from the forestomach tumors. Increases in the incidence of neoplastic lesions were observed at all dose levels: squamous cell papilloma or carcinoma in the forestomach and hepatocellular adenoma or carcinoma in males at ≥6 mg/kg; harderian gland adenoma in males at ≥20 mg/kg; squamous cell papilloma or carcinoma in oral mucosa in females, harderian gland adenoma in females, and uterine stromal polyps and endometrial adenoma or adenocarcinoma at 60 mg/kg. The lowest LOAEL in mice for an effect unrelated to carcinogenicity is 60 mg/kg for increases in bronchiole hyperplasia and hepatocellular necrosis.

Selection of the Principal Study: The NTP (1993) rat gavage study was selected as the principal study because it identified the lowest LOAELs for non-carcinogenic effects.

Summary of the Principal Study:

NTP. 1993. Toxicology and carcinogenesis of 1,2,3-trichloropropane (CAS No. 96-18-4) in F344/N rats and B6C3F1 mice (gavage studies). National Toxicology Program. TR384. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr384.pdf. May 19, 2020.

Groups of 60 male and 60 female F344/N rats were administered 0, 3, 10, or 30 mg/kg 1,2,3-trichloro-propane in corn oil by gavage 5 days/week for 2 years. Due to high mortality, rats in the 30 mg/kg groups were terminated after 77 (males) or 67 (females) weeks of exposure. After 15 months of exposure, 10 animals/sex/group were sacrificed. Parameters used to assess toxicity included twice daily clinical observations, body weights (weekly for 13 weeks and monthly thereafter), organ weights (brain, liver, kidney; evaluated at 15 months), hematological and serum clinical chemistry indices (evaluated at 15 months), and histopathology of major tissues and organs.

Significant decreases in survival were observed in rats at 10 and 30 mg/kg; mean survival days were 596 and 465 days in the 10 mg/kg males and females, respectively, and 580 and 366 days in the 30 mg/kg males and females, respectively, compared to 647 and 649 days in control males and females, respectively. In rats dying early, emaciation, lethargy, diarrhea, dyspnea, and tissue masses were observed; most of these signs were attributed to neoplasms of the oral mucosa or forestomach. No compound-related clinical signs were observed. Small decreases in body weight gain (<5%) were observed at 30 mg/kg in males; in females, body weight in the last year of the study was 15% lower than controls. Increases in absolute liver weights were observed at ≥3 mg/kg; relative liver weights were observed at ≥10 mg/kg. Increases in absolute kidney weights were observed at ≥3 mg/kg in males and ≥10 mg/kg in females; increases in relative kidney weights were observed at ≥10 mg/kg. Decreased hemoglobin levels were observed at 30 mg/kg; increases in leukocytes and segmented neutrophils were also observed at this dose level. Hematopoietic cell proliferation was observed at 10 and 30 mg/kg. Histological alterations were observed in the oral mucosa (pharynx and tongue), forestomach, pancreas, liver, kidney, preputial gland, clitoral gland, mammary gland, Zymbal’fs gland, and intestines. Acute inflammation was observed in the tongue of male rats treated with 30 mg/kg and female rats at 10 mg/kg. Oral mucosal lesions consisted of squamous cell papillomas or carcinomas at 10 mg/kg (37 and 54% in males and females, respectively) and 30 mg/kg (77 and 62% in males and females, respectively), but not at 3 mg/kg (8 and 12% in males and females, respectively) or controls (2 and 2% in males and females, respectively). Hyperkeratosis of the esophagus was observed in males at 30 mg/kg and females at ≥10 mg/kg. Squamous cell papillomas or carcinomas were also observed in the forestomach at 3 (20 and 33% in males and females, respectively), 10 mg/kg (40 and 63% in males and females, respectively), and 30 mg/kg (83 and 37% in males and females, respectively); no tumors were observed in controls. Increases in the incidence of forestomach tumors were also observed in the 10 and 30 mg/kg groups after 15 months of exposure. In the pancreas, focal hyperplasia of pancreatic acini was observed at ≥3 mg/kg/day (56, 92, 94, and 92% in males at 0, 3, 10, or 30 mg/kg and 10, 29, 46, and 17% in females) and adenomas were observed in males at ≥3 mg/kg (10, 42, 73, and 56% in males and 0, 0, 4, and 0% in females); the investigators noted that there was a morphologic continuum from the acinar hyperplasia to adenomas. Bile duct hyperplasia was observed in males at 10 and 30 mg/kg after 15 months and at 30 mg/kg after 2 years. Renal tubular hyperplasia in males at ≥10 mg/kg and females at 30 mg/kg; an increase in nephropathy was observed in males at 10 or 30 mg/kg, although the incidence was similar to controls (98–100% compared to 96% in controls). The mean severity scores were 2.0, 2.0, 2.6, and 2.4 in the 0, 3, 10, and 30 mg/kg groups, respectively. An increase in the incidence of adenomas in the kidneys was observed in males at 10 and 30 mg/kg; an increased incidence was also observed in the 30 mg/kg group after 15 months of exposure. Significant increases in the incidence of adenoma or carcinoma were observed in the preputial gland at 30 mg/kg and in the clitoral gland at ≥10 mg/kg. In females, increases in the incidence of adenocarcinomas of the mammary gland were observed at 10 and 30 mg/kg. An increased incidence on Zymbal’s gland carcinoma was observed in females at 30 mg/kg. Adenomatous polyps or adenocarcinomas were observed in the 30 mg/kg group; although the incidence was not statistically higher than controls, the investigators considered them to be treatment-related given the rarity of the lesion in historical controls and the decreased survival in rats in this group. In the testes, interstitial cell hyperplasia was observed at 30 mg/kg.

Selection of the Point of Departure for the MRL: Exposure data for several endpoints were considered as the POD for the MRL: increases in absolute liver weight at 15 months, bile duct hyperplasia at 15 months, increases in absolute kidney weight at 15 months, and increases in the severity of nephropathy in male rats at 2 years. The 15-month data were used for liver and kidney weights because organ weights were not assessed at 2 years; 15-month incidence data for bile duct hyperplasia were used because the LOAEL was lower than after 2 years of exposure.

BMD modeling was attempted for the increases in absolute liver and kidney weights and for bile duct hyperplasia; because only mean severity scores were reported for nephropathy, the data were not suitable for BMD modeling. The absolute liver and kidney weight data (Table A-11) were fit to all available continuous models in EPA’s BMDS (version 3.1.2) and bile duct hyperplasia incidence data (Table A-11) were fit to all dichotomous models in EPA’s BMDS (version 3.1.2) using the extra risk option. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residual at the data point (except the control) closest to the predefined BMR, a BMDL that was not 10 times lower than the lowest non-zero dose, and visual inspection of the dose-response curve. A BMR of 10% change from the control was used for liver and kidney weights; a BMR of 10% was used for the bile duct hyperplasia incidence data.

Table A-11 Summary of Absolute Liver Weight, Absolute Kidney Weight, and Bile Duct Hyperplasia in Male Rats Following 15-Month Oral Exposure to 1,2,3-Trichloropropane

Dose (mg/kg)^b^ | Number of rats | Mean±standard deviation^a^ | | Incidence of bile duct hyperplasia
Dose (mg/kg)^b^ | Number of rats | Absolute liver weight (g) | Absolute kidney weight (g) | Incidence of bile duct hyperplasia
0 | 10 | 14.27±1.17 | 1.35±0.095 | 1/10
3 | 10 | 15.63±1.17 | 1.46±0.126 | 2/10
10 | 10 | 16.80±1.52 | 1.51±0.095 | 5/10
30 | 8 | 18.23±1.47 | 1.75±0.141 | 8/8

a Mean±standard deviation; standard deviations estimated from reported standard error of the mean (SEM).

b Animals administered 1,2,3-trichloropropane via gavage 5 days/week.

Source: NTP 1993

The model predictions for increases in absolute liver weight are presented in Table A-12. Only three models provided adequate fit to the data (Exponential 4-degree, Exponential 5-degree, and Hill models); the other models had goodness-of-fit p-values that were <0.1. Of the models providing adequate fit, the Hill model was recommended because it had the lowest AIC.

Table A-12 Results from BMD Analysis (Constant Variance) of Absolute Liver Weight in Male Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 15 Months (NTP 1993)

Model | BMD_RD10_^a^ (mg/kg) | BMDL_RD10_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_RD10_^a^ (mg/kg) | BMDL_RD10_^a^ (mg/kg) | Test 4 p-value^b^ | AIC | Dose near BMD | Control group
Exponential 2^d^ | | | 0.0325 | 138.38 | 1.58 | −1.73
Exponential 3^d^ | | | 0.0325 | 138.38 | 1.58 | −1.73
Exponential 4^d^ | 4.33 | 2.18 | 0.5079 | 133.96 | 0.50 | −0.25
Exponential 5^d^ | 4.36 | 2.17 | 0.5078 | 133.96 | 0.50 | −0.25
Hill ^d^ ^,^ ^e^ | 3.77 | 1.60 | 0.6766 | 133.70 | 0.28 | −0.10
Polynomial Degree 3^d^ | | | 0.0456 | 137.70 | 1.48 | −1.62
Polynomial Degree 2^d^ | | | 0.0456 | 137.70 | 1.48 | −1.62
Power^d^ | | | 0.0456 | 137.70 | 1.48 | −1.62
Linear | | | 0.0456 | 137.70 | 1.48 | −1.62

a BMD and BMDL values for models that do not provide adequate are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Restricted model.

e Recommended model. Constant variance model provided adequate fit to variance data. With constant variance model applied, the only models that provided adequate fit to the means were the Exponential 4 and 5 models (the Exponential 5 converged on to the Exponential 4) and the Hill model. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with lowest AIC was selected (Hill).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _RD10_ = exposure dose associated with a 10% relative deviation from control)

All BMD models provided adequate fit to the absolute kidney weight data (with constant variance); the model outputs are presented in Table A-13. The BMDLs were sufficiently close (<3-fold difference) and the model with the lowest AIC (Linear model) was selected.

Table A-13 Results from BMD Analysis (Constant Variance) of Absolute Kidney Weight in Male Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 15 Months (NTP 1993)

Model | BMD_RD10_ (mg/kg) | BMDL_RD10_ (mg/kg) | Test 4 p-value^a^ | AIC | Scaled residuals^b^
Model | BMD_RD10_ (mg/kg) | BMDL_RD10_ (mg/kg) | Test 4 p-value^a^ | AIC | Dose near BMD | Control group
Exponential 2^c^ | 12.21 | 10.07 | 0.283 | −52.55 | 0.21 | −1.12
Exponential 3^c^ | 12.21 | 10.06 | 0.283 | −52.55 | 0.21 | −1.12
Exponential 4^c^ | 8.77 | 4.59 | 0.176 | −51.24 | −0.48 | −0.64
Exponential 5^c^ | 8.77 | 4.59 | 0.176 | −51.24 | −0.48 | −0.64
Hill^c^ | 8.61 | 4.08 | 0.180 | −51.27 | −0.51 | −0.61
Polynomial Degree 3^c^ | 11.22 | 9.00 | 0.328 | −52.84 | 0.04 | −0.99
Polynomial Degree 2^c^ | 11.22 | 9.00 | 0.328 | −52.84 | 0.04 | −0.99
Power^c^ | 11.22 | 9.00 | 0.328 | −52.84 | 0.04 | −0.99
Linear ^d^ | 11.22 | 9.00 | 0.328 | −52.84 | 0.04 | −0.99

a Values <0.1 fail to meet adequate fit.

b Scaled residuals for dose group near the BMD and for the control dose group.

c Restricted model.

d Recommended model. Constant variance model provided adequate fit to variance data. With constant variance model applied, all models provided adequate fit to the means. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with lowest AIC was selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _RD10_ = exposure dose associated with a 10% relative deviation from control)

All of the dichotomous models in BMD software provided adequate fit to the bile duct hyperplasia incidence data; model outputs are summarized in Table A-14. The BMDL values were within 3-fold of each; thus, the model with the lowest AIC (Probit) was selected.

Table A-14 Results from BMD Analysis of Bile Duct Hyperplasia Incidence in Male Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 15 Months (NTP 1993)

Model | BMD_10_ (mg/kg) | BMDL_10_ (mg/kg) | Test 4 p-value^a^ | AIC | Scaled residuals^b^
Model | BMD_10_ (mg/kg) | BMDL_10_ (mg/kg) | Test 4 p-value^a^ | AIC | Dose near BMD | Control group
Dichotomous Hill | 8.96 | 1.53 | 0.531 | 36.77 | 0.00 | −0.44
Gamma^c^ | 6.05 | 0.96 | 0.541 | 36.76 | 0.44 | −0.41
Log-Logistic^d^ | 8.96 | 1.53 | 0.822 | 34.77 | 0.00 | −0.44
Multistage Degree 3^e^ | 2.90 | 0.98 | 0.940 | 36.38 | 0.04 | −0.02
Multistage Degree 2^e^ | 3.56 | 0.99 | 0.730 | 36.54 | 0.19 | −0.09
Multistage Degree 1^e^ | 1.32 | 0.79 | 0.503 | 36.43 | 0.30 | 0.30
Weibull^c^ | 4.31 | 0.99 | 0.679 | 36.56 | 0.30 | −0.21
Logistic | 3.25 | 2.03 | 0.940 | 34.57 | 0.16 | 0.01
Log-Probit | 8.19 | 1.56 | 0.531 | 36.77 | 0.00 | −0.44
Probit ^f^ | 3.04 | 1.94 | 0.975 | 34.45 | 0.10 | 0.01

a Values <0.1 fail to meet adequate fit.

b Scaled residuals for dose group near the BMD and for the control dose group.

c Restricted model.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Recommended model. All models provided adequate fit to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with lowest AIC was selected (Probit).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% relative deviation from control)

To identify the POD for MRL derivation, a comparison was made of the BMD values (absolute liver weight, absolute kidney weight, and bile duct hyperplasia) and the NOAEL for nephropathy severity:

- BMD_RD10_ of 3.77 mg/kg for absolute liver weight increases in male rats
- BMD_RD10_ of 11.22 mg/kg for absolute kidney weight increases in male rats
- BMD_10_ of 3.04 mg/kg for increases in incidence of bile duct hyperplasia in male rats at 15 months
- NOAEL of 3 mg/kg for increases in severity of nephropathy in male rats

The lowest BMD was 3.04 mg/kg for bile duct hyperplasia; this value is essentially the same as the NOAEL for increases in the severity of nephropathy. The bile duct hyperplasia was selected as the critical effect because its POD takes into consideration responses over a range of doses as compared to the NOAEL for nephropathy which only considers the response at a single dose level. The BMDL_10_ for bile duct hyperplasia estimated from the Probit model is 1.94 mg/kg; this value was selected as the POD for the MRL. The fit of the Probit model is presented in Figure A-2.

Figure A-2 Fit of Probit Model for Bile Duct Hyperplasia in Male Rats Administered 1,2,3-Trichloropropane 5 Days/Week for 15 Months (NTP 1993)

Figure A-2 description

Intermittent Exposure: The BMDL_10_ of 1.94 mg/kg was adjusted for intermittent exposure (5 days/7 days) resulting in adjusted value of 1.38 mg/kg/day.

BMDL_ADJ_ = 1.94 mg/kg × (5 days / 7 days) = 1.38 mg / kg / day

Uncertainty Factor: The BMDL_ADJ_ was divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_ADJ_ ÷ UFs 1.38 mg / kg / day ÷ (10 × 10) = 0.01 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Identification of the liver and kidney as sensitive targets of toxicity is supported by intermediate-duration oral studies, which also found increases in liver and kidney weights, bile duct hyperplasia, and regenerative tubular hyperplasia in rats exposed for up to 17 weeks (NTP 1993).

Agency Contact (Chemical Manager): Malcolm Williams