# 9 REFERENCES

* Not cited in text

Abbas R, Fisher JW. 1997. A physiologically based pharmacokinetic model for trichloroethylene and its metabolites, chloral hydrate, trichloroacetate, dichloroacetate, trichloroethanol, and trichloroethanol glucuronide in B6C3F1 mice. Toxicol Appl Pharmacol 147(1):15–30.9356303
Abbas RR, Seckel CS, Kidney JK, . 1996. Pharmacokinetic analysis of chloral hydrate and its metabolism in B6C3F1 mice. Drug Metab Dispos 24(12):1340–1346.8971140
Abbas R, Seckel CS, MacMahon KL, . 1997. Determination of kinetic rate constants for chloral hydrate, trichloroethanol, trichloroacetic acid and dichloroacetic acid: A physiologically based modeling approach. Toxicologist 36:32–33.
Abelson PH. 1993. Health risk assessment. Regul Toxicol Pharmacol 17:219–223.8484029
Abrahamsson K, Ekdahl A, Collen J, . 1995. Marine algae—a source of trichloroethylene and perchloroethylene. Limnol Oceanogr 40:1321–1326.
ACGIH. 2012. Trichloroethylene. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 58, 110.
ACS. 1986. American Chemical Society. Chemcyclopedia 5:116.
Adamek R, Krupinski B. 2007. [Acute intoxication with trichloroethylene--a case report]. Przegl Lek 64(4–5):331–333. http://www.wple.net/plek/numery_2007/numer-4-5-2007/331-333-adamek-tri.pdf. March 31, 2011.17724903
Adami H, Chow W, Nyrén O, . 1996. Excess risk of primary liver cancer in patients with diabetes mellitus. J Natl Cancer Inst 88:1472–1477.8841022
Adams EM, Spencer HC, Rowe VK, . 1951. Vapor toxicity of trichloroethylene determined by experiments on laboratory animals. Arch Ind Hyg Occup Med 4:469–481.
Adgate JL, Church TR, Ryan AD, . 2004b. Outdoor, indoor, and personal exposure to VOCs in children. Environ Health Perspect 112(14):1386–1392.15471730
Adgate JL, Eberlly LE, Stroebel C, . 2004a. Personal, indoor, and outdoor VOC exposures in a probability sample of children. J Expo Anal Environ Epidemiol 14:S4–S13.15118740
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
AFRL. 2004. Development of a physiologically-based pharmacokinetic model of trichloroethylene and its metabolites for use in risk assessment. Wright-Patterson AFB, OH: Air Force Research Laboratory. ADA452195.
AIHA. 2011. Trichloroethylene. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. http://www.aiha.org/insideaiha/guidelinedevelopment/erpg/pages/default.aspx. October 31, 2011.
*Air Force. 1990. Development and validation of methods for applying pharmacokinetic data in risk assessment: Volume II. Trichloroethylene. Wright-Patterson Air Force Base, OH: U.S. Air Force, Air Force Systems Command, Harry G. Armstrong Medical Research Laboratory, Human Systems Division. ADA237366.
Albee RR, Nitschke KD, Mattsson JL, . 1997. Dichloroacetylene: Effects on the rat trigeminal nerve somatosensory evoked potential. Neurotoxicol Teratol 19(1):27–37.9088008
Albee RR, Spencer PJ, Johnson KA, . 1993. Initial submission: Neurotoxicological examination of rats exposed to trichloroethylene vapor for 13 weeks with cover letter dated 100193. Halogenated Solvents Industry Alliance. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0572050. 8EHQ-1093-12721S.
Albee RR, Spencer PJ, Johnson KA, . 2006. Lack of trigeminal nerve toxicity in rats exposed to trichloroethylene vapor for 13 weeks. Int J Toxicol 25(6):531–540.17132611
Alexander DD, Kelsh MA, Mink PJ, . 2007. A meta-analysis of occupational trichloroethylene exposure and liver cancer. Int Arch Occup Environ Health 81:127–143. 10.1007/s00420-007-0201-4.17492303
Alexander DD, Mink PJ, Mandel JH, . 2006. A meta-analysis of occupational trichloroethylene exposure and multiple myeloma or leukaemia. Occup Med (Lond) 56(7):485–493. 10.1093/occmed/kql083.16905622
Allemand H, Pessayre D, Descatoire V, . 1978. Metabolic activation of trichloroethylene into a chemically reactive metabolite toxic to the liver. J Pharmacol Exp Ther 204:714–723.633075
Allen BC, Fisher JW. 1993. Pharmacokinetic modeling of trichloroethylene and trichloroacetic acid in humans. Risk Anal 13:71–86.8451462
Allen JW, Collins BW, Evansky PA. 1994. Spermatid micronucleus analyses of trichloroethylene and chloral hydrate effects in mice. Mutat Res 323:81–88.7508572
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology.
Alvarez-Cohen L, McCarty PL. 1991a. Effects of toxicity, aeration and reductant supply on trichloroethylene transformation by a mixed methanotrophic culture. Appl Environ Microbiol 57:228–235.2036009
Alvarez-Cohen L, McCarty PL. 1991b. Product toxicity and cometabolic competitive inhibition modeling of chloroform and trichloroethylene transformation by methanotrophic resting cells. Appl Environ Microbiol 57:1031–1037.1905516
Alwis KU, Blount BC, Britt AS, . 2012. Simultaneous analysis of 28 urinary VOC metabolites using ultra high performance liquid chromatography coupled with electrospray ionization tandem mass spectrometry (UPLC-ESI/MSMS). Anal Chim Acta 750:152–160.23062436
Amacher DE, Zelljadt I. 1983. The morphological transformation of Syrian hamster embryo cells by chemicals reportedly nonmutagenic to Salmonella typhimurium. Carcinogenesis 4:291–295.6339095
An YJ, Kampbell DH, Weaver JW, . 2004. Natural attenuation of trichloroethene and its degradation products at a lake-shore site. Environ Pollut 130(3):325–335.15182966
Anagnostopoulos G, Sakorafas GH, Grigoriadis K, . 2004. Hepatitis caused by occupational chronic exposure to trichloroethylene. Acta Gastroenterol Belg 67(4):355–357.15727081
Andelman JB. 1985a. Human exposures to volatile halogenated organic chemicals in indoor and outdoor air. Environ Health Perspect 62:313–318.4085436
Andelman JB. 1985b. Inhalation exposure in the home to volatile organic contaminants of drinking water. Sci Total Environ 47:443–460.4089611
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andersen ME, Gargas ML, Jones RA, . 1980. Determination of the kinetic constants for metabolism of inhaled toxicants in vivo using gas uptake measurements. Toxicol Appl Pharmacol 54:100–116.7394779
Anderson BJ, McKee AD, Holford NH. 1997. Size, myths and the clinical pharmacokinetics of analgesia in paediatric patients. Clin Pharmacokinet 33(5):313–327.9391745
Anderson C, Sundberg K, Groth O. 1986. Animal model for assessment of skin irritancy. Contact Dermatitis 15:143–151.3780215
Anna CH, Maronpot RR, Pereira MA, . 1994. Ras proto-oncogene activation in dichloroacetic acid-, trichloroethylene- and tetrachloroethylene-induced liver tumors in B6C3F1 mice. Carcinogenesis 15:2255–2261.7955063
*Annau Z. 1981. The neurobehavioral toxicity of trichloroethylene. Neurobehav Toxicol Teratol 3:417–424.6278343
Anonymous. 2005. Errata to Environ Health Perspect 111(3):289-292. Environ Health Perspect 113(1):A18.
Anonymous. 2014. Erratum: Erratum for Johnson et al. [Environ Health Perspect 113:A18 (2005)]. (Erratum to Environ Health Perspect 111(Mar):289-292). Environ Health Perspect 122(4):A94.
Anttila A, Pukkala E, Sallmén M, . 1995. Cancer incidence among Finnish workers exposed to halogenated hydrocarbons. J Occup Environ Med 37:797–806.7552463
Antoine SR, DeLeon IR, O’Dell-Smith RM. 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
APHA. 1985. Standard methods for the examination of water and wastewater, 16th ed. American Public Health Association, American Water Works Association and Water Pollution Control Federation. Washington, DC, 591–602.
APHA. 1998a. 6200B. Purge and trap capillary-column gas chromatographic/mass spectrometric method. In: Standard methods for the examination of water and wastewater. Washington, DC: American Public Health Association, American Water Works Association, Water Environment Federation. 20th ed. 6-21 to 6-26.
APHA. 1998b. 6200C. Purge and trap capillary-column gas chromatographic method. In: Standard methods for the examination of water and wastewater. Washington, DC: American Public Health Association, American Water Works Association, Water Environment Federation. 20th ed. 6-26 to 6-30.
Aranda-Rodriguez R, Cabecinha A, Harvie J, . 2015. A method for quantification of volatile organic compounds in blood by SPME-GC-MS/MS with broader application: From non-occupational exposure population to exposure studies. J Chromatogr B Analyt Technol Biomed Life Sci 992:76–85. 10.1016/j.jchromb.2015.04.020.
Aranyi C, O’Shea WJ, Graham JA, . 1986. The effects of inhalation of organic chemical air contaminants on murine lung host defenses. Fundam Appl Toxicol 6:713–720.3519345
Arezzo JC, Simson R, Brennan NE. 1985. Evoked potentials in the assessment of neurotoxicity in humans. Neurobehav Toxicol Teratol 7:229–304.
Arito H, Takahashi M, Ishikawa T. 1994a. Effect of subchronic inhalation exposure to low-level trichloroethylene on heart rate and wakefulness-sleep in freely moving rats. Sangyo Igaku 36:1–8.8126932
Arito H, Takahashi M, Sotoyama M, . 1993. Electroencephalographic and autonomic responses to trichloroethylene inhalation in freely moving rats. Arch Toxicol 67:193–199.8494499
Arito H, Takahashi M, Tsuruta H, . 1994b. Age-related changes in electrocardiographic responses to trichloroethylene inhalation in conscious rats. Ind Health 32:129–144.7698902
*Asal NR, Geyer JR, Risser DR, . 1988. Risk factors in renal cell carcinoma. II. Medical history, occupation, multivariate analysis, and conclusions. Cancer Detect Prev 13(3–4):263–279.3266567
Asher WE, Luo W, Campo KW, . 2007. Application of a source apportionment model in consideration of volatile organic compounds in an urban stream. Environ Toxicol Chem 26(8):1606–1613.17702332
Astrand I, Ovrum P. 1976. Exposure to trichloroethylene. I. Uptake and distribution in man. Scand J Work Environ Health 4:199–211.
*Astrand I, Gamberale F. 1978. Effects on humans of solvents in the inspiratory air: A method of estimation of uptake. Environ Res 15:1–4.620656
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85:69–201.
Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. Trichloroethene. J Phys Chem Ref Data 1:116.
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470.
Atkinson A, Meeks RG, Roy D. 1993. Increased oxidative stress in the liver of mice treated with trichloroethylene. Biochem Mol Biol Int 31:297–304.8275017
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1994. National Exposure Registry: Trichloroethylene (TCE) subregistry baseline technical report. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
ATSDR. 1995. Adult environmental neurobehavioral test battery. U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry, Atlanta, GA. PB96109012.
ATSDR. 1997. Volatile organic compounds in drinking water and adverse pregnancy outcomes. Interim report. United States Marine Corps Base Camp Lejeune, North Carolina. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. http://tftptf.com/CERCLA/01975.pdf. March 4, 2011.
ATSDR. 1998. Volatile organic compounds in drinking water and adverse pregnancy outcomes: United States Marine Corps Base Camp Lejune, North Carolina. Atlanta, GA: U.S. Department of Health and Human Services. Agency for Toxic Substances and Disease Registry. PB98156540. http://www.tftptf.com/images/CL_DHS_HeaStudy_1998.pdf. December 28, 2011.
ATSDR.. 1999. National Exposure Registry: Trichloroethylene (TCE) subregistry baseline through follow-up 3 technical report. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
ATSDR. 2001. Final Report: Evaluation of priority health conditions in a community with historical contamination by trichloroethylene. Atlanta, GA: U.S. Department of Health and Human Services. Centers for Disease Control and Prevention. Agency for Toxic Substances and Disease Registry.
ATSDR. 2002. Impact of trichloroethylene exposure on oral motor, speech and hearing in children. Atlanta, GA: U.S. Department of Health and Human Services. Centers for Disease Control and Prevention. Agency for Toxic Substances and Disease Registry. PB2004100016.
ATSDR. 2004. Feasibility investigation of worker exposure to trichloroethylene at the View-Master Factory in Beaverton, Oregon. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. PB2005102173. ed. 54. http://www.oregon.gov/DHS/ph/res/viewmaster/tcereport.pdf. February 4, 2011.
ATSDR. 2006. Health consultation: Endicott area investigation: Health statistics review: Cancer and birth outcome analysis, Endicott area, Town of Union, Broome County, New York. Atlanta, GA: U.S. Department of Health and Human Services. Centers for Disease Control and Prevention. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/HAC/pha/EndicottAreaInvestigation/EndicottHealthStatsReviewHC052606.pdf. May 19, 2011.
ATSDR. 2008. Health consultation: Health statistics review follow-up: Cancer and birth outcome analysis. Endicott area investigation, Endicott area, Town of Union, Broome County, New York. Atlanta, GA: U.S. Department of Health and Human Services. Centers for Disease Control and Prevention. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/HAC/pha//EndicottAreaInvestigationFollowUp/EndicottAreaHC051508.pdf May 19, 2011.
ATSDR. 2011a. ATSDR’s substance-specific priority data needs - being filled via EPA/ATSDR test rule and/or voluntary research. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/pdns/beingfilled.pdf. October 31, 2011.
ATSDR. 2011b. ATSDR’s health survey of Marine Corps personnel and civilians. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/sites/lejeune/health_survey.html. December 26, 2011.
ATSDR. 2017a. Trichloroethylene. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. September 26, 2018.
ATSDR. 2017b. ATSDR Assessment of the evidence for the drinking water contaminants at Camp Lejeune and specific cancers and other diseases. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/sites/lejeune/docs/atsdr_summary_of_the_evidence_for_causality_tce_pce_508.pdf. October 22, 2018.
ATSDR. 2018. Morbidity study of former marines, employees, and dependents potentially exposed to contaminated drinking water at U.S. Marine Corps Base Camp Lejeune. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/sites/lejeune/docs/health_survey_report-508.pdf. December 7, 2018.
*Axelson O. 1986. Epidemiological studies of workers with exposure to tri- and tetrachloroethylenes. In: Chambers PL, Gehring P, Sasaki F, eds. New concepts and developments in toxicology. Proceedings of the 4th International Congress of Toxicology. Amsterdam, The Netherlands: Elsevier Science Publishers, 223–230.
*Axelson O, Andersson K, Hogstedt C, . 1978. A cohort study of trichloroethylene exposure and cancer mortality. J Occup Med 20:194–196.627938
Axelson O, Selden A, Andersson K, . 1994. Updated and expanded Swedish cohort study on trichloroethylene and cancer risk. J Occup Med 36:556–562.8027881
Baden JM, Kelley M, Mazze RI, . 1979. Mutagenicity of inhalation anaesthetics: Trichloroethylene, divinyl ether, nitrous oxide, and cyclopropane. Br J Anaesth 51:417–421.375954
*Bahr DE, Aldrich TE, Seidu D, . 2011. Occupational exposure to trichloroethylene and cancer risk for workers at the Paducah gaseous diffusion plant. Int J Occup Med Environ Health 24(1):67–77.21468904
Bai CL, Stacey NH. 1993. Mechanism of trichloroethylene-induced elevation of individual serum bile acids. II. In vitro and in vivo interference by trichloroethylene with bile acid transport in isolated rat hepatocytes. Toxicol Appl Pharmacol 121:296–302.8346546
Baker AB. 1958. The nervous system in trichloroethylene. An experimental study. J Neuropathol Exp Med 17:649–655.
Baker EL, Letz R, Fidler AT, . 1985. A computer-based neurobehavioral evaluation system for occupational and environmental epidemiology: Methodology and validation studies. Neurobehav Toxicol Teratol 7:369–377.4058646
Bakke B, Stewart PA, Waters MA. 2007. Uses of and exposure to trichloroethylene in U.S. industry: A systematic literature review. J Occup Environ Hyg 4(5):375–390.17454505
*Barbash J, Roberts PV. 1986. Volatile organic chemical contamination of groundwater resources in the U.S. J Water Pollut Control Fed 58:343–348.
Bardodej Z, Vyskocil J. 1956. The problem of trichloroethylene in occupational medicine: Trichloroethylene metabolism and its effect on the nervous system evaluated as a means of hygienic control. AMA Arch Ind Health 56:581–592.
Barkley J, Bunch J, Bursey JT, . 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment. A multimedia environmental study. Biomed Mass Spectrom 7:139–147.7448328
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barret L, Torch S, Leray CL, . 1992. Morphometric and biochemical studies in trigeminal nerve of rat after trichloroethylene or dichloroacetylene oral administration. Neurotoxicology 13:601–614.1282229
Barret L, Torch S, Usson Y, . 1991. A morphometric evaluation of the effects of trichloroethylene and dichloroacetylene on the rat mental nerve. Preliminary results. Neurosci Lett 131:141–144.1762688
Barret MD, Garrel S, Danel V, . 1987. Chronic trichloroethylene intoxication: A new approach by trigeminal-evoked potentials. Arch Environ Health 42:297–302.3452297
*Barrett HM, Cunningham JC, Johnston JH. 1939. Study of fate in organisms of some chlorinated hydrocarbons. J Ind Hyg Toxicol 21:470–490.
Barrio-Lage G, Parsons FZ, Nassar RS. 1987. Kinetics of the depletion of trichloroethene. Environ Sci Technol 21:366–370.22280176
Barrows ME, Petrocelli SR, Macek KJ, . 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Haque R, ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
*Barry KH, Zhang Y, Lan Q, . 2011. Genetic variation in metabolic genes, occupational solvent exposure, and risk of non-Hodgkin lymphoma. Am J Epidemiol 173:404–413.21228414
Barton HA, Bull R, Schultz I, . 1999. Dichloroacetate (DCA) dosimetry: Interpreting DCA-induced liver cancer dose response and the potential for DCA to contribute to trichloroethylene-induced liver cancer. Toxicol Lett 106(1):9–21.10378446
Barton HA, Creech JR, Godin CS, . 1995. Chloroethylene mixtures: Pharmacokinetic modeling and in vitro metabolism of vinyl chloride, trichloroethylene, and trans-1,2-dichloroethylene in rats. Toxicol Appl Pharmacol 130:237–247.7871537
Bartonicek V. 1962. Metabolism and excretion of trichloroethylene after inhalation by human subjects. Br J Ind Med 19:134–141.13865497
*Bartonicek VJ, Brun A. 1970. Subacute and chronic trichloroethylene poisoning: A neuropathological study in rabbits. Acta Pharm Toxicol 28:359–369.
Bartonicek V, Teisinger J. 1962. Effect of tetraethyl thiram disulphide (disulfiram) on metabolism of trichloroethylene in man. Br J Ind Med 19:216–221.
Bartsch H, Malaveille C, Barbin A, . 1979. Mutagenic and alkylating metabolites of halo-ethylenes, chlorobutadienes and dichlorobutenes produced by rodent or human liver tissues. Evidence for oxirane formation by P450-linked microsomal mono-oxygenases. Arch Toxicol 41(4):249–277.373707
Bassig BA, Zhang L, Tang X, . 2013. Occupational exposure to trichloroethylene and serum concentrations of IL-6, IL-10, and TNF-alpha. Environ Mol Mutagen 54:450–454.23798002
Battig K, Grandjean E. 1963. Chronic effects of trichloroethylene on rat behavior. Effects on swimming performance, exploratory behavior, and maze and avoidance learning. Arch Environ Health 7:694–699.14077217
Bauer M, Rabens SF. 1974. Cutaneous manifestations of trichloroethylene toxicity. Arch Dermatol 110:886–890.4280271
Beamer PI, Luik CE, Abrell L, . 2012. Concentration of trichloroethylene in breast milk and household water from Nogales, Arizona. Environ Sci Technol 46(16):9055–9061.22827160
Beliles RP, Brucik DJ, Mecler FJ, . 1980. Teratogenic-mutagenic risk of workplace contaminants: Trichloroethylene, perchloroethylene, and carbon disulfide. U.S. Department of Health, Education and Welfare. Contract No. 210-77-0047.
Bell A. 1951. Death from trichloroethylene in a dry-cleaning establishment. NZ Med J 50:119–126.
Bellar TA, Lichtenberg JJ, Kroner RC. 1974. The occurrence of organohalides in chlorinated drinking waters. J Am Water Works Assoc 66:703–706.
Beltran FJ, Gonzalez M, Rivas FJ, . 1995. Application of photochemical reactor models to UV irradiation of trichloroethylene in water. Chemosphere 31:2873–2885.
*Bentley P, Calder I, Elcombe C, . 1993. Hepatic peroxisome proliferation in rodents and its significance for humans. Food Chem Toxicol 31:857–907.8258416
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Bergman K. 1983a. Application and results of the whole-body autoradiography in distribution studies of organic solvents. CRC Crit Rev Toxicol 12:59–118.
*Bergman K. 1983b. Interactions of trichloroethylene with DNA in vitro and with DNA and RNA in various mouse tissues in vivo. Arch Toxicol 54:181–193.6197950
Berman E, Schlicht M, Moser VC, . 1995. A multidisciplinary approach to toxicological screening: I. Systemic toxicity. J Toxicol Environ Health 45:127–143.7783250
Bernauer U, Birner G, Dekant W, . 1996. Biotransformation of trichloroethene: Dose-dependent excretion of 2,2,2-trichloro-metabolites and mercapturic acids in rats and humans after inhalation. Arch Toxicol 70(6):338–346.8975632
*Bhakuni V, Roy R. 1994. Interaction of trichloroethylene with phosphatidylcholine and its localization in the phosphatidylcholine vesicles: A 1H-NMR study. Biochem Pharmacol 47:1461–1464.8185655
Bhowmick M, Semmens MJ. 1994. Ultraviolet photooxidation for the destruction of VOCs in air. Water Res 28:2407–2415.
Birner G, Bernauer U, Werner M, . 1997. Biotransformation, excretion and nephrotoxicity of haloalkene-derived cysteine S-conjugates. Arch Toxicol 72:1–8.9458184
Birner G, Vamvakas S, Dekant W, . 1993. Nephrotoxic and genotoxic N-acetyl-S-dichlorovinyl-L-cysteine is a urinary metabolite after occupational 1,1,2-trichloroethene exposure in humans: Implications for the risk of trichloroethene exposure. Environ Health Perspect 99:281–284.8319644
*Blain L, Lachapelle P, Molotchnikoff S. 1990. The effect of acute trichloroethylene exposure on electroretinogram components. Neurotoxicol Teratol 12:633–636.2255307
Blain L, Lachapelle P, Molotchnikoff S. 1992. Evoked potentials are modified by long term exposure to trichloroethylene. Neurotoxicology 13:203–206.1508420
Blain L, Lachapelle P, Molotchnikoff S. 1994. Electroretinal responses are modified by chronic exposure to trichloroethylene. Neurotoxicology 15:627–632.7854598
*Blair A, Decoufle P, Grauman D. 1979. Causes of death among laundry and dry cleaning workers. Am J Public Health 69:508–511.434285
Blair A, Hartge P, Stewart PA, . 1998. Mortality and cancer incidence of aircraft maintenance workers exposed to trichloroethylene and other organic solvents and chemicals: Extended follow up. Occup Environ Med 55(3):161–171.9624267
Blanco JG, Harrison PL, Evans WE, . 2000. Human cytochrome P450 maximal activities in pediatric versus adult liver. Drug Metab Dispos 28(4):379–382.10725303
Blankenship A, Chang DPY, Jones AD, . 1994. Toxic combustion by-products from the incineration of chlorinated hydrocarbons and plastics. Chemosphere 28:183–196.
Bloemen LJ, Monster AC, Kezic S, . 2001. Study on the cytochrome P-450- and glutathione-dependent biotransformation of trichloroethylene in humans. Int Arch Occup Environ Health 74(2):102–108.11317702
Blossom SJ, Doss JC. 2007. Trichloroethylene alters central and peripheral immune function in autoimmune-prone MRL(+/+) mice following continuous developmental and early life exposure. J Immunotoxicol 4(2):129–141.18958721
Blossom SJ, Gilbert KM. 2006. Exposure to a metabolite of the environmental toxicant, trichloroethylene, attenuates CD4^+^ T cell activation-induced cell death by metalloproteinase-dependent FasL shedding. Toxicol Sci 92(1):103–114.16641322
Blossom SJ, Cooney CA, Melnyk SB, . 2013. Metabolic changes and DNA hypomethylation in cerebellum are associated with behavioral alterations in mice exposed to trichloroethylene postnatally. Toxicol Appl Pharmacol 269(3):263–269.23566951
Blossom SJ, Doss JC, Gilbert KM. 2007. Chronic exposure to a trichloroethylene metabolite in autoimmune-prone MRL+/+ mice promotes immune modulation and alopecia. Toxicol Sci 95(2):401–411.17077186
Blossom SJ, Doss JC, Hennings LJ, . 2008. Developmental exposure to trichloroethylene promotes CD4+ T cell differentiation and hyperactivity in association with oxidative stress and neurobehavioral deficits in MRL+/+ mice. Toxicol Appl Pharmacol 231(3):344–353.18579175
Blossom SJ, Gilbert K, Gomez-Acevedo H, . 2010. Mechanism of T cell programming by trichloroethylene. Toxicol Lett 196(Suppl 1):S203.
Blossom SJ, Melnyk S, Cooney CA, . 2012. Postnatal exposure to trichloroethylene alters glutathione redox homeostasis, methylation potential, and neurotrophin expression in the mouse hippocampus. Neurotoxicology 33(6):1518–1527.22421312
Blossom SJ, Melnyk SB, Li M, . 2017. Inflammatory and oxidative stress-related effects associated with neurotoxicity are maintained after exclusively prenatal trichloroethylene exposure. Neurotoxicology 59:164–174. 10.1016/j.neuro.2016.01.002.26812193
Blossom SJ, Pumford NR, Gilbert KM. 2004. Activation and attenuation of apoptosis of CD4^+^ T cells following in vivo exposure to two common environmental toxicants, trichloroacetaldehyde hydrate and trichloroacetic acid. J Autoimmun 23:211–220.15501392
*Boekhold AJ, Van der Schee HA, Kaandorp BH. 1989. [Rapid gas-chromatographic determination of trichloroethylene and/or tetrachloroethylene in lettuce by direct headspace analysis.] Z Lebensm Unters Forsch 189:550–553. (German)2609777
*Bogen KT. 1988. Pharmacokinetics for regulatory risk analysis: The case of trichloroethylene. Regul Toxicol Pharmacol 8:447–466.3222486
Bogen KT, Colston BW Jr, Machicao LK. 1992. Dermal absorption of dilute aqueous chloroform, trichloroethylene, and tetrachloroethylene in hairless guinea pigs. Fundam Appl Toxicol 18:30–39.1601207
*Bogen KT, Hall LC, Perry L, . 1988. Health risk assessment of trichloroethylene (TCE) in California drinking water. Livermore, CA: University of California, Lawrence Livermore National Laboratory, Environmental Sciences Division. DE88005364.
Boice JD, Marano DE, Cohen SS, . 2006. Mortality among Rocketdyne workers who tested rocket engines, 1948-1999. J Occup Environ Med 48(10):1070–1092.17033507
Boice JD, Marano DE, Cohen SS, . 2006. Mortality among Rocketdyne workers who tested rocket engines, 1948-1999. J Occup Environ Med 48(Oct):1070–1092. 10.1097/01.jom.0000240661.33413.b5.17033507
Boice JD, Marano DE, Fryzek JP, . 1999. Mortality among aircraft manufacturing workers. Occup Environ Med 56(9):581–597.10615290
Bois FY. 2000a. Statistical analysis of Clewell et al. PBPK model of trichloroethylene kinetics. Environ Health Perspect 108(Suppl 2):307–316.10807560
Bois FY. 2000b. Statistical analysis of Fisher et al. PBPK model of trichloroethylene kinetics. Environ Health Perspect 108(Suppl 2):275–282.10807558
*Bolt HM. 1987. Pharmacokinetic factors and their implication in the induction of mouse liver tumors by halogenated hydrocarbons. Arch Toxicol Suppl 10:190–203.
*Bolt HM. 2003. Genotoxicity—threshold or not? Introduction of cases of industrial chemicals. Toxicol Lett 140–141:43–51.
Bolt HM, Lammert M, Selinski S, . 2004. Urinary α_1_-microglobulin excretion as biomarker of renal toxicity in trichloroethylene-exposed persons. Int Arch Occup Environ Health 77(3):186–190.14986001
Bonse G, Henschler D. 1976. Chemical reactivity, biotransformations and toxicity of polychlorinated aliphatic compounds. CRC Crit Rev Toxicol 10:395–409.
Bonse G, Urban T, Reichert D, . 1975. Chemical reactivity, metabolic oxirane formation, and biological reactivity of chlorinated ethylenes in the isolated perfused rat liver preparation. Biochem Pharmacol 24:1829–1834.1233985
Borzelleca JF, O’Hara TM, Gennings C, . 1990. Interactions of water contaminants. I. Plasma enzyme activity and response surface methodology following gavage administration of CCl_4_ and CHCl_3_ or TCE singly and in combination in the rat. Fundam Appl Toxicol 14:477–490.2340978
Boublík T, Fried V, Hála E. 1984. The vapor pressures of pure substances. Phys Sci Data 17:87–88.
Bourg ACM, Mouvet C, Lerner DN. 1992. A review of the attenuation of trichloroethylene in soils and aquifers. Q J Eng Geol 25:359–370.
*Bouwer EJ, McCarty PL, Bouwer H, . 1984. Organic contaminant behavior during rapid infiltration of secondary wastewater at the Phoenix 23rd Avenue project. Water Res 18:463–472.
Bove FJ, Fulcomer MC, Klotz JB, . 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141:850–862.7717362
Bove FJ, Ruckart PZ, Maslia M, . 2014b. Mortality study of civilian employees exposed to contaminated drinking water at USMC Base Camp Lejeune: A retrospective cohort study. Environ Health 13:68. 10.1186/1476-069X-13-68.25115749
Bove FJ, Ruckart PZ, Maslia M, . 2014a. Evaluation of mortality among marines and navy personnel exposed to contaminated drinking water at USMC Base Camp Lejeune: A retrospective cohort study. Environ Health 13:10. 10.1186/1476-069X-13-10.24552493
Boverhof DR, Krieger SM, Hotchkiss JA, . 2013. Assessment of the immunotoxic potential of trichloroethylene and perchloroethylene in rats following inhalation exposure. J Immunotoxicol 10(3):311–320.23167264
Bowman JP, Jimenez L, Rosario I, . 1993. Characterization of the methanotrophic bacterial community present in a trichloroethylene-contaminated subsurface groundwater site. Appl Environ Microbiol 59:2380–2387.8368829
Boyer AS, Finch WT, Runyan RB. 2000. Trichloroethylene inhibits development of embryonic heart valve precursors in vitro. Toxicol Sci 53(1):109–117.10653528
Boyes WK, Bercegeay M, Ali JS, . 2003. Dose-based duration adjustments for the effects of inhaled trichloroethylene on rat visual function. Toxicol Sci 76(1):121–130.12915717
Boyes WK, Bercegeay M, Krantz T, . 2005. Momentary brain concentration of trichloroethylene predicts the effects on rat visual function. Toxicol Sci 87(1):187–196.15976185
Boyes WK, Bushnell PJ, Crofton KM, . 2000. Neurotoxic and pharmacokinetic responses to trichloroethylene as a function of exposure scenario. Environ Health Perspect 108(Suppl 2):317–322.10807561
*Brass HJ, Feige MA, Halloran T, . 1977. The national organic monitoring survey: Sampling and analyses for purgeable organic compounds. In: Pojasek RB, ed. Drinking water quality enhancement source protection. Ann Arbor, MI: Ann Arbor Science, 393–416.
Brender JD, Shinde MU, Zhan FB, . 2014. Maternal residential proximity to chlorinated solvent emissions and birth defects in offspring: A case-control study. Environ Health 13:96. 10.1186/1476-069x-13-96.25406847
Brenner D. 2010. Results of a long-term study of vapor intrusion at four large buildings at the NASA Ames Research Center. J Air Waste Manag Assoc 60(6):747–758.20565001
Brigmon RL, Bell NC, Freedman DL, . 1998. Natural attenuation of trichloroethylene in rhizosphere soils at the Savannah River Site. J Soil Contam 7(4):433–453.
Brittain GJC. 1948. Trichloroethylene (trilene) as anesthetic in neurosurgery. Anesth Analg 27:145–151.
Briving C, Jacobson I, Hamberger A, . 1986. Chronic effects of perchloroethylene and trichloroethylene on the gerbil brain amino acids and glutathione. Neurotoxicology 7(1):101–108.2872637
Brogren CH, Christensen JM, Rasmussen K. 1986. Occupational exposure to chlorinated organic solvents and its effect on the renal excretion of N-acetyl-beta-D-glucosaminidase. Arch Toxicol Suppl 9:460–464.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. Washington, DC: CV Mosby Company, 143–144.
Bronzetti G, Zeiger E, Frezza D. 1978. Genetic activity of trichloroethylene in yeast. J Environ Pathol Toxicol 1:411–418.363965
Brown RP, Delp MD, Lindstedt SL, . 1997. Physiological parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health 13(4):407–484.9249929
*Brown LP, Farrar DG, de Rooij CG. 1990. Health risk assessment of environmental exposure to trichloroethylene. Regul Toxicol Pharmacol 11:24–41.2184464
Bruckmann P, Kersten W, Funcke W, . 1988. The occurrence of chlorinated and other organic trace compounds in urban air. Chemosphere 17:2363–2380.
*Bruckner JV. 2000. Differences in sensitivity of children and adults to chemical toxicity: The NAS panel report. Regul Toxicol Pharmacol 31(3):280–285.10915586
Bruckner JV, Davis BD, Blancato JN. 1989. Metabolism, toxicity, and carcinogenicity of trichloroethylene. CRC Crit Rev Toxicol 20:31–50.
*Bruckner JV, Weil WB. 1999. Biological factors which may influence an older child’s or adolescent’s responses to toxic chemicals. Regul Toxicol Pharmacol 29(2 Pt 1):158–164.10341146
Brugnone F, Perbellini L, Giuliari M, . 1994. Blood and urine concentrations of chemical pollutants in the general population. Med Lav 85:370–389.7885292
Brüning T, Bolt HM. 2000. Renal toxicity and carcinogenicity of trichloroethylene: Key results, mechanisms and controversies. Crit Rev Toxicol 30(3):253–285.10852497
Brüning T, Pesch B, Wiesenhutter B, . 2003. Renal cell cancer risk and occupational exposure to trichloroethylene: Results of a consecutive case-control study in Arnsberg, Germany. Am J Ind Med 43(3):274–285.12594774
Brüning T, Sundberg AG, Birner G, . 1999. Glutathione transferase alpha as a marker for tubular damage after trichloroethylene exposure. Arch Toxicol 73(4–5):246–254.10463390
*Brüning T, Vamvakas S, Makropoulos V, . 1996. A case of acute intoxication by trichloroethene: Clinical symptoms, toxicokinetics, and renal damage. Naunyn Schmiedebergs Arch Pharmacol 353(4 Suppl.):R109.
Brüning T, Vamvakas S, Makropoulos V, . 1998. Acute intoxication with trichloroethene: Clinical symptoms, toxicokinetics, metabolism, and development of biochemical parameters for renal damage. Toxicol Sci 41(2):157–165.9520351
Brusseau ML, Nelson NT, Zhang Z, . 2007. Source-zone characterization of a chlorinated-solvent contaminated Superfund site in Tucson, AZ. J Contam Hydrol 90(1–2):21–40.17049404
Buben JA, O’Flaherty EJ. 1985. Delineation of the role of metabolism in the hepatotoxicity of trichloroethylene and perchloroethylene: A dose-effect study. Toxicol Appl Pharmacol 78:105–122.2994252
Buhagen M, Gronskag A, Ragde SF, . 2016. Association between kidney cancer and occupational exposure to trichloroethylene. J Occup Environ Med 58(9):957–959. 10.1097/jom.0000000000000838.27465103
Bukowski J. 2014. Critical review of the epidemiologic literature regarding the association between congenital heart defects and exposure to trichloroethylene. Crit Rev Toxicol 44(7):581–589. 10.3109/10408444.2014.910755.24898789
Bull RJ, Templin M, Larson JL, . 1993. The role of dichloroacetate in the hepatocarcinogenicity of trichloroethylene. Toxicol Lett 68:203–211.8516764
Burg JR, Gist GL. 1999. Health effects of environmental contaminant exposure: An intrafile comparison of the Trichloroethylene Subregistry. Arch Environ Health 54(4):231–241.10433181
Burg JR, Gist GL, Allred SL, . 1995. The national exposure registry - morbidity analysis of noncancer outcomes from the trichloroethylene subregistry baseline data. Int J Occup Med Toxicol 4:237–257.
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: A review of past Agency for Toxic Substances and Disease Registry public health evaluations. J Environ Health 75(9):36–41.
Burmaster DE. 1982. The new pollution-groundwater contamination. Environment 24:7–13, 33–36.
Bushnell PJ. 1997. Concentration-time relationships for the effects of inhaled trichloroethylene on signal detection behavior in rats. Fund Appl Toxicol 36:30–38.
Bushnell PJ, Oshiro WM. 2000. Behavioral components of tolerance to repeated inhalation of trichloroethylene (TCE) in rats. Neurotoxicol Teratol 22(2):221–229.10758351
Butler TC. 1949. Metabolic transformation of trichloroethylene. J Pharmacol Exp Ther 97:84–92.18140120
Buxton PH, Hayward M. 1967. Polyneuritis cranials associated with industrial trichloroethylene poisoning. J Neurol Neurosurg Psychiatry 30:511–518.4170824
Byers VS, Levin AS, Ozonoff DM, . 1988. Association between clinical symptoms and lymphocyte abnormalities in a population with chronic domestic exposure to industrial solvent-contaminated domestic water supply and a high incidence of leukemia. Cancer Immunol Immunother 27:77–81.3260823
Cai H, Guengerich FP. 1999. Mechanism of aqueous decomposition of trichloroethylene oxide. 121(50):11656–11663.
Cai H, Guengerich FP. 2000. Acylation of protein lysines by trichloroethylene oxide. Chem Res Toxicol 13(5):327–335.10813648
Cai P, Konig R, Boor PJ, . 2008. Chronic exposure to trichloroethene causes early onset of SLE-like disease in female MRL +/+ mice. Toxicol Appl Pharmacol 228(1):68–75.18234256
Cakmak A, Ekici A, Ekici M, . 2004. Respiratory findings in gun factory workers exposed to solvents. Respir Med 98(1):52–56.14959814
Callen DF, Wolf CR, Philpot RM. 1980. Cytochrome P-450-mediated genetic activity and cytotoxicity of seven halogenated aliphatic hydrocarbons in Saccharomyces cerevisiae. Mutat Res 77:55–63.6767185
*Candura SM, Faustman EM. 1991. Trichloroethylene: Toxicology and health hazards. G Ital Med Lav 13:17–25.1845454
*Capellini A, Grisler R. 1958. [Liver function in workers constantly exposed to trichloroethylene.] Med Lav Um 23:240–248. (Italian)
Caprioli F, Pometta R, Visentin S, . 2001. “Hepatitic flare”, asthenia, peripheral polyneuropathy and diffuse liver steatosis in a hepatitis C virus asymptomatic chronic carrier. Dig Liver Dis 33(4):359–362.11432516
Carlson GP. 1974. Enhancement of the hepatotoxicity of trichloroethylene by inducers of drug metabolism. Res Commun Chem Pathol Pharmacol 7:637–640.4363358
Carney EW, Thorsrud BA, Dugard PH, . 2006. Developmental toxicity studies in Crl:CD (SD) rats following inhalation exposure to trichloroethylene and perchloroethylene. Birth Defects Res B Dev Reprod Toxicol 77(5):405–412.17066414
Carrieri M, Magosso D, Piccoli P, . 2007. Acute, nonfatal intoxication with trichloroethylene. Arch Toxicol 81(7):529–532.17285313
CAS. 2011. Trichloroethylene. American Chemical Society. http://www.commonchemistry.org/ChemicalDetail.aspz?ref=79-01-6. January 25, 2011.
Cavanagh JB, Buxton PH. 1989. Trichloroethylene cranial neuropathy: Is it really a toxic neuropathy or does it activate latent herpes virus? J Neurol Neurosurg Psychiatry 52:297–303.2538571
CDC. 2018. Fourth national report on human exposure to environmental chemicals. Updated tables, March 2018. Centers for Disease Control and Prevention, U. S. Department of Health and Human Services.
Chae HB, Kim JA, Lee KS, . 1999. A case of hepatitis after occupational exposure of trichloroethylene. Korean J Hepatol 5(1):59–64.
Chae HJ, Lee SK, Lee KJ, . 2003. Exfoliative dermatitis and toxic hepatitis associated with occupational exposure to trichloroethylene. Korean J Occup Environ Med 15(1):117–117.
Chakrabarti SK, Tuchweber B. 1988. Studies of acute nephrotoxic potential of trichloroethylene in Fischer-344 rats. J Toxicol Environ Health 23:147–158.3343692
*Chang YM, Tai CF, Yang SC, . 2003. A cohort mortality study of workers exposed to chlorinated organic solvents in Taiwan. Ann Epidemiol 13(9):652–660.14732305
*Chang YM, Tai CF, Yang SC, . 2005. Cancer incidence among workers potentially exposed to chlorinated solvents in an electronics factory. J Occup Health 47(2):171–180.15824483
Channel SR, Pravecek TL. 1998. Metabolism of trichloroethylene in B6C3F1 mouse and human liver slices. Drug Chem Toxicol 21(3):275–289.9706461
Charbotel B, Fevotte J, Hours M, . 2006. Case-control study on renal cell cancer and occupational exposure to trichloroethylene. Part II: Epidemiological aspects. Ann Occup Hyg 50(8):777–787.16840435
*Charbotel B, Gad S, Caiola D, . 2007. Trichloroethylene exposure and somatic mutations of the VHL gene in patients with renal cell carcinoma. J Occup Med Toxicol 2:13. http://www.occup-med.com/content/pdf/1745-6673-2-13.pdf. February 9, 2011.17997830
Charbotel B, Massardier-Pilonchery A, Fort E, . 2013. Occupational trichloroethylene exposure and cervical pathology: A case-control study. Ann Occup Hyg 57(3):407–416. 10.1093/annhyg/mes075.23091111
Chard BK, Doucette WJ, Chard JK, . 2006. Trichloroethylene uptake by apple and peach trees and transfer to fruit. Environ Sci Technol 40(15):4788–4793 16913140
*Charles MJ, Simmons MS. 1987. Recovery studies of volatile organics in sediments using purge/trap methods. Anal Chem 59:1217–1221.
Cheikh Rouhou M, Rheault I, Haddad S. 2013. Modulation of trichloroethylene in vitro metabolism by different drugs in rats. Toxicol in Vitro 27(1):34–43.23089131
ChemIDplus. 2013. Trichloroethylene. Bethesda, MD: U.S. National Library of Medicine. http://chem.sis.nlm.nih.gov/chemidplus/. May 6, 2013.
Chen XM, Dallas CE, Muralidhara S, . 1993. Analyses of volatile C_2_ haloethanes and haloethenes in tissues: Sample preparation and extraction. J Chromatogr 612:199–208.8468377
Chia SE, Goh VH, Ong CN. 1997. Endocrine profiles of male workers with exposure to trichloroethylene. Am J Ind Med 32(3):217–222.9219650
Chia SE, Ong CN, Tsakok MF, . 1996. Semen parameters in workers exposed to trichloroethylene. Reprod Toxicol 10(4):295–299.8829252
Chifflot H, Fautrel B, Sordet C, . 2008. Incidence and prevalence of systemic sclerosis: A systematic literature review. Semin Arthritis Rheum 37(4):223–235.17692364
Chiou GT, Kile DE. 1998. Deviations from sorption linearity on soils of polar and nonpolar organic compounds at low relative concentrations. Environ Sci Technol 32:338–343.
Chittasobhaktra T, Wannanukul W, Wattanakrai P, . 1997. Fever, skin rash, jaundice and lymphadenopathy after trichloroethylene exposure: A case report. J Med Assoc Thai 80(Suppl 1):S144–148.9347662
Chiu WA, Micallef S, Monster AC, . 2007. Toxicokinetics of inhaled trichloroethylene and tetrachloroethylene in humans at 1 ppm: Empirical results and comparisons with previous studies. Toxicol Sci 95(1):23–36.17032701
Chiu WA, Okino MS, Evans MV. 2009. Characterizing uncertainty and population variability in the toxicokinetics of trichloroethylene and metabolites in mice, rats, and humans using an updated database, physiologically based pharmacokinetic (PBPK) model, and Bayesian approach. Toxicol Appl Pharmacol 241(1):36–60.19660485
Chiu WA, Okino MS, Lipscomb JC, . 2006. Issues in the pharmacokinetics of trichloroethylene and its metabolites. Environ Health Perspect 114(9):1450–1456.16966104
Cho HJ, Jaffe PR, Smith JA. 1993. Simulating the volatilization of solvents in unsaturated soils during laboratory and field infiltration experiments. Water Res 29:3329–3342.
Chodola GR, Biswas N, Bewtra JK, . 1989. Fate of selected volatile organic substances in aqueous environment. Wat Poll Res J Can 24:119–142.
*Christensen HE, Luginbyhl TT, Carroll BB. 1974. The toxic substances list 1974. Washington, DC: National Institute for Occupational Safety and Health, 353.
Christensen KY, Vizcaya D, Richardson H, . 2013. Risk of selected cancers due to occupational exposure to chlorinated solvents in a case-control study in Montreal. J Occup Environ Med 55(2):198–208. 10.1097/JOM.0b013e3182728eab.23147555
Christensen JM, Rasmussen K, Koppen B. 1988. Automatic headspace gas chromatographic method for the simultaneous determination of trichloroethylene and metabolites in blood and urine. J Chromatogr 442:317–323.3417822
Cichocki JA, Guyton KZ, Guha N, . 2016. Target organ metabolism, toxicity, and mechanisms of trichloroethylene and perchloroethylene: Key similarities, differences, and data gaps. J Pharmacol Exp Ther 359(1):110–123. 10.1124/jpet.116.232629.27511820
Class T, Ballschmiter K. 1986. Chemistry of organic traces in air. VI: Distribution of chlorinated C_1_-C_4_ hydrocarbons in air over the northern and southern Atlantic Ocean. Chemosphere 15:413–427.
Clay P. 2008. Assessment of the genotoxicity of trichloroethylene and its metabolite, S-(1,2-dichlorovinyl)-L-cysteine (DCVC), in the comet assay in rat kidney. Mutagenesis 23(1):27–33.18003627
Clayton CA, Pellizzari ED, Whitmore RW, . 1999. National Human Exposure Assessment Survey (NHEXAS): Distributions and associations of lead, arsenic and volatile organic compounds in EPA region 5. J Expo Anal Environ Epidemiol 9(5):381–392.10554141
Clearfield HR. 1970. Hepatorenal toxicity from sniffing spot remover (trichloroethylene). Dig Dis 15:851–856.
*Clewell HJ. 2011. Addressing priority data needs for trichloroethylene with physiologically based pharmacokinetic modeling. I: Neurological and developmental toxicity. Monroe, LA: ENVIRON International Corporation. [Unpublished study]
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clewell HJ, Gentry PR, Covington TR, . 2000. Development of a physiologically based pharmacokinetic model of trichloroethylene and its metabolites for use in risk assessment. Environ Health Perspect 108 Suppl 2:283–305.
*Clewell HJ, Gentry PR, Gearhart JM, . 1995. Considering pharmacokinetic and mechanistic information in cancer risk assessments for environmental contaminants: Examples with vinyl chloride and trichloroethylene. Chemosphere 31:2561–2578.7670867
CMR. 1983. Chemical Profile. Trichloroethylene. Chem Market Rep, February 14, 1983.
CMR. 1986. Chemical Profile. Trichloroethylene. Chem Market Rep, January 27, 1986.
CMR. 1989. Chemical Profile. Trichloroethylene. Chem Market Rep, January 23, 1989.
CMR. 1995. Chemical profile: Trichloroethylene. Chem Market Rep, February 6, 1995.
CMR. 1997. Chemical profile: Trichloroethylene. Chem Market Rep, December 8, 1997.
CMR. 2000. Chemical profile: Trichloroethylene. Chem Market Rep, September 25, 2000.
CMR. 2002. Chemical profile: Trichloroethylene. Chem Market Rep, July 22–29, 2002.
CMR. 2005. Chemical profile: Trichloroethylene. Chem Market Rep, July 4–17, 2005.
*Coberly S, Oudiz DJ, Overstreet JW, . 1992. Effects of maternal exposure to trichloroethylene (TCE) on cell proliferation in the mouse preimplantation embryo. Reprod Toxicol 6:241–245.1591481
Cocco P, t’Mannetje A, Fadda D, . 2010. Occupational exposure to solvents and risk of lymphoma subtypes: Results from the Epilymph case-control study. Occup Environ Med 67(5):341–347.20447988
Cocco P, Vermeulen R, Flore V, . 2013. Occupational exposure to trichloroethylene and risk of non-Hodgkin lymphoma and its major subtypes: A pooled InterLymph analysis. Occup Environ Med 70(11):795–802. 10.1136/oemed-2013-101551.23881218
Cohn P, Klotz J, Bove F, . 1994. Drinking water contamination and the incidence of leukemia and non-Hodgkin’s lymphoma. Environ Health Perspect 102:556–561.9679115
*Cojocel C, Beuter W, Müller W, . 1989. Lipid peroxidation: A possible mechanism of trichloroethylene-induced nephrotoxicity. Toxicology 55:131–141.2711399
Cole WJ, Mitchell RG, Salamonsen RF. 1975. Isolation, characterization and quantitation of chloral hydrate as a transient metabolite of trichloroethylene in man using electron gas capture gas chromatography and mass fragmentography. J Pharm Pharmacol 27:167–171.237998
Collins BJ, Goehl TJ, Jameson CW, . 1986. Analytical methods for determination of neat and microencapsulated trichloroethylene in dosing vehicles and whole blood. J Anal Toxicol 10:236–240.3807322
Commandeur JNM, Vermeulen NPE. 1990. Identification of N-acetyl-S-(2,2-dichlorovinyl) and N-acetyl-S-(1,2-dichlorovinyl)-L-cysteine as two regioisomeric mercapturic acids of trichloroethylene in the rat. Chem Res Toxicol 3:212–218.1966701
Commandeur JN, Boogaard PJ, Mulder GJ, . 1991. Mutagenicity and cytotoxicity of two regioisomeric mercapturic acids and cysteine S-conjugates of trichloroethylene. Arch Toxicol 65:373–380.1929851
Conde-Salazar L, Guimaraens D, Romero LV, . 1983. Subcorneal pustular eruption and erythema from occupational exposure to trichloroethylene. Contact Dermatitis 9:235–237.6222880
*Constan AA, Yang RSH, Baker DC, . 1995. A unique pattern of hepatocyte proliferation in F344 rats following long-term exposures to low levels of a chemical mixture of groundwater contaminants. Carcinogenesis 16:303–310.7859362
Cooper GS, Makris SL, Nietert PJ, . 2009. Evidence of autoimmune-related effects of trichloroethylene exposure from studies in mice and humans. Environ Health Perspect 117(5):696–702.19479009
Cooper KW, Hickman KE. 1982. Refrigeration. In: Grayson M, Eckroth P, eds. Kirk-Othmer encyclopedia of chemical technology. 3rd ed. Vol. 20. New York, NY: John Wiley and Sons, Inc., 91–92.
Coopman VA, Cordonnier JA, De Letter EA, . 2003. Tissue distribution of trichloroethylene in a case of accidental acute intoxication by inhalation. Forensic Sci Int 134(2–3):115–119.12850404
Corbett TH, Cornell RG, Enders JL, . 1974. Birth defects among children of nurse anesthetists. Anesthesiology 41:341–344.4412215
*Corbett TH, Hamilton GC, Yoon MK, . 1973. Occupational exposure of operating room personnel to trichloroethylene. Can Anaesth Soc J 20:675–678.4780181
*Cordoer S, Ha M-C, Ayme S, . 1992. Maternal occupational exposure and congenital malformations. Scand J Work Environ Health 18:11–17.
*Cornish HH and Adefuin J. 1966. Ethanol potentiation of halogenated aliphatic solvent toxicity. Am Ind Hyg Assoc J 27:57–61.5920489
Corton JC. 2008. Evaluation of the role of peroxisome proliferator-activated receptor α (PPARα) in mouse liver tumor induction by trichloroethylene and metabolites. Crit Rev Toxicol 38(10):857–875. 10.1080/10408440802209796.18821149
Cosby NC, Dukelow WR. 1992. Toxicology of maternally ingested trichloroethylene (TCE) on embryonal and fetal development in mice and of TCE metabolites on in vitro fertilization. Fundam Appl Toxicol 19:268–274.1516784
Costa AK, Katz ID, Ivanetich KM. 1980. Trichloroethylene: Its interaction with hepatic microsomal cytochrome P-450 in vitro. Biochem Pharmacol 29:433–439.6767486
*Costa G, Merletti F, Segnan N. 1989. A mortality cohort study in a north Italian aircraft factory. Br J Ind Med 46(10):738–743.2818961
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Ann Rev Pharmacol Toxicol 44:87–110. 10.1146/annurev.pharmtox.44.101802.121424.14744240
Costantini AS, Benvenuti A, Vineis P, . 2008. Risk of leukemia and multiple myeloma associated with exposure to benzene and other organic solvents: Evidence from the Italian Multicenter case-control study. Am J Ind Med 51(11):803–811. 10.1002/ajim.20592.18651579
Costas K, Knorr RS, Condon SK. 2002. A case-control study of childhood leukemia in Woburn, Massachusetts: The relationship between leukemia incidence and exposure to public drinking water. Sci Total Environ 300(1–3):23–35.12685468
*Cothern CR, Coniglio WA, Marcus WL. 1986. Estimating risk to human health. Environ Sci Technol 20:111–116.22288794
*Cotruvo JA. 1988. Drinking water standards and risk assessment. Regul Toxicol Pharmacol 8:288–299.3238060
*Coyne LB, Warren JS, Cerbus CS. 1987. An evaluation of a new desorption technique for air sampling sorbent tubes. Am Ind Hyg Assoc J 48:668–670.3618481
Crawford JS, Davies P. 1975. A return to trichloroethylene for obstetrical anaesthesia. Br J Anaesth 47:482–489.1138759
*Crebelli R, Carere A. 1989. Genetic toxicology of 1,1,2-trichloroethylene. Mutat Res 221:11–37.2664493
Crebelli R, Bignami M, Conti L, . 1982. Mutagenicity of trichloroethylene in Salmonella typhimurium TA100. Ann Ist Super Sanita 18(1):117–121.6763484
Crebelli R, Conti G, Conti L, . 1985. Mutagenicity of trichloroethylene, trichloroethanol, and chloral hydrate in Aspergillus nidulans. Mutat Res 155:105–111.3883153
Crofton KM, Zhao X. 1993. Mid-frequency hearing loss in rats following inhalation exposure to trichloroethylene: Evidence from reflex modification audiometry. Neurotoxicol Teratol 15:413–423.8302243
Crofton KM, Zhao X. 1997. The ototoxicity of trichloroethylene: Extrapolation and relevance of high-concentration, short-duration animal exposure data. Fundam Appl Toxicol 38(1):101–106.9268609
Crofton KM, Lassiter TL, Rebert CS. 1994. Solvent-induced ototoxicity in rats: An atypical selective mid-frequency hearing deficit. Hear Res 80:25–30.7852200
*Cronin WJ, Oswald EJ, Shelley ML, . 1995. A trichloroethylene risk assessment using a Monte Carlo analysis of parameter uncertainty in conjunction with physiologically-based pharmacokinetic modeling. Risk Anal 15:555–565.7501875
*Csanady GA, Goen T, Klein D, . 2010. Trichloroacetic acid in urine as biological exposure equivalent for low exposure concentrations of trichloroethene. Arch Toxicol 84(11):897–902.20414643
Cummings BS, Lash LH. 2000. Metabolism and toxicity of trichloroethylene and S-(1,2-dichlorovinyl)-L-cysteine in freshly isolated human proximal tubular cells. Toxicol Sci 53(2):458–466.10696794
Cummings BS, Parker JC, Lash LH. 2001. Cytochrome P450-dependent metabolism of trichloroethylene in rat kidney. Toxicol Sci 60(1):11–19.11222868
*Czirjak L, Pocs E, Szegedi G. 1994. Localized scleroderma after exposure to organic solvents. Dermatology 189:399–401.7873829
Czirjak L, Schlammadinger J, Szegedi G. 1993. Systemic sclerosis and exposure to trichloroethylene. Dermatology 186:236.8453156
Daft JL. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc Off Anal Chem 71:748–760.3417594
Dai Y, Leng S, Li L, . 2009. Effects of genetic polymorphisms of N-Acetyltransferase on trichloroethylene-induced hypersensitivity dermatitis among exposed workers. Ind Health 47(5):479–486.19834256
Dallas CE, Gallo JG, Ramanathan R, . 1991. Physiological pharmacokinetic modeling of inhaled trichloroethylene in rats. Toxicol Appl Pharmacol 110:303–314.1891776
Daniel FB, DeAngelo AB, Stober JA, . 1992. Hepatocarcinogenicity of chloral hydrate, 2-chloroacetaldehyde, and dichloroacetic acid in the male B6C3F1 mouse. Fundam Appl Toxicol 19:159–168.1516771
*Dart RC. 2004. Halogenated hydrocarbons- halogenated solvents. In: Medical toxicology. 3rd ed. Philadelphia, PA: Lippincott Williams & Wilkins, 1339–1341.
*Das RM, Scott JE. 1994. Trichloroethylene-induced pneumotoxicity in fetal and neonatal mice. Toxicol Lett 73:227–239.8091431
David NJ, Wolman R, Milne FJ, . 1989. Acute renal failure due to trichloroethylene poisoning. Br J Ind Med 46:347–349.2751934
Davis SI, Laszlo Pallos L, Wu JQ, . 2005. ATSDR’s trichloroethylene subregistry methods and results: 1989-2000. Arch Environ Occup Health 60(3):130–139.17153085
Dawson BV, Johnson PD, Goldberg SJ, . 1990. Cardiac teratogenesis of trichloroethylene and dichloroethylene in a mammalian model. J Am Coll Cardiol 16:1304–1309.2229779
Dawson BV, Johnson PD, Goldberg SJ, . 1993. Cardiac teratogenesis of halogenated hydrocarbon-contaminated drinking water. J Am Coll Cardiol 21:1466–1472.8473657
DeAngelo AB, Daniel FB, Stober JA, . 1991. The carcinogenicity of dichloroacetic acid in the male B6C3F1 mouse. Fundam Appl Toxicol 16:337–347.2055364
De Baere S, Meyer E, Dirinck I, . 1997. Tissue distribution of trichloroethylene and its metabolites in a forensic case. J Anal Toxicol 21(3):223–227.9171208
Dees C, Travis C. 1993. The mitogenic potential of trichloroethylene in B6C3F1 mice. Toxicol Lett 69:129–137.8212055
Defalque RJ. 1961. Pharmacology and toxicology of trichloroethylene: A critical review of the world literature. Clin Pharmacol Ther 2:665–668.13721182
Deipser A, Stegmann R. 1994. The origin and fate of volatile trace components in municipal solid waste landfills. Waste Manag Res 12:129–139.
*Dekant W. 2001. Does exposure to trichloroethene in low doses constitute a cancer risk to humans? Human Ecol Risk Assess 7(4):657–675.
Dekant W, Berthold K, Vamvakas S, . 1988. Thioacylating intermediates as metabolites of S-(1,2-dichlorovinyl)-L-cysteine and S-(1,2,2-trichlorovinyl)-L-cysteine formed by cysteine conjugate β-lyase. Chem Res Toxicol 1(3):175–178.2979728
Dekant W, Koob M, Henschler D. 1990. Metabolism of trichloroethene--in vivo and in vitro evidence for activation by glutathione conjugation. Chem Biol Interact 73:89–101.2302745
*Dekant W, Martens G, Vamvakas S, . 1987. Bioactivation of tetrachloroethylene. Role of glutathione S-transferase-catalyzed conjugation versus cytochrome P-450-dependent phospholipid alkylation. Drug Metab Dispos Biol Fate Chem 15:702–709.2891489
Dekant W, Metzler M, Henschler D. 1984. Novel metabolites of trichloroethylene through dechlorination reactions in rats, mice and humans. Biochem Pharmacol 33:2021–2027.6743352
Dekant W, Metzler M, Henschler D. 1986a. Identification of S-1,2-dichlorovinyl- N-acetyl-cysteine as a urinary metabolite of trichloroethylene: A possible explanation for its nephrocarcinogenicity in male rats. Biochem Pharmacol 35:2455–2458.3741453
Dekant W, Schulz A, Metzler M, . 1986b. Absorption, elimination and metabolism of trichloroethylene: A quantitative comparison between rats and mice. Xenobiotica 16:143–152.3962335
Dekant W, Vamvakas S, Berthold K, . 1986c. Bacterial β-lyase mediated cleavage and mutagenicity of cysteine conjugates derived from the nephrocarcinogenic alkenes trichloroethylene, tetrachloroethylene, and hexachlorobutadiene. Chem Biol Interact 60:31–45.3536138
Delinsky AD, Bruckner JV, Bartlett MG. 2005. A review of analytical methods for the determination of trichloroethylene and its major metabolites chloral hydrate, trichloroacetic acid and dichloroacetic acid. Biomed Chromatogr 19(8):617–639.15828053
De Roos AJ, Olshan AF, Teschke K, . 2001. Parental occupational exposures to chemicals and incidence of neuroblastoma in offspring. Am J Epidemiol 154(2):106–114.11447042
*Deveaux M, Huvenne J-P. 1987. Identification of solvents of abuse using gas chromatography/fourier transform infrared spectrometry after headspace sampling. Chromatographia 23:626–630.
DeWalle FB, Chian ESK. 1981. Detection of trace organics in well water near a solid waste landfill. J Am Water Works Assoc 73:206–211.
Dhuner KG, Nordqvist P, Renstrom B. 1957. Cardiac irregularities in trichloroethylene poisoning. Acta Anaesthesiol Scand 1:121–135.
Dickson AG, Riley JP. 1976. The distribution of short-chain halogenated aliphatic hydrocarbons in some marine organisms. Mar Pollut Bull 7:167–169.
Dietz EA, Singley KF. 1979. Determination of chlorinated hydrocarbons in water by headspace gas chromatography. Anal Chem 51:1809–1814.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloromethanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates and reactivities of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9:833–838.
Diot E, Lesire V, Guilmot JL, . 2002. Systemic sclerosis and occupational risk factors: A case-control study. Occup Environ Med 59(8):545–549.12151611
Dobaradaran S, Nabizadeh R, Mahvi AH, . 2012. Kinetic and degradation efficiency of trichloroethylene (TCE) via photochemical process from contaminated water. Afr J Biotechnol 11(8):2006–2012.
*Dobkin A, Byles P. 1963. Trichloroethylene anesthesia. Clin Anesth 1:44–65.
*DOE. 2010. Trichloroethylene. Table 3: Protective action criteria (PAC) rev 26 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. September 2010. Oak Ridge, TN: Oak Ridge Institute for Science and Education (ORISE), Office of Emergency Management and Policy, U.S. Department of Energy. http://www.atlintl.com/DOE/teels/teel/Table3.pdf. November 1, 2011.
DOE. 2012. Protective action criteria (PAC). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. April 24, 2013.
Dogui M, Mrizak N, Yacoubi M, . 1991. Trigeminal somatosensory evoked potentials in workers handling trichloroethylene. Neurophysiol Clin 21:95–103.1921942
Dong Y, Liang X, Krumholz LR, . 2009. The relative contributions of abiotic and microbial processes to the transformation of tetrachloroethylene and trichloroethylene in anaerobic microcosms. Environ Sci Technol 43(3):690–697.19245003
Doolittle DJ, Muller G, Scribner HE. 1987. The in vivo-in vitro hepatocyte assay for assessing DNA repair and DNA replication: Studies in the CD-1 mouse. Food Chem Toxicol 25:399–405.3609980
Dorfmueller MA, Henne SP, York RG, . 1979. Evaluation of teratogenicity and behavioral toxicity with inhalation exposure of maternal rats to trichloroethylene. Toxicology 14:153–166.538767
Dosemeci M, Cocco P, Chow WH. 1999. Gender differences in risk of renal cell carcinoma and occupational exposures to chlorinated aliphatic hydrocarbons. Am J Ind Med 36(1):54–59.10361587
Doucette WJ, Chard JK, Fabrizius H, . 2007. Trichloroethylene uptake into fruits and vegetables: three-year field monitoring study. Environ Sci Technol 41(7):2505–2509.17438807
Doust GD, Huang J. 1992. The fate and transport of hazardous chemicals in the subsurface environment. Water Sci Technol 25:169–176.
Driscoll TR, Hamdan HH, Wang G, . 1992. Concentrations of individual serum or plasma bile acids in workers exposed to chlorinated aliphatic hydrocarbons. Br J Ind Med 49:700–705.1419858
*Droz PO, Wu MM, Cumberland WG. 1989a. Variability in biological monitoring of organic solvent exposure. II. Application of a population physiological model. Br J Ind Med 46:547–558.2775674
*Droz PO, Wu MM, Cumberland WG, . 1989b. Variability in biological monitoring of solvent exposure. I. Development of a population physiological model. Br J Ind Med 46:447–460.2765418
D’Souza RW, Bruckner JV, Feldman S. 1985. Oral and intravenous trichloroethylene pharmacokinetics in the rat. J Toxicol Environ Health 15:587–601.4046066
Duffel MW, Jakoby WB. 1982. Cysteine S-conjugate N-acetyltransferase from rat kidney microsomes. Mol Pharmacol 21:444–448.6892478
Dumas S, Parent ME, Siemiatycki J. 2000. Rectal cancer and occupational risk factors: A hypothesis-generating, exposure-based case-control study. Int J Cancer 87:874–879.10956400
Duprat P, Gradiski D. 1980. Cytogenetic effect of trichloroethylene in the mouse as evaluated by the micronucleus test. IRCS Medical Science Library Compendium 8:182.
DuTeaux SB, Berger T, Hess RA, . 2004. Male reproductive toxicity of trichloroethylene: Sperm protein oxidation and decreased fertilizing ability. (Erratum in: Biol Reprod 79:787). Biol Reprod 70(5):1518–1526.14736810
DuTeaux SB, Hengel MJ, DeGroot DE, . 2003. Evidence for trichloroethylene bioactivation and adduct formation in the rat epididymis and efferent ducts. Biol Reprod 69(3):771–779.12724279
Dyksen JE, Hess AF. 1982. Alternatives for controlling organics in groundwater supplies. J Am Water Works Assoc 74:394–403.
*Edling C, Lindberg A, Ulfberg J. 1993. Occupational exposure to organic solvents as a cause of sleep apnea. Br J Ind Med 50:276–279.8457496
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604. 10.1016/j.neuro.2011.12.009.22198708
Elcombe CR. 1985. Species differences in carcinogenicity and peroxisome proliferation due to trichloroethylene: A biochemical human hazard assessment. Arch Toxicol Suppl 8:6–17.4015401
Elcombe CR, Rose MS, Pratt IS. 1985. Biochemical, histological, and ultrastructural changes in rat and mouse liver following the administration of trichloroethylene: Possible relevance to species differences in hepatocarcinogenicity. Toxicol Appl Pharmacol 79:365–376.4035684
Elfarra AA, Anders MW. 1984. Renal processing of glutathione conjugates. Role in nephrotoxicity. Biochem Pharmacol 33:3729–3732.6508831
*Elfarra AA, Jakobson I, Anders MW. 1986. Mechanism of S-(1,2-dichlorovinyl)glutathione-induced nephrotoxicity. Biochem Pharmacol 35:283–288.2867768
El Ghawabi SM, Mansoor MB, El Gamel, . 1973. Chronic trichloroethylene exposure. J Egypt Med Assoc 56:715–724.4618847
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology—diagnosis and treatment of human poisoning. New York, NY: Elsevier, 990–993.
Emmert B, Bunger J, Keuch K, . 2006. Mutagenicity of cytochrome P450 2E1 substrates in the Ames test with the metabolic competent S. typhimurium strain YG7108pin3ERb_5_. Toxicology 228(1):66–76.16978761
*Eng W, Palumbo AV, Sriharan S, . 1991. Methanol suppression of trichloroethylene degradation by Methylosinus trichosporium (OB3b) and methane-oxidizing mixed cultures. Appl Biochem Biotechnol 28/29:887–899.1929390
Ensley BD. 1991. Biochemical diversity of trichloroethylene metabolism. Ann Rev Microbiol 45:283–299.1741617
Entz RC, Hollifield HC. 1982. Headspace gas chromatographic analysis of foods for volatile halocarbons. J Agric Food Chem 30:84–88.
Entz RC, Thomas KW, Diachenko GW. 1982. Residues of volatile halocarbons in foods using headspace gas chromatography. J Agric Food Chem 30:846–849.
EPA. 1979a. Atmospheric distributions, sources and sinks of selected halocarbons, hydrocarbons, SF_6_, and N_2_O. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Laboratory, Office of Research and Development, 24–33. EPA 600379107.
EPA. 1979b. Identification of conventional pollutants. U.S. Environmental Protection Agency. Fed Regist 44:44501–44503.
*EPA. 1979c. Water-related environmental fate of 129 priority pollutants--Vol. 11. Washington, DC: U.S. Environmental Protection Agency, 52-1 to 52-13. EPA440479029b.
*EPA. 1982a. Hazard Profile for Trichloroethylene. Prepared by the Office of Health and Environmental Assessment, Environmental Criteria Office, Cincinnati, OH for the Office of Solid Waste, Washington, DC.
EPA. 1982b. Purgeable halocarbons - method 601. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency. PB83201798. EPA600482057.
EPA. 1982c. Test methods for evaluating solid waste. Physical/chemical methods. Method 8010--halogenated volatile organics. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8010-1 to 8010-12.
EPA. 1982d. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600S383021.
EPA. 1982e. Purgeables - method 624. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency. PB83201798. EPA600482057.
*EPA. 1985a. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.
*EPA. 1985b. Health advisory. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water, September, 1985.
EPA. 1985c. Health assessment document for trichloroethylene-final report. Washington, DC: U.S. Environmental Protection Agency. PB85249696.
*EPA. 1985d. National primary drinking water regulations volatile synthetic organic chemicals. Fed Regist 50:46902.
EPA. 1985e. Survey of trichloroethylene emission sources. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air and Radiation, Office of Air Quality Planning and Standards, 1-1 to 2-8, 2-12. EPA450385021. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000JE3Q.txt. March 4, 2011.
*EPA. 1987a. Addendum to the health assessment document for trichloroethylene: Update carcinogenicity assessment for trichloroethylene. Review draft. June 1987. EPA600882006FA.
*EPA. 1987b. Ground-water monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
*EPA. 1987c. Health Advisories for 25 organics. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. PB87235578.
*EPA. 1987d. Intercomparison of sampling techniques for toxic organic compounds in indoor air. Northrop Services, Inc., Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600487008.
EPA. 1987e. Land disposal restrictions for certain California list hazardous wastes and modifications to the framework. Fed Regist 52:25760–25767.
*EPA. 1987f. List (phase I) of hazardous constituents for ground-water monitoring. U.S. Environmental Protection Agency. Fed Regist 52:25942–25952.
*EPA. 1987g. National primary drinking water regulations-synthetic organic chemicals: Monitoring for unregulated contaminants. U.S. Environmental Protection Agency. Federal Register 52:25690–25717.
*EPA. 1987h. Reportable quantity adjustments. U.S. Environmental Protection Agency. Fed Regist 52:8140–8186.
*EPA. 1987i. Toxic chemical release reporting: Community-right-to-know. U.S. Environmental Protection Agency. Fed Regist 52:21152–21208.
EPA. 1987j. Household products containing methylene chloride and other chlorinated solvents: A “shelf” survey. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1988. Recommendations for and documentations of biological values for use in risk assessment. U.S. Environmental Protection Agency. PB88179874.
*EPA. 1989. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141,142,143.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
*EPA. 1994a. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066F.
EPA. 1994b. Method 8010B. Halogenated volatile organic compounds by gas chromatography. Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.caslab.com/EPA-Methods/PDF/8010B.pdf. May 10, 2013.
EPA. 1994c. Method 8240B. Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.caslab.com/EPA-Methods/PDF/8240B.pdf. May 10, 2013.
EPA. 1995a. Method 502.2. Volatile organic compounds in water by purge and trap capillary column gas chromatography with photoionization and electrolytic conductivity detectors in series. Methods for the determination of organic compounds in drinking water - supplement III. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R95131. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30003E77.txt. June 1, 2011.
EPA. 1995b. Method 524.2. Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. Methods for the determination of organic compounds in drinking water - supplement III. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R95131. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30003E77.txt. June 1, 2011.
EPA. 1995c. Method 551.1. Determination of chlorination disinfection byproducts, chlorinated solvents, and halogenated pesticides/herbicides in drinking water by liquid-liquid extraction and gas chromatography with electron-capture detection. Methods for the determination of organic compounds in drinking water - supplement III. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R95131. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30003E77.txt. June 1, 2011.
EPA. 1996a. Method 8021B. Aromatic and halogenated volatiles by gas chromatography using photoionization and/or electrolytic conductivity detectors. Test methods for evaluating solid waste, physical/chemical methods. U.S. Environmental Protection Agency. SW846. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/8021b.pdf. June 2, 2011.
EPA. 1996b. Method 8260B. Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). Test methods for evaluating solid waste, physical/chemical methods. U.S. Environmental Protection Agency. SW846. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/8260b.pdf. June 2, 2011.
EPA. 1996c. Method 0031. Sampling method for volatile organic compounds (SMVOC). Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/0031.pdf. May 7, 2013.
EPA. 1996d. Method 5021. Volatile organic compounds in soils and other solid matrices using equibrium headspace analysis. Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/5021.pdf. May 7, 2013.
EPA. 1996e. Method 5032. Volatile organic compounds by vacuum distillation. Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/5032.pdf. May 7, 2013.
EPA. 1996f. Method 5030b. Purge-and-trap for aqueous samples. Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/5030b.pdf. May 7, 2013.
EPA. 1996g. Method 5035. Closed-system purge-and-trap and extraction for volatile organics in soil and waste samples. Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/5035.pdf. May 7, 2013.
EPA. 1996h. Method 5041A. Analysis for desorption of sorbent cartridges from volatile organic sampling train (VOST). Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/5041a.pdf. May 7, 2013.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency. EPA630R96012.
EPA. 1998. Notice of availability of draft RCRA waste minimization PBT priority chemical list. U.S. Environmental Protection Agency. Fed Regist 63(216): 60332–60343. http://www.gpo.gov/fdsys. April 24, 2013.
*EPA. 1999. National air toxics program: The integrated urban strategy. U.S. Environmental Protection Agency. Fed Regist 64(137):38706–38740. http://www.gpoaccess.gov/fr/index.html. July 29, 2011.
EPA. 2000. National air pollutant emission trends, 1900-1998. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/trends/trends98/trends98.pdf. May 7, 2013.
EPA. 2001a. Method 601. Purgeable halocarbons. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Pt. 136, App A, Meth 601. http://www.gpo.gov/fdsys/pkg/CFR-2001-title40-vol19/pdf/CFR-2001-title40-vol19-part136-appA.pdf. June 1, 2011.
*EPA. 2001b. Method 1624 revision B. Volatile organic compounds by isotope dilution GC/MS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Pt. 136, App A, Meth 1624. http://www.gpo.gov/fdsys/pkg/CFR-2001-title40-vol19/pdf/CFR-2001-title40-vol19-part136-appA.pdf. June 1, 2011.
*EPA. 2001c. Trichloroethylene health risk assessment: Synthesis and characterization. U.S. Environmental Protection Agency. http://oaspub.epa.gov/eims/eimscomm.getfile?p_download_id=4580. June 2, 2011.
EPA. 2002. OSWER draft guidance for evaluating the vapor intrusion to indoor air pathway from groundwater and soils (subsurface vapor intrusion guidance). U.S. Environmental Protection Agency. http://www.epa.gov/epawaste/hazard/correctiveaction/eis/vapor/complete.pdf. August 27, 2013.
EPA. 2003. Method 5030C. Purge-and-trap for aqueous samples. Test methods for evaluating solid waste, physical/chemical methods. U.S. Environmental Protection Agency. SW846. http://www.epa.gov/osw/hazard/testmethods/pdfs/5030c.pdf. June 2, 2011.
EPA. 2005a. Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens. U.S. Environmental Protection Agency. EPA630R03003F. http://www.epa.gov/raf/publications/pdfs/childrens_supplement_final.pdf. November 22, 2011.
EPA. 2005b. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986).
EPA. 2007a. Method 1624. Revison b-volatile organic compounds by isotope dilution GC/MS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136 App A, Method 1624. http://www.gpo.gov/fdsys/pkg/CFR-2007-title40-vol22/pdf/CFR-2007-title40-vol22-part136-appA.pdf. May 14, 2013.
EPA. 2007b. Method 8261. Volatile organic compounds by vacuum distillation in combination with gas chromatography/mass spectrometry (VD/GC/MS). Test methods for evaluating solid waste, physical/chemical methods. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/8261.pdf. May 7, 2013.
EPA. 2008. Child-specific exposure factors handbook. U.S. Environmental Protection Agency. EPA600R06096F. http://oaspub.epa.gov/eims/eimscomm.getfile?p_download_id=484738. August 11, 2011.
*EPA. 2009a. Air data: Access to air pollution data. U.S. Environmental Protection Agency. http://www.epa.gov/oar/data/index.html. June 2, 2011.
EPA. 2009c. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 74(194):51850–51862. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2009b. Method 524.3. Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. U.S. Environmental Protection Agency. Office of Ground Water and Drinking Water. EPA815B09009. http://www.epa.gov/ogwdw000/methods/pdfs/methods/met524-3.pdf. June 1, 2011.
EPA. 2009d. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. April 24, 2013.
EPA. 2009e. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. April 24, 2013.
EPA. 2010a. CAS 79-01-6. Non-confidential 2006 IUR records by chemical, including manufacturing, processing and use information. U.S. Environmental Protection Agency. http://cfpub.epa.gov/iursearch/index.cfm?err=t#chemical. January 26, 2011.
EPA. 2010b. EPI Suite results for CAS 000079-01-6. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/exposure/pubs/episuitedl.htm. January 26, 2011.
EPA. 2010c. Method 624. Purgeables. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Pt. 136, App A, Meth 624. http://www.gpo.gov/fdsys/pkg/CFR-2010-title40-vol22/pdf/CFR-2010-title40-vol22-part136-appA.pdf. June 1, 2011.
*EPA. 2010d. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/pubs/results78.htm. October 31, 2011.
*EPA. 2010e. Toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15. http://www.gpo.gov/fdsys/pkg/CFR-2010-title40-vol28/pdf/CFR-2010-title40-vol28-chapI-subchapN.pdf. November 2, 2011.
EPA. 2011a. 42 Category summaries. Trichloroethylene. 2005 National emissions inventory data and documentation. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/net/2005inventory.html#inventorydata. May 14, 2013.
EPA. 2011g. Background indoor air concentrations of volatile organic compounds in North American residences (1990-2005): A compilation of statistics for assessing vapor intrusion. U.S. Environmental Protection Agency. http://www.epa.gov/oswer/vaporintrusion/documents/oswer-vapor-intrusion-background-Report-062411.pdf. May 7, 2013.
*EPA. 2011b. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. November 2, 2011.
*EPA. 2011c. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/index1.pdf. November 2, 2011.
EPA. 2011d. Occurrence data accessing unregulated contaminant monitoring data. U.S. Environmental Protection Agency. http://water.epa.gov/lawsregs/rulesregs/sdwa/ucmr/data.cfm. June 2, 2011.
EPA. 2011f. Monitor values report - hazardous air pollutants. U.S. Environmental Protection Agency. http://www.epa.gov/oar/data/hapvals.html. August 11, 2011.
EPA. 2011e. Toxicological review for trichloroethylene. U.S. Environmental Protection Agency. http://www.epa.gov/iris/supdocs/0199index.html. October 30, 2011.
EPA. 2012a. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012b. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/drink/standards/hascience.cfm. April 24, 2013.
EPA. 2012c. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012d. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012e. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012f. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012g. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012h. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012i. Toxic Substances Control Act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.30. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012j. Toxic Substances Control Act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2013c. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/. April 24, 2013.
*EPA. 2013a. Air toxics data. Trichloroethylene. Air toxics-data analysis. U.S. Environmental Protection Agency. http://www.epa.gov/ttnamti1/toxdat.html#data. May 14, 2013.
EPA. 2013d. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. April 24, 2013.
EPA. 2013e. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=124:1. April 24, 2013.
EPA. 2013f. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/mtl.html. April 24, 2013.
EPA. 2013g. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. April 24, 2013.
EPA. 2013b. Trichloroethylene. 2008 National emissions inventory data. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/net/2008inventory.html. May 14, 2013.
EPA. 2014a. TSCA workplan chemical risk assessment. Trichloroethylene: Degreasing, spot cleaning, and arts & crafts uses. U.S. Environmental Protection Agency. EPA740R14002. http://www.epa.gov/oppt/existingchemicals/pubs/TCE_OPPTWorkplanChemRA_FINAL_062414.pdf. September 29, 2014.
EPA. 2014b. TCE Developmental cardiac toxicity assessment update. U.S. Environmental Protection Agency. EPA-HQ-OPPT-2012-0723-0045. http://www.noticeandcomment.com/TCE-Developmental-Cardiac-Toxicity-Assessment-Update-fn-148249.aspx. October 27, 2015.
EPA. 2015a. Chemical data access tool (CDAT). 2012 Chemical data reporting (CDR), ethane, 1,1,2-trichloro-. U.S. Environmental Protection Agency. http://java.epa.gov/oppt_chemical_search/. November 24, 2015.
EPA. 2015b. Technology transfer network. Clearinghouse for inventories & emissions factors. National Emissions Inventory (NEI) air pollutant emissions trends data. U.S. Environmental Protection Agency. http://www3.epa.gov/ttnchie1/trends/. December 7, 2015.
EPA. 2015c. STORET data warehouse access. Trichloroethylene. CAS Number 79-01-6. U.S. Environmental Protection Agency. http://www3.epa.gov/storet/dbtop.html. December 2, 2015.
EPA. 2016. Letter to Ms. Faye Graul dated February 26, 2016. “This letter is in response to your Information Quality Guidelines (IQG) Request for Reconsideration (RFR) dated June 17, 2015 (RFR 13401 A) submitted to the Environmental Protection Agency (EPA) by the Halogenated Solvents Industry Alliance, Inc. (HSIA) pursuant to EPA’s guidelines for ensuring and maximizing the quality, objectivity, utility, and integrity of information disseminated by the Environmental Protection Agency (EPA IQG)”. U.S. Environmental Protection Agency. https://www.epa.gov/quality/epa-information-quality-guidelines-requests-correction-and-requests-reconsideration#14001. May 6, 2016.
EPA. 2017. Risk management for trichloroethylene (TCE). Ban spot removers. U.S. Environmental Protection Agency. https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-trichloroethylene-tce. November 29, 2018.
EPA. 2018. Air Quality System (AQS). U.S. Environmental Protection Agency. https://www.epa.gov/aqs. December 11, 2018.
Ertle T, Henschler D, Muller G, . 1972. Metabolism of trichloroethylene in man. I. The significance of trichloroethanol in long-term exposure conditions. Arch Toxicol 29:171–188.
*Eskenazi B, Bracken MB, Holford TR, . 1988. Exposure to organic solvents and hypertensive disorders of pregnancy. Am J Ind Med 14:177–188.3207103
Ettema JH, Zielhuis RL, Burer E, . 1975. Effects of alcohol, carbon monoxide and trichloroethylene on mental capacity. Int Arch Occup Environ Health 35:117–132.1184204
Evans MV, Chiu WA, Okino MS, . 2009. Development of an updated PBPK model for trichloroethylene and metabolites in mice, and its application to discern the role of oxidative metabolism in TCE-induced hepatomegaly. Toxicol Appl Pharmacol 236(3):329–340.19249323
Ewers J, Freier-Schröder D, Knackmuss H-J. 1990. Selection of trichloroethene (TCE) degrading bacteria that resist inactivation by TCE. Arch Microbial 154:410–413.
*Eyre RJ, Stevens DK, Parker JC, . 1995a. Acid-labile adducts to protein can be used as indicators of the cysteine S-conjugate pathway of trichloroethene metabolism. J Toxicol Environ Health 46:443–464.8523471
Eyre RJ, Stevens DK, Parker JC, . 1995b. Renal activation of trichloroethene and S-(1,2-dichlorovinyl)-l-cysteine and cell proliferative responses in the kidneys of F344 rats and B6C3F1 mice. J Toxicol Environ Health 46:465–481.8523472
Fabian P. 1986. Halogenated hydrocarbons in the atmosphere. In: Hutzinger O, ed. The handbook of environmental chemistry. Vol. 4. Part A. Berlin: Springer-Verlag, 25–51.
Fagliano J, Berry M, Bove F, . 1990. Drinking water contamination and the incidence of leukemia: An ecologic study. Am J Public Health 80:1209–1212.2400032
Fahrig R. 1977. The mammalian spot test (Fellfleckentest) with mice. Arch Toxicol 38:87–98.199140
Fan AM. 1988. Trichloroethylene: Water contamination and health risk assessment. Rev Environ Contam Toxicol 101:55–92.3275994
Fan S, Scow KM. 1993. Biodegradation of trichloroethylene and toluene by indigenous microbial populations in soil. Appl Environ Microbiol 59:1911–1918.8328806
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. April 24, 2013.
Fechter LD, Liu Y, Herr DW, . 1998. Trichloroethylene ototoxicity: Evidence for a cochlear origin. Toxicol Sci 42(1):28–35.9538045
Feingold A, Holaday DA. 1977. The pharmacokinetics of metabolism of inhalation anaesthetics. Br J Anaesth 49:155–162.836747
Feldman RG. 1970. Facial nerve latency studies in man. Effects of trichloroethylene exposure. Electromyography 10:93–100.5456120
Feldman RG, Mayer RM, Taub A. 1970. Evidence for peripheral neurotoxic effect of trichloroethylene. Neurology 20:599–605.4316305
Feldman RG, White RF, Currie JN, . 1985. Long-term follow-up after single toxic exposure to trichloroethylene. Am J Ind Med 8:119–126.4050794
Feldman RG, Chirico-Post J, Proctor SP. 1988. Blink reflex latency after exposure to trichloroethylene in well water. Arch Environ Health 43:143–147.3377549
Feldman RG, Niles C, Proctor SP, . 1992. Blink reflex measurement of effects of trichloroethylene exposure on the trigeminal nerve. Muscle Nerve 15:490–495.1565117
*Fernandez JG, Humbert BE, Droz PO, . 1975. [Exposition au trichloroethylene. Bilan de l’absorption, de l’excretion et du metabolisme sur des sujets humains]. Arch Mal Prof 35:397–407. (French)
Fernandez JG, Humbert BE, Droz PO, . 1977. Trichloroethylene exposure. Simulation of uptake, excretion and metabolism using a mathematical model. Br J Ind Med 34:43–55.843463
Ferrario JB, Lawler GC, DeLeon IR, . 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam Toxicol 34:246–255.3978262
Filser JG, Bolt HM. 1979. Pharmacokinetics of halogenated ethylenes in rats. Arch Toxicol 42:123–136.485853
*Fisher JW. 1993. Evaluating the risks of liver and lung cancer in humans exposed to trichloroethylene using a physiological model. Toxicol Lett 68:127–129.8516759
Fisher JW. 2000. Physiologically based pharmacokinetic models for trichloroethylene and its oxidative metabolites. Environ Health Perspect 108 Suppl 2:265–273.
Fisher JW, Allen BC. 1993. Evaluating the risk of liver cancer in humans exposed to trichloroethylene using physiological models. Risk Anal 13:87–95.8451463
Fisher JW, Channel SR, Eggers JS, . 2001. Trichloroethylene, trichloroacetic acid, and dichloroacetic acid: Do they affect fetal rat heart development? Int J Toxicol 20(5):257–267.11766123
Fisher JW, Gargas ML, Allen BC, . 1991. Physiologically based pharmacokinetic modeling with trichloroethylene and its metabolite, trichloroacetic acid, in the rat and mouse. Toxicol Appl Pharmacol 109:183–195.2068722
Fisher JW, Mahle D, Abbas R. 1998. A human physiologically based pharmacokinetic model for trichloroethylene and its metabolites, trichloroacetic acid and free trichloroethanol. Toxicol Appl Pharmacol 152(2):339–359.9853003
Fisher JW, Whittaker TA, Taylor DH, . 1989. Physiologically based pharmacokinetic modeling of the pregnant rat: A multiroute exposure model for trichloroethylene and its metabolite, trichloroacetic acid. Toxicol Appl Pharmacol 99:395–414.2749729
Fisher JW, Whittaker TA, Taylor DH, . 1990. Physiologically based pharmacokinetic modeling of the lactating rat and nursing pup: A multiroute exposure model for trichloroethylene and its metabolite, trichloroacetic acid. Toxicol Appl Pharmacol 102:497–513.2315918
Fleming-Jones ME, Smith RE. 2003. Volatile organic compounds in foods: A five year study. J Agric Food Chem 51:8120–8127.14690406
Fogel MM, Taddeo AR, Fogel S. 1986. Biodegradation of chlorinated ethenes by a methane-utilizing mixed culture. Appl Environ Microbiol 51:720–724.3085587
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Forand SP, Lewis-Michl EL, Gomez MI. 2012. Adverse birth outcomes and maternal exposure to trichloroethylene and tetrachloroethylene through soil vapor intrusion in New York State. Environ Health Perspect 120(4):616–621.22142966
Ford ES, Rhodes S, McDiarmid M, . 1995. Deaths from acute exposure to trichloroethylene. J Occup Environ Med 37:749–754.7670923
Forkert PG, Forkert L. 1994. Trichloroethylene induces pulmonary fibrosis in mice. Can J Physiol Pharmacol 72:205–210.8069766
Forkert PG, Sylvestre PL, Poland JS. 1985. Lung injury induced by trichloroethylene. Toxicology 36:199–214.4049431
Forkert PG, Lash LH, Nadeau V, . 2002. Metabolism and toxicity of trichloroethylene in epididymis and testis. Toxicol Appl Pharmacol 182(3):244–254.12183104
Forkert PG, Baldwin RM, Millen B, . 2005. Pulmonary bioactivation of trichloroethylene to chloral hydrate: Relative contributions of CYP2E1, CYP2F, and CYP2B1. Drug Metab Dispos 33(10):1429–1437.15987776
Forkert PG, Lash L, Tardif R, . 2003. Identification of trichloroethylene and its metabolites in human seminal fluid of workers exposed to trichloroethylene. Drug Metab Dispos 31(3):306–311.12584157
Forkert PG, Millen B, Lash LH, . 2006. Pulmonary bronchiolar cytotoxicity and formation of dichloroacetyl lysine protein adducts in mice treated with trichloroethylene. J Pharmacol Exp Ther 316(2):520–529.16269531
*Forssman S, Holmquist CE. 1953. The relation between inhaled and exhaled trichloroethylene and trichloroacetic acid excreted in the urine of rats exposed to trichloroethylene. Acta Pharmacol Toxicol 9:235–244.
*Fort DJ, Rayburn JR, DeYoung DJ, . 1991. Assessing the efficacy of an Aroclor 1254-induced exogenous metabolic activation system for FETAX. Drug Chem Toxicol 14:143–160.1889373
*Fort DJ, Stover EL, Rayburn JR, . 1993. Evaluation of the developmental toxicity of trichloroethylene and detoxification metabolites using Xenopus. Teratog Carcinog Mutagen 13:35–45.8100651
Fox BG, Borneman JG, Wackett LP, . 1990. Haloalkane oxidation by the soluble methane monooxygenase from Methylosinus trichosporium OB3b: Mechanistic and environmental implications. Biochemistry 29:6419–6427.2207083
*Fox TR, Watanabe PG. 1985. Detection of a cellular oncogene in spontaneous liver tumors of B6C3F1 mice. Science 228:596–597.3983645
Franco A, Costoya MA, Roca E. 2007. Estimating risk during showering exposure to VOCs of workers in a metal-degreasing facility. J Toxicol Environ Health A 70(7):627–637.17365617
Fredriksson A, Danielsson BRG, Eriksson P. 1993. Altered behavior in adult mice orally exposed to tri- and tetrachloroethylene as neonates. Toxicol Lett 66:13–19.8427017
Fredriksson M, Bengtsson N, Hardell L, . 1989. Colon cancer, physical activity, and occupational exposures. Cancer 63:1838–1842.2702592
Freedman DL, Gossett JM. 1989. Biological reductive dechlorination of tetrachloroethylene and trichloroethylene to ethylene under methanogenic conditions. Appl Environ Microbiol 55:2144–2151.2552919
Freni SC, Bloomer AW. 1988. Report on the Battle Creek Health Study. Lansing, MI: Michigan Department of Public Health.
Fujita H, Koizumi A, Yamamoto M, . 1984. Inhibition of δ-aminolevulinate dehydratase in trichloroethylene-exposed rats, and the effects on heme regulation. Biochem Biophys Acta 800:1–10.6743680
Fukuda K, Takemoto K, Tsuruta H. 1983. Inhalation carcinogenicity of trichloroethylene in mice and rats. Ind Health 21:243–254.6654707
Gamberale F, Annwall G, Olson BA. 1976. Exposure to trichloroethylene. III. Psychophysiological functions. Scand J Work Environ Health 2:220–224.1019596
Garabrant DH, Held J, Langholz B, . 1988. Mortality of aircraft manufacturing workers in southern California. Am J Ind Med 13(6):683–693.3389363
Garabrant DH, Lacey JV, Jr., Laing TJ, . 2003. Scleroderma and solvent exposure among women. Am J Epidemiol 157(6):493–500.12631538
*Garbarini DR, Lion LW. 1986. Influence of the nature of soil organics on the sorption of toluene and trichloroethylene. Environ Sci Technol 20:1263–1269.
Gash DM, Rutland K, Hudson NL, . 2008. Trichloroethylene: Parkinsonism and complex 1 mitochondrial neurotoxicity. Ann Neurol 63(2):184–192.18157908
Gay BW Jr, Hanst PL, Bulfalini JJ, . 1976. Atmospheric oxidation of chlorinated ethylenes. Environ Sci Technol 10:58–67.
*Gehringer P, Proksch E, Szinovatz W, . 1988. Radiation-induced decomposition of aqueous trichloroethylene solutions. Int J Appl Instrum [A] 39:1227–1231.
Geng C, Lu Q, Chen M, . 2010. Quantitative risk assessment of trichloroethylene for a former chemical works in Shanghai, China. Hum Ecol Risk Assess 16(2):429–443.
Giardino NJ, Esmen NA, Andelman JB. 1992. Modeling volatilization of trichloroethylene from a domestic shower spray: The role of drop-size distribution. Environ Sci Technol 26:1602–1606.
*Giger W, Schwarzenbach RP, Hoehn E, . 1983. [Behavior of organic water contaminants in groundwater formation and in groundwater.] Gas, Wasser, Abwasser 63:517–531. (German)
Gilbert KM, Griffin JM, Pumford NR. 1999. Trichloroethylene activates CD4+ T cells: Potential role in an autoimmune response. Drug Metab Rev 31(4):901–916.10575554
Gilbert KM, Rowley B, Gomez-Acevedo H, . 2011. Coexposure to mercury increases immunotoxicity of trichloroethylene. Toxicol Sci 119(2):281–292.21084432
Gilbert KM, Whitlow AB, Pumford NR. 2004. Environmental contaminant and disinfection by-product trichloroacetaldehyde stimulates T cells in vitro. Int Immunopharmacol 4(1):25–36.14975357
Gilboa SM, Desrosiers TA, Lawson C, . 2012. Association between maternal occupational exposure to organic solvents and congenital heart defects, National Birth Defects Prevention Study, 1997-2002. Occup Environ Med 69(9):628–635. 10.1136/oemed-2011-100536.22811060
Gilkeson GS, Keil D, Peden-Adams MM. 2004. Immune effects of trichloroethylene on autoimmune disease in mice. In: Mohr LC, Hoel DG, Jollow D, eds. Trichloroethylene: The scientific basis of risk assessment. Charleston, SC: Medical University of South Carolina Press, 87–98.
Gimmi T, Fluehler H, Studer B, . 1993. Transport of volatile chlorinated hydrocarbons in unsaturated aggregated media. Water Air Soil Pollut 68:291–305.
Giovanetti A, Rossi L, Mancuso M, . 1998. Analysis of lung damage induced by trichloroethylene inhalation in mice fed diets with low, normal, and high copper content. Toxicol Pathol 26(5):628–635.9789949
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Glaser MA. 1931. Treatment of trigeminal neuralgia with trichloroethylene. JAMA 96:916–920.
Goel SK, Rao GS, Pandya KP, . 1992. Trichloroethylene toxicity in mice: A biochemical, hematological and pathological assessment. Indian J Exp Biol 30(5):402–406.1459618
Goeptar AR, Commandeur JNM, Vanommen B, . 1995. Metabolism and kinetics of trichloroethylene in relation to toxicity and carcinogenicity. Relevance of the mercapturic acid pathway. Chem Res Toxicol 8:3–21.7703363
Goh CL, Ng SK. 1988. A cutaneous manifestation of trichloroethylene toxicity. Contact Dermatitis 18:59–61.3349787
Goh VH, Chia SE, Ong CN. 1998. Effects of chronic exposure to low doses of trichloroethylene on steroid hormone and insulin levels in normal men. Environ Health Perspect 106(1):41–44.9417767
*Gold LS, Stewart PA, Milliken K, . 2011. The relationship between multiple myeloma and occupational exposure to six chlorinated solvents. Occup Environ Med 68(6):391–399. 10.1136/oem.2009.054809.20833760
Goldberg ME, Johnson HE, Pozzani UC, . 1964a. Behavioral response of rats during inhalation of trichloroethylene and carbon disulfide vapours. Acta Pharmacol Toxicol 21:36–44.
Goldberg ME, Johnson HE, Pozzani UC, . 1964b. Effect of repeated inhalation of vapors of industrial solvents on animal behavior. I. Evaluation of nine solvent vapors on pole-climb performance in rats. Am Ind Hyg Assoc J 25:369–375.14194199
Goldberg SJ, Lebowitz MD, Graver EJ, . 1990. Pediatric cardiology: An association of human congenital cardiac malformations and drinking water contaminants. J Am Coll Cardiol 16:155–164.2358589
Goldman SM, Quinlan MPH, Ross GW, . 2012. Solvent exposures and Parkinson disease risk in twins. Ann Neurol 71(6):776–784.22083847
Goldsmith LB, Friberg SE, Wahlberg JE. 1988. The effect of solvent extraction on the lipids of the stratum corneum in relation to observed immediate whitening of the skin. Contact Dermatitis 19:348–350.3233954
Goldsworthy TL, Popp JA. 1987. Chlorinated hydrocarbon-induced peroxisomal enzyme activity in relation to species and organ carcinogenicity. Toxicol Appl Pharmacol 88:225–233.3564041
*Goldsworthy TL, Lyght O, Burnett VL, . 1988. Potential role of α-2μ-globulin, protein droplet accumulation, and cell replication in the renal carcinogenicity of rats exposed to trichloroethylene, perchloroethylene, and pentachloroethane. Toxicol Appl Pharmacol 96:367–379.2461605
Goon AT, Lee LT, Tay YK, . 2001. A case of trichloroethylene hypersensitivity syndrome. Arch Dermatol 137(3):274–276.11255324
Gordon SM, Callahan PJ, Nishioka MG, . 1999. Residential environmental measurements in the national human exposure assessment survey (NHEXAS) pilot study in Arizona: Preliminary results for pesticides and VOCs. J Expo Anal Environ Epidemiol 9(5):456–470.10554148
Gossett RW, Brown DA, Young DR. 1983. Predicting the bioaccumulation of organic compounds in marine organisms using octanol/water partition coefficients. Mar Pollut Bull 14:387–392.
Grandjean E. 1960. Trichloroethylene effects on animal behavior. The effects of trichloroethylene vapors on a food motivated conditioned climbing reaction of rats. Arch Environ Health 1:106–108.13828905
Grandjean E. 1963. The effects of short exposures to trichloroethylene on swimming performances and motor activity of rats. Am Ind Hyg Assoc J 24:376–379.14042497
Grandjean E, Muchinger R, Turrian V, . 1955. Investigations into the effect of exposure to trichloroethylene in mechanical engineering. Br J Ind Med 12:131–142.14363593
Graovac-Leposavic LJ, Milosavlijevic Z, Ilic V. 1964. [Liver function in workers exposed to trichloroethylene.] Arch Hig Rada 15:93–97. (Serbo-Croatian)
*Grasso P. 1988. Neurotoxic and neurobehavioral effects of organic solvents on the nervous system. Occup Med 3:525–539.2841771
Grathwohl P. 1990. Influence of organic matter from soils and sediments from various origins on the sorption of some chlorinated aliphatic hydrocarbons: Implications on K_oc_ correlations. Environ Sci Technol 24(11):1687–1693.
*Green T. 2000. Pulmonary toxicity and carcinogenicity of trichloroethylene: Species differences and modes of action. Environ Health Perspect 108(Suppl 2):261–264.10807556
*Green T, Prout MS. 1985. Species differences in response to trichloroethylene. II. Biotransformation in rats and mice. Toxicol Appl Pharmacol 79:401–411.3929429
*Green T, Dow J, Ellis MK, . 1997. The role of glutathione conjugation in the development of kidney tumours in rats exposed to trichloroethylene. Chem Biol Interact 105(2):99–117.9251723
Green T, Dow J, Ong CN, . 2004. Biological monitoring of kidney function among workers occupationally exposed to trichloroethylene. Occup Environ Med 61(4):312–317.15031388
Greenberg MS, Burton GA, Fisher JW. 1999. Physiologically based pharmacokinetic modeling of inhaled trichloroethylene and its oxidative metabolites in B6C3F1 mice. Toxicol Appl Pharmacol 154(3):264–278.9931286
*Greenland S, Salvan A, Wegman DH, . 1994. A case-control study of cancer mortality at a transformer-assembly facility. Int Arch Occup Environ Health 66(1):49–54.7927843
Greim H, Bonse G, Radwan Z, . 1975. Mutagenicity in vitro and potential carcinogenicity of chlorinated ethylenes as a function of metabolic oxirane formation. Biochem Pharmacol 24:2013–2017.1108881
Griffin JM, Blossom SJ, Jackson SK, . 2000a. Trichloroethylene accelerates an autoimmune response by Th_1_ T cell activation in MRL +/+ mice. Immunopharmacology 46(2):123–137.10647871
Griffin JM, Gilbert KM, Lamps LW, . 2000b. CD4(+) T-cell activation and induction of autoimmune hepatitis following trichloroethylene treatment in MRL+/+ mice. Toxicol Sci 57(2):345–352.11006364
Griffin JM, Lipscomb JC, Pumford NR. 1998. Covalent binding of trichloroethylene to proteins in human and rat hepatocytes. Toxicol Lett 95(3):173–181.9704819
Grob K, Frauenfelder C, Artho A. 1990. Uptake by foods of tetrachloroethylene, trichloroethylene, toluene, and benzene from air. Z Lebensm Unters Forsch 191:435–441.2103659
Gu ZW, Sele B, Chmara D, . 1981a. [Effects of trichloroethylene and its metabolites on the rate of sister chromatid exchange. In vivo and in vitro study on the human lymphocytes]. Ann Genet 24:105–106.6977287
Gu ZW, Sele B, Jalbert P, . 1981b. Induction of sister chromatid exchange by trichloroethylene and its metabolites. Toxicol Eur Res 3:63–67. (French)7245187
Guehl D, Bezard E, Dovero S, . 1999. Trichloroethylene and parkinsonism: A human and experimental observation. Eur J Neurol 6(5):609–611.10457397
Guengerich FP, Shimada T. 1991. Oxidation of toxic and carcinogenic chemicals by human cytochrome P-450 enzymes. Chem Res Toxicol 4(4):391–407.1912325
Gummin DD. 2015. Hydrocarbons. In: Hoffman RS, Lewin NA, Goldfrank LR, ., eds. Goldfrank’s toxicologic emergencies. Tenth ed. New York, NY: McGraw-Hill Education, 309–310, 1334.
*Gun RT, Grygorcewicz C, Nettelbeck TJ. 1978. Choice reaction time in workers using trichloroethylene. Med J Aust 1(10):535–536.683058
Guo X, Dixit V, Liu H, . 2006. Inhibition and recovery of rat hepatic glutathione s-transferase zeta and alteration of tyrosine metabolism following dichloroacetate exposure and withdrawal. Drug Metab Dispos 34(1):36–42.16199472
Gutch CF, Tomhave WG, Stevens SC. 1965. Acute renal failure due to inhalation of trichloroethylene. Ann Int Med 63:128–134.14305960
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Ha JH, Lee CG, Yoon SH, . 2009. A case of hypersensitive exfoliative dermatitis with hepatitis after an occupational exposure to trichloroethylene. Korean J Asmtha Allergy Clin Immunol 29(2):132–137.
Hack CE, Chiu WA, Jay Zhao Q, . 2006. Bayesian population analysis of a harmonized physiologically based pharmacokinetic model of trichloroethylene and its metabolites. Regul Toxicol Pharmacol 46(1):63–83.16889879
Hadkhale K, Martinsen JI, Weiderpass E, . 2017. Occupational exposure to solvents and bladder cancer: A population-based case control study in Nordic countries. Int J Cancer 140(8):1736–1746. 10.1002/ijc.30593.28032642
Haglid KG, Briving C, Hansson HA, . 1981. Trichloroethylene: Long-lasting changes in the brain after rehabilitation. Neurotoxicology 2:659–673.7200581
Halmes NC, Perkins EJ, McMillan DC, . 1997. Detection of trichloroethylene-protein adducts in rat liver and plasma. Toxicol Lett 92(3):187–194.9334829
Hamdan H, Stacey NH. 1993. Mechanism of trichloroethylene-induced elevation of individual serum bile acids. I. Correlation of trichloroethylene concentrations to bile acids in rat serum. Toxicol Appl Pharmacol 121:291–295.8346545
Hansen J, Raaschou-Nielsen O, Christensen JM, . 2001. Cancer incidence among Danish workers exposed to trichloroethylene. J Occup Environ Med 43(2):133–139.11227631
Hansen J, Sallmén M, Seldén, . 2013. Risk of cancer among workers exposed to trichloroethylene: Analysis of three Nordic cohort studies. J Natl Cancer Inst 105:869–877.23723420
*Hardell L, Eriksson M, Degerman A. 1994. Exposure to phenoxyacetic acids, chlorophenols, or organic solvents in relation to histopathology, stage, and anatomical localization of non-Hodgkin’s lymphoma. Cancer Res 54:2386–2389.8162585
*Hardell L, Eriksson M, Lenner P, . 1981. Malignant lymphoma and exposure to chemicals, especially organic solvents, chlorophenols and phenoxy acids: A case-control study. Br J Cancer 43:169–176.7470379
Hardin BD, Bond GP, Sikov MR, . 1981. Testing of selected workplace chemicals for teratogenic potential. Scand J Work Environ Health 7(Suppl 4):66–75.7330632
Hardin BD, Kelman BJ, Brent RL. 2004. Trichloroethylene and cardiac malformations. Environ Health Perspect 112(11):A607–A608; author reply A608-609.
Hardin BD, Kelman BJ, Brent RL. 2005. Trichloroethylene and dichloroethylene: A critical review of teratogenicity. Birth Defects Res A Clin Mol Teratol 73(12):931–955. 10.1002/bdra.20192.16342278
Harkov R, Gianti SJ, Bozzelli JW, . 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health [A] 20:491–501.
Harkov R, Kebbekus B, Bozzelli JW, . 1984. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ 38:259–274.
*Harrington JM, Whitby H, Gray CN, . 1989. Renal disease and occupational exposure to organic solvents: A case referent approach. Br J Ind Med 46(9):643–650.2789968
Hartwell TD, Crowder JH, Sheldon LS, . 1985. Levels of volatile organics in indoor air. In: Proceedings of the Air Pollution Control Association 78th Annual Meeting, Detroit, Michigan. June 16-21, 1085.
Hasanen E, Soininen V, Pyysalo M, . 1979. The occurrence of aliphatic chlorine and bromine compound in automobile exhaust. Atmos Environ 13:1217–1219.
Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2:249–272.24264296
Hayashi N, Igarashi A, Matsuyama T, . 2000. Eosinophilic fasciitis following exposure to trichloroethylene: Successful treatment with cyclosporin. Br J Dermatol 142(4):830–832.10792252
Healy TEJ, Poole TR, Hooper A. 1982. Rat fetal development and maternal exposure to trichloroethylene 100 ppm. Br J Anaesth 54:337–341.7066129
Heikes DL, Hopper ML. 1986. Purge and trap method for determination of fumigants in whole grains, milled grain products, and intermediate grain-based foods. J Assoc Off Anal Chem 69:990–998.3542956
Heineman EF, Cocco P, Gomez MR, . 1994. Occupational exposure to chlorinated aliphatic hydrocarbons and risk of astrocytic brain cancer. Am J Ind Med 26:155–169.7977393
Helliwell PJ, Hutton AM. 1950. Trichloroethylene anesthesia. I. Distribution in the foetal and maternal circulation of pregnant sheep and goats. Anesthesia 5:4–13.
Henry SM, Grbic-Galic D. 1991a. Influence of endogenous and exogenous electron donors and trichloroethylene oxidation toxicity on trichloroethylene oxidation by methanotrophic cultures from a groundwater aquifer. Appl Environ Microbiol 57:236–244.2036010
Henry SM, Grbic-Galic D. 1991b. Inhibition of trichloroethylene oxidation by the transformation intermediate carbon monoxide. Appl Environ Microbiol 57:1770–1776.1908211
Henschler D, Eder E, Neudecker T, . 1977. Carcinogenicity of trichloroethylene: Fact or artifact? Arch Toxicol 37:233–236.332116
Henschler D, Elsasser H, Romer W, . 1984. Carcinogenicity study of trichloroethylene, with and without epoxide stabilizers, in mice. J Cancer Res Clin Oncol 107:149–156.6736101
Henschler D, Romer W, Elasser HM, . 1980. Carcinogenicity study of trichloroethylene by long-term inhalation in three animal species. Arch Toxicol 43:237–248.7387385
*Henschler D, Vamvakas S, Lammert M, . 1995. Increased incidence of renal cell tumors in a cohort of cardboard workers exposed to trichloroethene. Arch Toxicol 69:291–299.7654132
*Henson JM, Yates MV, Cochran JW, . 1988. Microbial removal of halogenated methanes, ethanes, and ethylenes in an aerobic soil exposed to methane. Published in FEMS Microbiology Ecology. Prepared in cooperation with Northrop Services, Inc. Ada, OK and Oklahoma Univ, Norman Dept of Botany and Microbiology. EPA600J88066.
*Herren-Freund SL, Pereira MA, Khoury MD, . 1987. The carcinogenicity of trichloroethylene and its metabolites, trichloroacetic acid and dichloroacetic acid, in mouse liver. Toxicol Appl Pharmacol 90:183–189.3629594
Hewer CL. 1943. Further observations on trichloroethylene. Proc R Soc Med 36:463–465.19992686
Hewitt AD, Shoop SA. 1994. Rapid assessment of trichloroethylene in ground water. Ground Water Monitor Remediation 14:116–122.
Hewitt AD, Miyares PH, Leggett DC, . 1992. Comparison of analytical methods for determination of volatile organic compounds in soils. Environ Sci Technol 26:1932–1938.
Heydari M, Ahmadizadeh M, Ahmadi Angali K. 2017. Ameliorative effect of vitamin E on trichloroethylene-induced nephrotoxicity in rats. J Nephropathol 6(3):168–173. 10.15171/jnp.2017.29.28975097
*Hine J, Mookerjee PK. 1975. The intrinsic hydrophilic character of organic compounds. Correlations in terms of structural contributions. J Org Chem 40: 292–298.
Hissink EM, Bogaards JJ, Freidig AP, . 2002. The use of in vitro metabolic parameters and physiologically based pharmacokinetic (PBPK) modeling to explore the risk assessment of trichloroethylene. Environ Toxicol Pharmacol 11(3–4):259–271.21782610
Hobara T, Kobayashi H, Higashihara E, . 1984. Acute effects of 1,1,1-trichloroethane, trichloroethylene, and toluene on the haematologic parameters in dogs. Arch Environ Contam Toxicol 13:589–593.6486885
Hobara T, Kobayashi H, Kawamoto T, . 1986. Extrahepatic organs metabolism of inhaled trichloroethylene. Toxicology 41:289–303.3775778
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hoffmann P, Heinroth K, Richards D, . 1994. Depression of calcium dynamics in cardiac myocytes - a common mechanism of halogenated hydrocarbon anesthetics and solvents. J Mol Cell Cardiol 26:579–589.8072012
Hong WX, Yang L, Chen M, . 2012. Proteomic analysis of trichloroethylene-induced alterations in expression, distribution, and interactions of SET/TAF-Iα and two SET/TAF-Iα-binding proteins, eEF1A1 and eEF1A2, in hepatic L-02 cells. Toxicol Appl Pharmacol 263(2):259–272.22771849
Horvath AL, Getzen FW, Maczynska Z. 1999. IUPAC-NIST solubility data series 67. Halogenated ethanes and ethenes with water. J Phys Chem Ref Data 28(2):395–627.
Hosgood HD, Zhang L, Tang X, . 2012. Decreased numbers of CD4^+^ naive and effector memory T cells, and CD8^+^ naive T cells, are associated with trichloroethylene exposure. Front Oncol 1:53.22649769
Hov O, Penkett SA, Isaksen ISA, . 1984. Organic gases in the Norwegian arctic. Geophys Res Lett 11:425–428.
HSDB. 2013. Trichloroethylene. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. May 7, 2013.
Huang H, Kamijima M, Wang H, . 2006. Human herpes virus 6 reactivation in trichloroethylene-exposed workers suffering from generalized skin disorders accompanied by hepatic dysfunction. J Occup Health 48(6):417–423.17179634
Humphrey JH, McClelland M. 1944. Cranial-nerve palsies with herpes following general anaesthesia. Br Med J 1:315–318.20785308
Huo W, Zhang K, Nie Z, . 2010. Kidney injury molecule-1 (KIM-1): A novel kidney-specific injury molecule playing potential double-edged functions in kidney injury. Transplant Rev 24(3):143–146.
Huybrechts T, Dewulf J, Van Langenhove H. 2005. Priority volatile organic compounds in surface waters of the southern North Sea. Environ Pollut 133(2):255–264.15519456
IARC. 1979. Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Some halogenated hydrocarbons. Lyon, France: International Agency for Research on Cancer, World Health Organization, 491–514.
IARC. 1995. Monographs on the evaluation of carcinogenic risks to humans. Vol 63. Drycleaning, some chlorinated solvents, and other industrial chemicals. Lyon, France: International Agency for Research on Cancer, World Health Organization.
IARC. 2014. IARC monographs on the evaluation of carcinogenic risks to humans. Trichloroethylene, tetrachloroethylene, and some chlorinated agents. Volume 106. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol106/mono106.pdf. July 8, 2014.
Iavicoli I, Marinaccio A, Carelli G. 2005. Effects of occupational trichloroethylene exposure on cytokine levels in workers. J Occup Environ Med 47(5):453–457 15891523
Ikeda M. 1977. Metabolism of trichloroethylene and tetrachloroethylene in human subjects. Environ Health Perspect 21:239–245.612449
Ikeda M, Ohtsuji H, Imamura T, . 1972. Urinary excretion of total trichloro-compounds, trichloroethanol, and trichloroacetic acid as a measure of exposure to trichloroethylene and tetrachloroethylene. Br J Ind Med 29:328–333.5044605
Imamura T, Ikeda M. 1973. Lower fiducial limit of urinary metabolite level as an index of excessive exposure to industrial chemicals. Br J Ind Med 30:289.4723791
Imbriani M, Niu Q, Negri S, . 2001. Trichloroethylene in urine as biological exposure index. Ind Health 39(3):225–230.11499997
Inoue O, Seiji K, Kawai T, . 1989. Relationship between vapor exposure and urinary metabolite excretion among workers exposed to trichloroethylene. Am J Ind Med 15:103–110.2784624
Irving RM, Elfarra AA. 2013. Mutagenicity of the cysteine S-conjugate sulfoxides of trichloroethylene and tetrachloroethylene in the Ames test. Toxicology 306:157–161.23416178
IRIS. 2011. Trichloroethylene. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. April 24, 2013.
Isaacson LG, Taylor DH. 1989. Maternal exposure to 1,1,2-trichloroethylene affects myelin in the hippocampal formation of the developing rat. Brain Res 488:403–407.2743138
Isaacson LG, Spohler SA, Taylor DH. 1990. Trichloroethylene affects learning and decreases myelin in the rat hippocampus. Neurotoxicol Teratol 12:375–381.2392097
*Ishikawa S, Nozaki Y, Tsunemi T, . 1990. Effects of trichloroethylene on embryonic chick heart [Abstract]. Senten Ijo 30:253.
Jacob S, Hery M, Protois JC, . 2007. New insight into solvent-related end-stage renal disease: Occupations, products and types of solvents at risk. Occup Environ Med 64:843–848.17567724
Jakobson I, Holmberg B, Ekner A. 1986. Venous blood levels of inhaled trichloroethylene in female rats and changes induced by interacting agents. Acta Pharmacol Toxicol 59:135–143.
Jakobson I, Wahlberg JE, Holmberg B, . 1982. Uptake via the blood and elimination of 10 organic solvents following epicutaneous exposure of anesthetized guinea pigs. Toxicol Appl Pharmacol 63:181–187.7089968
James WRL. 1963. Fatal addiction to trichloroethylene. Br J Ind Med 20:47–49.13957277
James RH, Adams RE, Finkel JM, . 1985. Evaluation of analytical methods for the determination of POHC in combustion products. J Air Pollut Control Assoc 35:959–969.
Jaspers RM, Muijser H, Lammers JH, . 1993. Mid-frequency hearing loss and reduction of acoustic startle responding in rats following trichloroethylene exposure. Neurotoxicol Teratol 15:407–412.8302242
Jeffers PM, Ward LM, Woytowitch LM, . 1989. Homogenous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes and propanes. Environ Sci Technol 23:965–969.
Jensen S, Rosenberg R. 1975. Degradability of some chlorinated aliphatic hydrocarbons in sea water and sterilized water. Water Res 9:659–661.
Jia Q, Zang D, Yi J, . 2012. Cytokine expression in trichloroethylene-induced hypersensitivity dermatitis: An in vivo and in vitro study. Toxicol Lett 215(1):31–39.23041168
Johnson PD, Dawson BV, Goldberg SJ. 1998. A review: Trichloroethylene metabolites: Potential cardiac teratogens. Environ Health Perspect 106(Suppl 4):995–999.9703484
*Johnson PD, Dawson BV, Goldberg SJ, . 2004. Trichloroethylene: Johnson et al.’s response. Environ Health Perspect 112(11):A608–A609.
Johnson PD, Goldberg SJ, Mays MZ, . 2003. Threshold of trichloroethylene contamination in maternal drinking waters affecting fetal heart development in the rat. (Erratum in: Environ Health Perspect 113(1):A18; Erratum in: Environ Health Perspect 122(4):A94). Environ Health Perspect 111(3):289–292.12611656
Johnston JE, MacDonald Gibson J. 2011. Probabilistic approach to estimating indoor air concentrations of chlorinated volatile organic compounds from contaminated groundwater: A case study in San Antonio, Texas. Environ Sci Technol 45(3):1007–1013.21162557
Jones GR, Singer PP. 2008. An unusual trichloroethanol fatality attributed to sniffing trichloroethylene. J Anal Toxicol 32(2):183–186.18334104
*Jorgenson TA, Meierhenry EF, Rushbrook CJ, . 1985. Carcinogenicity of chloroform in drinking water to male Osborne-Mendel rats and female B6C3F1 mice. Fundam Appl Toxicol 5:760–769.4043598
Joron GE, Cameron DG, Halpenny GW. 1955. Massive necrosis of the liver due to trichloroethylene. Can Med Assoc J 73:890–891.13270193
Jung HG, Kim HH, Song BG, . 2012. Trichloroethylene hypersensitivity syndrome: A disease of fatal outcome. Yonsei Med J 53(1):231–235.22187259
Jung WT, Fujita M, Sohn DH. 1992. Levels of volatile halogenated hydrocarbons in Tokyo rain and their seasonal, time-series changes. Eisei Kagaku 38:490–497.
Jurkiewicz A, Maciel GE. 1995. Solid state 13C NMR studies of the interaction of acetone, carbon tetrachloride and trichloroethylene with soil components. Sci Total Environ 164:195–202.
*Kadry AM, Skowronski GA, Turkall RM, . 1991a. Kinetics and bioavailability of soil-adsorbed trichloroethylene in male rats exposed orally. Biol Monit 1:75–86.
*Kadry AM, Turkall RM, Skowronski GA, . 1991b. Soil adsorption alters kinetics and bioavailability of trichloroethylene in orally exposed female rats. Toxicol Lett 58:337–346.1957329
Kamijima M, Hisanaga N, Wang H, . 2007. Occupational trichloroethylene exposure as a cause of idiosyncratic generalized skin disorders and accompanying hepatitis similar to drug hypersensitivities. Int Arch Occup Environ Health 80(5):357–370.17106739
Kamijima M, Wang H, Huang H, . 2008. Trichloroethylene causes generalized hypersensitivity skin disorders complicated by hepatitis. J Occup Health 50(4):328–338.18540116
Kan FW, Forkert PG, Wade MG. 2007. Trichloroethylene exposure elicits damage in epididymal epithelium and spermatozoa in mice. Histol Histopathol 22(9):977–988.17523075
Kanazawa S, Filip Z. 1986. Effects of trichloroethylene, tetrachloroethylene, and dichloromethane on enzymatic activities in soil. Appl Microbiol Biotechnol 25:76–81.
Kaneko T, Saegusa M, Tasaka K, . 2000. Immunotoxicity of trichloroethylene: A study with MRL-lpr/lpr mice. J Appl Toxicol 20(6):471–475.11180269
Kaneko T, Wang P-Y, Sato A. 1994. Enzymes induced by ethanol differently affect the pharmacokinetics of trichloroethylene and 1,1,1-trichloroethane. Occup Environ Med 51:113–119.8111458
*Karami S, Bassig B, Stewart PA, . 2013. Occupational trichloroethylene exposure and risk of lymphatic and haematopoietic cancers. Occup Environ Med 70(8):591–599.23723297
*Karami S, Lan Q, Rothman N, . 2012. Occupational trichloroethylene exposure and kidney cancer risk: A meta-analysis. Occup Environ Med 69:858–867.23000822
*Kato I, Koenig KL, Watanabe-Meserve H, . 2005. Personal and occupational exposure to organic solvents and risk of non-Hodgkin’s lymphoma (NHL) in women (United States). Cancer Causes Control 16(10):1215–1224. 10.1007/s10552-005-0385-4.16215872
Kato-Weinstein J, Lingohr MK, Orner GA, . 1998. Effects of dichloroacetate on glycogen metabolism in B6C3F1 mice. Toxicology 130(2–3):141–154.9865481
Kautiainen A, Vogel JS, Turteltaub KW. 1997. Dose-dependent binding of trichloroethylene to hepatic DNA and protein at low doses in mice. Chem Biol Interact 106(2):109–121.9366897
Kawasaki M. 1980. Experiences with the test scheme under the chemical control law of Japan: An approach to structure-activity correlations. Ecotoxicol Environ Saf 4:444–454.7472248
Kawata K, Fujieda Y. 1993. [Volatile chlorinated hydrocarbons in ambient air at Niigata area.] Jpn J Toxicol Environ Health (Eisei Kagaku) 39:474–479. (Japanese)
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology--drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167. 10.1056/NEJMra035092.13679531
Keil DE, Peden-Adams MM, Wallace S, . 2009. Assessment of trichloroethylene (TCE) exposure in murine strains genetically-prone and non-prone to develop autoimmune disease. J Environ Sci Health A Tox Hazard Subst Environ Eng 44(5):443–453.19241258
Keller DA, Heck HD. 1988. Mechanistic studies on chloral toxicity: Relationship to trichloroethylene carcinogenesis. Toxicol Lett 42:183–191.3406960
*Kelsh MA, Alexander DD, Mink PJ, . 2010. Occupational trichloroethylene exposure and kidney cancer: A meta-analysis. Epidemiology 21(1):95–102.20010212
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38.7379718
Kernan GJ, Ji BT, Dosemeci M, . 1999. Occupational risk factors for pancreatic cancer: A case-control study based on death certificates from 24 U.S. states. Am J Ind Med 36:260–270.10398934
Ketcha MM, Stevens DK, Warren DA, . 1996. Conversion of trichloroacetic acid to dichloroacetic acid in biological samples. J Anal Toxicol 20(4):236–241.8835661
Keys DA, Bruckner JV, Muralidhara S, . 2003. Tissue dosimetry expansion and cross-validation of rat and mouse physiologically based pharmacokinetic models for trichloroethylene. Toxicol Sci 76(1):35–50.12915716
Kezic S, Monster AC, Kruse J, . 2000. Skin absorption of some vaporous solvents in volunteers. Int Arch Occup Environ Health 73(6):415–422.11007346
Kezic S, Monster AC, van de Gevel IA, . 2001. Dermal absorption of neat liquid solvents on brief exposures in volunteers. Am Ind Hyg Assoc J 62(1):12–18.
Khalil MAK, Rasmussen RA. 1983. Gaseous tracers of arctic haze. Environ Sci Technol 17:157–164.22263680
Khan MF, Wu X, Ansari GA. 2001. Anti-malondialdehyde antibodies in MRL+/+ mice treated with trichloroethene and dichloroacetyl chloride: Possible role of lipid peroxidation in autoimmunity. Toxicol Appl Pharmacol 170(2):88–92.11162772
Khan FM, Kaphalia BS, Prabhakar BS, . 1995. Trichloroethene-induced autoimmune response in female MRL +/+ mice. Toxicol Appl Pharmacol 134:155–160.7676450
Kilburn KH. 2002a. Do duration of exposure, proximity to electronic manufacturing plants, and involvement in a lawsuit affect chlorinated solvent toxicity? Arch Environ Health 57(2):121–126.12194156
Kilburn KH. 2002b. Is neurotoxicity associated with environmental trichloroethylene (TCE)? Arch Environ Health 57(2):113–120.12194155
Kilburn KH, Warshaw RH. 1992. Prevalence of symptoms of systemic lupus erythematosus (SLE) and of fluorescent antinuclear antibodies associated with chronic exposure to trichloroethylene and other chemicals in well water. Environ Res 57:1–9.1740091
Kilburn KH, Warshaw RH. 1993. Effects on neurobehavioral performance of chronic exposure to chemically contaminated well water. Toxicol Ind Health 9:391–404.8367882
Kilburn KH, Warshaw RH, Hanscom B. 1994. Balance measured by head (and trunk) tracking and a force platform in chemically (PCB and TCE) exposed and referent subjects. Occup Environ Med 51:381–385.8044229
Kim D, Ghanayem BI. 2006. Comparative metabolism and disposition of trichloroethylene in Cyp2e1-/- and wild-type mice. Drug Metab Dispos 34(12):2020–2027.16959879
Kim S, Collins LB, Boysen G, . 2009a. Liquid chromatography electrospray ionization tandem mass spectrometry analysis method for simultaneous detection of trichloroacetic acid, dichloroacetic acid, S-(1,2-dichlorovinyl)glutathione and S-(1,2-dichlorovinyl)-L-cysteine. Toxicology 262(3):230–238.19549554
Kim S, Kim D, Pollack GM, . 2009b. Pharmacokinetic analysis of trichloroethylene metabolism in male B6C3F1 mice: Formation and disposition of trichloroacetic acid, dichloroacetic acid, S-(1,2-dichlorovinyl)glutathione and S-(1,2-dichlorovinyl)-L-cysteine. Toxicol Appl Pharmacol 238(1):90–99.19409406
Kim SK, Chang H, Zellers ET. 2011. Microfabricated gas chromatograph for the selective determination of trichloroethylene vapor at sub-parts-per-billion concentrations in complex mixtures. Anal Chem 83(18):7198–7206.21859085
*Kimbrough RD, Mitchell FL, Houk VN. 1985. Trichloroethylene: An update. J Toxicol Environ Health 15:369–383.3897556
Kimmerle G, Eben A. 1973a. Metabolism, excretion and toxicology of trichloroethylene after inhalation. 1. Experimental exposures on rats. Arch Toxikol 30:115–126.4685263
Kimmerle G, Eben A. 1973b. Metabolism, excretion and toxicology of trichloroethylene after inhalation. 2. Experimental human exposure. Arch Toxikol 30:127–138.4685264
Kinney PL, Chillrud SN, Ramstrom S, . 2002. Exposures to multiple air toxics in New York City. Environ Health Perspect 110(Suppl 4):539–546.12194883
Kirchner K, Helf D, Ott P, . 1990. The reaction of OH radicals with 1,1-di-, tri-, and tetrachloroethylene. Ber Bunsenges Phys Chem 94:77–83.
Kishi R, Harabuchi I, Ikeda T, . 1993. Acute effects of trichloroethylene on blood concentrations and performance decrements in rats and their relevance to humans. Br J Ind Med 50:470–480.8507600
Kjellstrand P, Holmquist B, Alm P, . 1983a. Trichloroethylene: Further studies of the effects on body and organ weights and plasma butyrylcholinesterase activity in mice. Acta Pharmacol Toxicol 53:375–384.
Kjellstrand P, Holmquist B, Mandahl N, . 1983b. Effects of continuous trichloroethylene inhalation on different strains of mice. Acta Pharmacol Toxicol 53:369–374.
Kjellstrand P, Kanje M, Bjerkemo M. 1987. Regeneration of the sciatic nerve in mice and rats exposed to trichloroethylene. Toxicol Lett 38(1–2):187–191.3629629
Kjellstrand P, Kanje M, Mansson L, . 1981. Trichloroethylene: Effects on body and organ weights in mice, rats and gerbils. Toxicology 21:105–115.7281199
*Klaassen CD. 1985. Nonmetallic environmental toxicants: Air pollutants, solvents, and vapors, and pesticides. In: Gilman AG, Goodman LS, Rall TW, ., eds. Goodman and Gilman’s: The pharmacological basis of therapeutics. 7th ed. New York, NY: MacMillan Publishing Co., 1628–1637.
Klaunig JE, Babich MA, Baetcke KP, . 2003. PPARα agonist-induced rodent tumors: Modes of action and human relevance. Crit Rev Tox 33(6):655–780.
*Klaunig JE, Ruch RJ, Pereira MA. 1986. Carcinogenicity of chlorinated methane and ethane compounds administered in drinking water to mice. Environ Health Perspect 69:89–95.3816740
Klaunig JE, Siglin JC, Schafer LD, . 1991. Correlation between species and tissue sensitivity to chemical carcinogenesis in rodents and the induction of DNA synthesis. Prog Clin Biol Res 369:185–194.1946517
Kleinfeld M, Tabershaw IR. 1954. Trichloroethylene toxicity: Report of five fatal cases. Arch Ind Hyg Occup Med 10:134–141.
Kligerman AD, Bryant MF, Doerr CL, . 1994. Inhalation studies of the genotoxicity of trichloroethylene to rodents. Mutat Res 322:87–96.7519326
Kobayashi R, Ikemoto T, Seo M, . 2010. Enhancement of immediate allergic reactions by trichloroethylene ingestion via drinking water in mice. J Toxicol Sci 35(5):699–707.20930464
Kobayashi R, Nakanishi T, Nagase H. 2012. Trichloroethylene enhances TCR-CD3-induced proliferation of CD8+ rather than CD4+ T cells. J Toxicol Sci 37(2):381–387.22467029
Koch R, Schlegelmilch R, Wolf HU. 1988. Genetic effects of chlorinated ethylenes in the yeast Saccharomyces cerevisiae. Mutat Res 206:209–216.3050501
Kohlmüller D, Kochen W. 1994. Exhalation air analyzed in long-term postexposure investigations of acetonitrile and trichloroethylene exposures in two subjects. Clin Chem 40:1462–1464.
*Koizumi A. 1989. Potential of physiologically based pharmacokinetics to amalgamate kinetic data of trichloroethylene and tetrachloroethylene obtained in rats and man. Br J Ind Med 46:239–249.2713280
Koizumi A, Fujita H, Sadamoto T, . 1984. Inhibition of δ-aminolevulinic acid dehydratase by trichloroethylene. Toxicology 30:93–102.6710543
Koizumi A, Kastl PE, Reitz RH, . 1986. Fate of ^14^C-trichloroethylene administered to rats in drinking water. DOW Chemical USA, Health and Environmental Sciences, Mammalian and Environmental Toxicology, Midland, Michigan.
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Konietzko H. 1979. [Health damage due to trichloroethylene: An epidemiological and experimental clinical study.] Fortscritte der Medisin 97(14):671–679. (German)
Konietzko H, Elster I. 1973. [Toxic effects on heart of trichloroethylene.] Arch Toxikol 31:93–98. (German)4127014
Konietzko H, Reill G. 1980. The effect of trichloroethylene on some serum enzymes and on the cytoenzymological activity in leucocytes and on the acid base equilibrium. Int Arch Occup Environ Health 47:61–67.7429647
Konietzko H, Elster I, Bengsath A. 1975a. [EEG variation with controlled exposure to trichloroethylene.] Int Arch Occup Environ Health 35:257–264. (German)1176181
*Konietzko H, Elster I, Bengsath A, . 1975b. [Psychomotor reactions under standardized trichloroethylene load.] Arch Toxicol 33:129–139. (German)1242298
Konietzko H, Elster I, Vetter K, . 1974. Field studies in solvent factories: Second communication: Telemetric EEG monitoring of solvent workers at trichloroethylene basins. Arbeitsschutz 23:129–133.
Konietzko H, Haberlandt W, Heilbronner H, . 1978. [Chromosome studies on trichloroethylene workers.] Arch Toxicol 40:201–206. (German)581058
*König HP, Lahl U, Kock H. 1987. Determination of organic volatiles in ambient air in the area of a landfill. J Aerosol Sci 18:837–840.
*Kössler F. 1991. Trichloroethylene interactions with muscle cells. J Appl Toxicol 11:189–194.1918792
Kosson DS, Dienemann EA, Ahlert RC. 1985. Characterization and treatability studies of an industrial landfill leachate (Kin-Buc I). Proc Ind Waste Conf 39:329–341.
Kostrzewski P, Jakubowski M, Kolacinski Z. 1993. Kinetics of trichloroethylene elimination from venous blood after acute inhalation poisoning. Clin Toxicol 31:353–363.
Kotelchuck M, Parker G. 1979. Woburn Health Data Analysis, 1969-1979. Boston, MA: Massachusetts Department of Health.
Krause RJ, Lash LH, Elfarra AA. 2003. Human kidney flavin-containing monooxygenases and their potential roles in cysteine S-conjugate metabolism and nephrotoxicity. J Pharmacol Exp Ther 304(1):185–191.12490590
Krishnadasan A, Kennedy N, Zhao Y, . 2007. Nested case-control study of occupational chemical exposures and prostate cancer in aerospace and radiation workers. Am J Ind Med 50(5):383–390. 10.1002/ajim.20458.17407146
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kroneld R. 1989. Volatile pollutants in suburban and industrial air. Bull Environ Contam Toxicol 42:868–872.2743019
Krost KJ, Pellizzari ED, Walburn SG, . 1982. Collection and analysis of hazardous organic emissions. Anal Chem 54:810–817.
Kulig BM. 1987. The effects of chronic trichloroethylene exposure on neurobehavioral functioning in the rat. Neurotoxicol Teratol 9:171–178.3657753
Kumar P, Prasad AK, Dutta KK. 2000a. Steroidogenic alterations in testes and sera of rats exposed to trichloroethylene (TCE) by inhalation. Hum Exp Toxicol 19(2):117–121.10773841
Kumar P, Prasad AK, Maji BK, . 2001a. Hepatotoxic alterations induced by inhalation of trichloroethylene (TCE) in rats. Biomed Environ Sci 14(4):325–332.11862613
Kumar P, Prasad AK, Mani U, . 2001b. Trichloroethylene induced testicular toxicity in rats exposed by inhalation. Hum Exp Toxicol 20(11):585–589.11926613
Kumar P, Prasad AK, Mani U, . 2002a. Effect of trichloroethylene (TCE) inhalation on biotransformation enzymes of rat lung and liver. J Environ Biol 23(1):1–6.12617310
Kumar P, Prasad AK, Saxena DK, . 2000b. Fertility and general reproduction studies in trichloroethylene exposed rats. Indian J Occup Health 43(3):117–126.
Kumar P, Purohit DC, Prasad AK, . 2002b. Histobiochemical alterations in rat lungs induced by inhalation of trichloroethylene. J Ecophysiol Occup Health 2:265–274.
Kylin B, Axell K, Samuel HE, . 1967. Effect of inhaled trichloroethylene on the CNS as measured by optokinetic nystagmus. Arch Environ Health 15:48–52.4951693
Kylin B, Reichard H, Sumegi I, . 1962. Hepatoxic effect of tri- and tetrachloroethylene on mice. Nature (London) 193:395.14461126
Lachnit V, Pietschmann H. 1960. Activity of serum glutamic oxaloacetic transaminase and aldolase in workers exposed to halogenated hydrocarbons. Ind Med Surg 29:523–525.13758077
Lagakos SW, Wessen BJ, Zelen M. 1986a. An analysis of contaminated well water and health effects in Woburn, Massachusetts. J Am Stat Assoc 81:583–596.
Lagakos SW, Wessen BJ, Zelen M. 1986b. Rejoinder [Letter]. J Am Stat Assoc 81:611–614.
Laham S. 1970. Studies on placental transfer: Trichloroethylene. Ind Med 39:46–49.
Laib RJ, Stockle G, Bolt HM, . 1979. Vinyl chloride and trichloroethylene: Comparison of alkylating effects of metabolites and induction of preneoplastic enzyme deficiencies in rat liver. J Can Res Clin Oncol 94:139–147.
Lan Q, Zhang L, Tang X, . 2010. Occupational exposure to trichloroethylene is associated with a decline in lymphocyte subsets and soluble CD27 and CD30 markers. Carcinogenesis 31(9):1592–1596.20530238
Land PC, Owen EL, Linde HW. 1981. Morphologic changes in mouse spermatozoa after exposure to inhalation anesthetics during early spermatogenesis. Anesthesiology 54:53–56.6109470
*Landrigan PJ, Stein GF, Kominsky JR, . 1987. Common-source community and industrial exposure to trichloroethylene. Arch Environ Health 42:327–332.3439809
Lapare S, Tardif R, Brodeur J. 1995. Effect of various exposure scenarios on the biological monitoring of organic solvents in alveolar air. II. 1,1,1-Trichloroethane and trichloroethylene. Int Arch Occup Environ Health 67(6):375–394.8567088
Larson JL, Bull RJ. 1989. Effect of ethanol on the metabolism of trichloroethylene. J Toxicol Environ Health 28:395–406.2593173
Larson JL, Bull RJ. 1992b. Metabolism and lipoperoxidative activity of trichloroacetate and dichloroacetate in rats and mice. Toxicol Appl Pharmacol 115:268–277.1641860
Larson JL, Bull RJ. 1992a. Species differences in the metabolism of trichloroethylene to the carcinogenic metabolites trichloroacetate and dichloroacetate. Toxicol Appl Pharmacol 115:278–285.1641861
Lash LH, Anders MW. 1989. Uptake of nephrotoxic S-conjugates by isolated rat renal proximal tubular cells. J Pharmacol Exp Ther 248(2):531–537.2918469
Lash LH, Chiu WA, Guyton KZ, . 2014. Trichloroethylene biotransformation and its role in mutagenicity, carcinogenicity and target organ toxicity. Mutat Res/ Rev Mutat Res 762:22–36. 10.1016/j.mrrev.2014.04.003.25484616
Lash LH, Fisher JW, Lipscomb JC, . 2000a. Metabolism of trichloroethylene. Environ Health Perspect 108(Suppl 2):177–200.
Lash LH, Jones DP, Anders MW. 1988. Glutathione homeostasis and glutathione S- conjugate toxicity in kidney. Rev Biochem Toxicol 9:29–67.
Lash LH, Lipscomb JC, Putt DA, . 1999b. Glutathione conjugation of trichloroethylene in human liver and kidney: Kinetics and individual variation. Drug Metab Dispos 27(3):351–359.10064565
Lash LH, Parker JC, Scott CS. 2000b. Modes of action of trichloroethylene for kidney tumorigenesis. Environ Health Perspect 108(Suppl 2):225–240.
Lash LH, Putt DA, Brashear WT, . 1999a. Identification of S-(1,2-dichlorovinyl)glutathione in the blood of human volunteers exposed to trichloroethylene. J Toxicol Environ Health A 56(1):1–21.9923751
Lash LH, Putt DA, Parker JC. 2006. Metabolism and tissue distribution of orally administered trichloroethylene in male and female rats: Identification of glutathione- and cytochrome P-450-derived metabolites in liver, kidney, blood, and urine. J Toxicol Environ Health A 69(13):1285–1309.16754541
Lash LH, Qian W, Putt DA, . 1998. Glutathione conjugation of trichloroethylene in rats and mice: Sex-, species-, and tissue-dependent differences. Drug Metab Dispos 26(1):12–19.9443846
Lash LH, Xu Y, Elfarra AA, . 1995. Glutathione-dependent metabolism of trichloroethylene in isolated liver and kidney cells of rats and its role in mitochondrial and cellular toxicity. Drug Metab Dispos 23:846–853.7493552
Laughter AR, Dunn CS, Swanson CL, . 2004. Role of the peroxisome proliferator-activated receptor α (PPARα) in responses to trichloroethylene and metabolites, trichloroacetate and dichloroacetate in mouse liver. Toxicology 203(1–3):83–98.15363585
Laureno R. 1993. Trichloroethylene does not cause trigeminal neuropathy. Muscle Nerve 16(2):217.
*Lauwerys RL. 1983. Industrial chemical exposure: Guidelines for biological monitoring. Davis, CA: Biomedical Publications, 87–91.
La Vecchia C, Negri E, Franceschi S, . 1994. A case-control study of diabetes mellitus and cancer risk. Br J Cancer 70:950–953.7947103
Lawrence WH, Partyka EK. 1981. Chronic dysphagia and trigeminal anesthesia after trichloroethylene exposure. Ann Intern Med 95:710.7305154
Leandri M, Schizzi R, Scielzo C, . 1995. Electrophysiological evidence of trigeminal root damage after trichloroethylene exposure. Muscle Nerve 18:467–468.7715634
Lee KM, Bruckner JV, Muralidhara S, . 1996. Characterization of presystemic elimination of trichloroethylene and its nonlinear kinetics in rats. Toxicol Appl Pharmacol 139:262–271.8806842
Lee KM, Muralidhara S, Schnellmann RG, . 2000a. Contribution of direct solvent injury to the dose-dependent kinetics of trichloroethylene: Portal vein administration to rats. Toxicol Appl Pharmacol 164(1):46–54.10739743
Lee KM, Muralidhara S, White CA, . 2000b. Mechanisms of the dose-dependent kinetics of trichloroethylene: Oral bolus dosing of rats. Toxicol Appl Pharmacol 164(1):55–64.10739744
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehmann I, Thoelke A, Rehwagen M, . 2002. The influence of maternal exposure to volatile organic compounds on the cytokine secretion profile of neonatal T cells. Environ Toxicol 17:203–210.12112628
Leighton DT, Calo JM. 1981. Distribution coefficients of chlorinated hydrocarbons in dilute air-water systems for groundwater contamination applications. J Chem Eng Data 26:383–385.
*Leikin JB, Paloucek FP. 2002. Trichloroethylene. In: Poisoning & toxicology handbook. 3rd ed. Hudson, OH: Lexi-Comp, Inc., 1212–1213.
*Le Mesurier SM, Lykke AW, Stewart BW. 1980. Reduced yield of pulmonary surfactant: Patterns of response following administration of chemicals to rats by inhalation. Toxicol Lett 5:89–93.6892858
Leung HW. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Lewis GD, Reynolds RC, Johnson AR. 1984. Some effects of trichloroethylene on mouse lungs and livers. Gen Pharmacol 15:139–144.6425111
*Li H, Dai Y, Huang H, . 2007. HLA-B1301 as a biomarker for genetic susceptibility to hypersensitivity dermatitis induced by trichloroethylene among workers in China. Environ Health Perspect 115(11):1553–1556.18007983
Ligocki MP, Leuenberger C, Pankow JF. 1985. Trace organic compounds in rain. II. Gas scavenging of neutral organic compounds. Atmos Environ 19:1609–1617.
Lindbohm ML, Taskinen H, Sallmen M, . 1990. Spontaneous abortions among women exposed to organic solvents. Am J Ind Med 17(4):449–463 2327413
Liotier J, Barbier M, Plantefeve G, . 2008. A rare cause of abdominal compartment syndrome: Acute trichloroethylene overdose. Clin Toxicol (Phila) 46(9):905–907 19003597
Lipscomb JC, Garrett CM, Snawder JE. 1997. Cytochrome P-450-dependent metabolism of trichloroethylene: Interindividual differences in humans. Toxicol Appl Pharmacol 142:311–318.9070354
Lipworth L, Sonderman JS, Mumma MT, . 2011. Cancer mortality among aircraft manufacturing workers: An extended follow-up. J Occup Environ Med 53(9):992–1007. 10.1097/JOM.0b013e31822e0940.21866047
*Liu YT, Jin C, Chen Z, . 1988. [Increased subjective symptom prevalence among workers exposed to trichloroethylene at sub-OEL levels.] Tohoku J Exp Med 155:183–195. (Japanese)3212780
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Loeber CP, Hendrix MJC, DePinos SD, . 1988. Trichloroethylene: A cardiac teratogen in developing chick embryos. Pediatr Res 24:740–744.3205631
Loh MM, Houseman EA, Gray GM, . 2006. Measured concentrations of VOCs in several non-residential microenvironments in the United States. Environ Sci Technol 40(22):6903–6911.17153993
Longley EO, Jones R. 1963. Acute trichloroethylene narcosis. Arch Environ Health 7:249–252.14047582
*Luster MI, Dean JH, Moore JA. 1982. Evaluation of immune functions on toxicology. In: Hayes AW, ed. Principles and methods of toxicology. New York, NY: Raven Press, 561–586.
*Mackay D, Shiu WY. 1981. A critical review of Henry’s law constants for chemicals of environmental interest. J Phy Chem Ref Data 19:1175–1179.
MacMahon B. 1986. Comment. J Am Stat Assoc 21:597–599.
Makide Y, Tominaga T, Rowland FS. 1979. [Gas chromatographic analysis of halogenated hydrocarbons in air over Japan.] Chemistry Lett (Chemical Society of Japan) 4:355–358. (Japanese)
*Malek B, Kremarova B, Rodova A. 1979. [An epidemiological study of hepatic tumor incidence in subjects working with trichloroethylene. II. Negative result of retrospective investigations in dry cleaners.] Prac Lek 31:124–126. (Czech)
Maltoni C, Lefemine G, Cotti G. 1986. Experimental research on trichloroethylene carcinogenesis. Princeton, NJ: Princeton Scientific Publishing Co., Inc. 45–81, 93, 99–100, 112, 116, 130, 136–153, 157–186, 240–393.
Maltoni C, Lefemine G, Cotti G, . 1988. Long-term carcinogenicity bioassays on trichloroethylene administered by inhalation to Sprague-Dawley rats and Swiss and B6C3F1 mice. Ann NY Acad Sci 534:316–342.3389663
Mandel JH, Kelsh MA, Mink PJ, . 2006. Occupational trichloroethylene exposure and non-Hodgkin’s lymphoma: A meta-analysis and review. Occup Environ Med 63(9):597–607. 10.1136/oem.2005.022418.16644896
*Mannsville. 1992. Chemical product synopsis: Trichloroethylene. Cortland, NY: Mannsville Chemical Products Corp.
Manson JM, Murphy M, Richdale N, . 1984. Effect of oral exposure to trichloroethylene on female reproductive function. Toxicology 32:229–242.6474485
Marie I, Gehanno JF, Bubenheim M, . 2014. Prospective study to evaluate the association between systemic sclerosis and occupational exposure and review of the literature. Autoimmun Rev 13(2):151–156. 10.1016/j.autrev.2013.10.002.24129037
Martin SA, Simmons MB, Ortiz-Serrano M, . 2005. Environmental exposure of a community to airborne trichloroethylene. Arch Environ Occup Health 60(6):314–316.17447576
*Martindale W. 1977. Halothane and general anaesthetics. In: Wade A, ed. The extra pharmacopoeia: Incorporating Squire’s “Companion.” 27th ed. London: Pharmaceutical Press, 714–715.
Mattei F, Guida F, Matrat M, . 2014. Exposure to chlorinated solvents and lung cancer: Results of the ICARE study. Occup Environ Med 71(10):681–689. 10.1136/oemed-2014-102182.25015929
Maymo-Gatell X, Chien Y, Gosset JM, . 1997. Isolation of a bacterium that reductively dechlorinates tetrachloroethene to ethene. Science 276:1568–1571.9171062
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
*Mazza V, Brancaccio A. 1967. [Characteristics of the formed elements of the blood and bone marrow in experimental trichloroethylene intoxication.] Folia Med 50:318–324. (Italian)
Mazzullo M, Bartoli S, Bonora A, . 1992. In vivo and in vitro interaction of trichloroethylene with macromolecules from various organs of rat and mouse. Res Commun Chem Pathol Pharmacol 76:192–208.1376481
McCarthy TB, Jones RD. 1983. Industrial gassing poisonings due to trichloroethylene, perchloroethylene, and 1,1,1-trichloroethane, 1961-80. Br J Ind Med 40:450–455.6626474
McCarthy MC, Hafner HR, Chinkin LR, . 2007. Temporal variability of selected air toxics in the United States. Atmos Environ 41(34):7180–7194. 10.1016/j.atmosenv.2007.05.037. http://www.sciencedirect.com/science/article/pii/S1352231007004840.
McCarthy MC, Hafner HR, Montzka SA. 2006. Background concentrations of 18 air toxics for North America. J Air Waste Manage Assoc 56:3–11.
McConnell G, Ferguson DM, Pearson CR. 1975. Chlorinated hydrocarbons and the environment. Endeavour 34:13–8.54249
McCormick K, Abdel-Rahman MS. 1991. The role of testosterone in trichloroethylene penetration in vitro. Environ Res 54:82–92.2004639
McCunney RJ. 1988. Diverse manifestations of trichloroethylene. Br J Ind Med 45:122–126.3342194
McDonald GJ, Wertz WE. 2007. PCE, TCE, and TCA vapors in subslab soil gas and indoor air: A case study in upstate New York. Ground Water Monit Remed 27(4):86–92.
McGregor DB, Reynolds DM, Zeiger E. 1989. Conditions affecting the mutagenicity of trichloroethylene in Salmonella. Environ Mol Mutagen 13:197–202.2651116
*McKinney LL, Weakley FB, Eldridge AC, . 1957. S-(dichlorovinyl)-L-cysteine: An agent causing fatal aplastic anemia in calves. J Am Chem Soc 79:3932–3933.
McKinney PA, Alexander FE, Cartwright RA, . 1991. Parental occupations of children with leukaemia in west Cumbria, North Humberside, and Gateshead. Br Med J 302:681–687.2021741
McKone TE. 1987. Human exposure to volatile organic compounds in household tap water: The indoor inhalation pathway. Environ Sci Technol 21:1194–1201.
McKone TE, Knezovich JP. 1991. The transfer of trichloroethylene (TCE) from a shower to indoor air: Experimental measurements and their implications. J Air Waste Manag Assoc 41:832–837.
McLaren J, Boulikas T, Vamvakas S. 1994. Induction of poly(ADP-ribosyl)ation in the kidney after in vivo application of renal carcinogens. Toxicology 88:101–112.8160192
*McLean D, Pearce N, Langseth H, . 2006. Cancer mortality in workers exposed to organochlorine compounds in the pulp and paper industry: An international collaborative study. Environ Health Perspect 114(7):1007–1012.16835051
McNab WW, Narasimhan TN. 1994. Degradation of chlorinated hydrocarbons and groundwater geochemistry: A field study. Environ Sci Technol 28:769–775.22191815
McNeill WC. 1979. Trichloroethylene. In: Grayson M, Eckroth P, eds. Kirk-Othmer encyclopedia of chemical technology. 3rd ed. Vol. 5. New York, NY: John Wiley and Sons, Inc., 745–753.
MDPH. 1996. Final report of the Woburn environmental and birth study draft for public comment. Volume 1: Analysis of reproductive outcomes and environmental exposures in Woburn, MA. Massachusetts Department of Public Health, Bureau of Environmental Health Assessment, Massachusetts of Health Research Institute in collaboration with the Division of Birth Defects and Developmental Disabilities, U.S. Centers for Disease Control and Prevention.
MDPH. 1997. Woburn Childhood Leukemia Follow-up Study. Volume I. Analyses. Final report. Massachusetts Department of Public Health. Bureau of Environmental Health Assessment. Boston, Massachusetts.
Melnick RL, Jameson CW, Goehl TJ, . 1987. Application of microencapsulation for toxicology studies. II. Toxicity of microencapsulated trichloroethylene in Fischer 344 rats. Fundam Appl Toxicol 8(4):432–442.3111923
Mensing T, Welge P, Voss B, . 2002. Renal toxicity after chronic inhalation exposure of rats to trichloroethylene. Toxicol Lett 128(1–3):243–247.11869834
Merdink JL, Gonzalez-Leon A, Bull RJ, . 1998. The extent of dichloroacetate formation from trichloroethylene, chloral hydrate, trichloroacetate, and trichloroethanol in B6C3F1 mice. Toxicol Sci 45(1):33–41.9848108
Merdink JL, Stenner RD, Stevens DK, . 1999. Effect of enterohepatic circulation on the pharmacokinetics of chloral hydrate and its metabolites in F344 rats. J Toxicol Environ Health A 57(5):357–368.10405189
Merrick BA, Robinson M, Condie LW. 1989. Differing hepatotoxicity and lethality after subacute trichloroethylene exposure in aqueous or corn oil gavage vehicles in B6C3F1 mice. J Appl Toxicol 9:15–21.2926094
Mertens JA. 2000. Trichloroethylene. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc., 1–10. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.2018090313051820.a01/abstract. November 2, 2011.
Mhiri C, Choyakh F, Ben Hmida M, . 2004. Trigeminal somatosensory evoked potentials in trichloroethylene-exposed workers. Neuroscience 9(2):102–107.
Michael LC, Erickson MD, Parks SP, . 1980. Volatile environmental pollutants in biological matrices with a headspace purge technique. Anal Chem 52:1836–1841.7435989
*Mikiskova H, Mikiska A. 1966. Trichloroethanol in trichloroethylene poisoning. Br J Ind Med 23:116–125.5929685
Milby TH. 1968. Chronic trichloroethylene intoxication. J Occup Med 10:252–254.5651787
Milde G, Nerger M, Mergler R. 1988. Biological degradation of volatile chlorinated hydrocarbons in groundwater. Water Sci Technol 20(3):67–73.
Miligi L, Costantini AS, Benvenuti A, . 2006. Occupational exposure to solvents and the risk of lymphomas. Epidemiology 17(5):552–561.16878041
Miller PW, Mycyk MB, Leikin JB, . 2002. An unusual presentation of inhalant abuse with dissociative amnesia. Vet Hum Toxicol 44(1):17–19.11824766
Miller RE, Guengerich FP. 1982. Oxidation of trichloroethylene by liver microsomal cytochrome P-450: Evidence for chlorine migration in a transition state not involving trichloroethylene oxide. Biochemistry 21:1090–1097.7074051
Miller RE, Guengerich FP. 1983. Metabolism of trichloroethylene in isolated hepatocytes, microsomes, and reconstituted systems containing cytochrome P-450. Cancer Res 43:1145–1152.6825087
Millet DB, Atlas EL, Blake DR, . 2009. Halocarbon emissions from the United States and Mexico and their global warming potential. Environ Sci Technol 43(4):1055–1060.19320157
Mirsalis JC, Tyson CK, Steinmetz KL, . 1989. Measurement of unscheduled DNA synthesis and S-phase synthesis in rodent hepatocytes following in vivo treatment: Testing of 24 compounds. Environ Mol Mutagen 14:155–164.2792091
Mishima N, Hoffman S, Hill EG, . 2006. Chick embryos exposed to trichloroethylene in an ex ovo culture model show selective defects in early endocardial cushion tissue formation. Birth Defects Res A Clin Mol Teratol 76(7):517–527.16933305
Mitchell ABS, Parsons-Smith BG. 1969. Trichloroethylene neuropathy. Br Med J 1:422–423.4303442
*Monstad P, Mellgren SI, Sulg IA. 1992. The clinical significance of sleep apnea in workers exposed to organic solvents: Implications for the diagnosis of organic solvent encephalopathy. J Neurol 239:195–198.1597686
*Monstad P, Nissen T, Sulg IA, . 1987. Sleep apnea and organic solvent exposure. J Neurol 234:152–154.3585422
*Monster AC. 1988. Biological markers of solvent exposure. Arch Environ Health 43:90–93.3377562
Monster AC, Boersma G. 1975. Simultaneous determination of trichloroethylene and metabolites in blood and exhaled air by gas chromatography. Int Arch Occup Environ Health 35:155–163.1184206
Monster AC, Boersma G, Duba WC. 1976. Pharmacokinetics of trichloroethylene in volunteers: Influence of workload and exposure concentration. Int Arch Occup Environ Health 38:87–102.1002309
Monster AC, Boersma G, Duba WC. 1979. Kinetics of trichloroethylene in repeated exposure of volunteers. Int Arch Occup Environ Health 42:283–292.422269
Montani D, Lau EM, Descatha A, . 2015. Occupational exposure to organic solvents: A risk factor for pulmonary veno-occlusive disease. Eur Respir J 46(6):1721–1731. 10.1183/13993003.00814-2015.26541523
Moore LE, Boffetta P, Karami S, . 2010. Occupational trichloroethylene exposure and renal carcinoma risk: Evidence of genetic susceptibility by reductive metabolism gene variants. Cancer Res 70(16):6527–6536.20663906
Morgan RW, Kelsh MA, Zhao K, . 1998. Mortality of aerospace workers exposed to trichloroethylene. Epidemiology 9(4):424–431.9647907
Moritz F, de La Chapelle A, Bauer F, . 2000. Esmolol in the treatment of severe arrhythmia after acute trichloroethylene poisoning. Intensive Care Med 26(2):256.10784325
Morreale SA. 1976. A case of acute trichloroethylene poisoning with myocardial infarction. Med Lav 67:176–182.1021711
Morris LE, Noltensmeyer MH, White JM. 1953. Epinephrine induced cardiac irregularities in the dog during anesthesia with trichloroethylene, cyclopropane, ethyl chloride and chloroform. Anesthesiology 14:153–158.13031151
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Mortelmans K, Haworth S, Lawlor T, . 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(Suppl 7):1–119.
Moser VC, Cheek BM, MacPhail RC. 1995. A multidisciplinary approach to Toxicological screening: III. Neurobehavioral toxicity. J Toxicol Environ Health 45:173–210.7783252
Moser VC, MacPhail RC, Gennings C. 2003. Neurobehavioral evaluations of mixtures of trichloroethylene, heptachlor, and di(2-ethylhexyl)phthlate in a full-factorial design. Toxicology 188(2–3):125–137.12767685
Moslen MT, Reynolds ES, Szabo S. 1977. Enhancement of the metabolism and hepatotoxicity of trichloroethylene and perchloroethylene. Biochem Pharmacol 26:369–375.192239
Motohashi Y, Miyazaki Y. 1990. Time-dependent effects on trichloroethylene on motor activity in rats. Chronobiol Int 7:193–201.2268881
Motwani JN, Popp SA, Johnson GM, . 1986. Field screening techniques developed under the superfund program. The 7th National Conference on Management of Uncontrolled Hazardous Waste Sites. December 1-3, 1986, Washington, DC, 105–109.
Mouvet C, Barberis D, Bourg ACM. 1993. Adsorption isotherms of tri- and tetrachloroethylene by various natural solids. J Hydrol 149:163–182.
Mu DY, Scow KM. 1994. Effect of trichloroethylene (TCE) and toluene concentrations on TCE and toluene biodegradation and the population density of TCE and toluene degraders in soil. Appl Environ Microbiol 60:2661–2665.8074538
Muijser H, Lammers JH, Kullig BM. 2000. Effects of exposure to trichloroethylene and noise on hearing in rats. Noise Health 2(6):57–66.12689479
Mulholland JA, Sarofim AF, Sosothikul P, . 1992. Formation of perchloroaromatics during trichloroethylene pyrolysis. Combust Flame 89:103–115.
Müller G, Spassovski M, Henschler D. 1972. Trichloroethylene exposure and trichloroethylene metabolites in urine and blood. Arch Toxicol 29:335–340.
Müller G, Spassovski M, Henschler D. 1974. Metabolism of trichloroethylene in man. II. Pharmacokinetics of metabolites. Arch Toxicol 32:283–295.4480028
Müller G, Spassowski M, Henschler D. 1975. Metabolism of trichloroethylene in man. III. Interaction of trichloroethylene and ethanol. Arch Toxicol 33:173–189.1173750
*Müller WF, Coulston F, Korte F. 1982. Comparative metabolism of 14C-trichloroethylene in chimpanzees, baboons, and rhesus monkeys. Chemosphere 11:215–218.
Mumtaz NM, Neft RE, Lichtueld MY, . 1994. The public health impact of chemicals and chemical mixture by-products at hazardous waste sites. In: Andrews JS, Frumkin H, Johnson BL, ., eds. Hazardous Waste and Public Health: International Congress on the Health Effects of Hazardous Waste. Princeton, NJ: Princeton Scientific Publishing Co., Inc., 508–516.
*Munz C, Roberts PV. 1987. Air-water phase equilibria of volatile organic solutes. J Am Water Works Assoc 79:62–69.
Murata K, Inoue O, Akutsu M, . 2010. Neuromotor effects of short-term and long-term exposures to trichloroethylene in workers. Am J Ind Med 53(9):915–921.20698023
Murray AJ, Riley JP. 1973. Occurrence of some chlorinated aliphatic hydrocarbons in the environment. Nature 242:37–38.4550019
Murry DJ, Crom WR, Reddick WE, . 1995. Liver volume as a determinant of drug clearance in children and adolescents. Drug Metab Dispos 23(10):1110–1116.8654200
Nagaya T, Ishikawa N, Hata H. 1989a. Sister-chromatid exchanges in lymphocytes of workers exposed to trichloroethylene. Mutat Res 222:279–282.2922011
Nagaya T, Ishikawa N, Hata H. 1989b. Urinary total protein and β2-microglobulin in workers exposed to trichloroethylene. Environ Res 50:86–92.2676510
Nagaya T, Ishikawa N, Hata H. 1990. No change in serum dopamine-β-hydroxylase activity in workers exposed to trichloroethylene. Toxicol Lett 54:221–227.2260120
Nagaya T, Ishikawa N, Hata H, . 1993. Subclinical and reversible hepatic effects of occupational exposure to trichloroethylene. Int Arch Occup Environ Health 64:561–563.8314614
*Naish N. 1945. Poisoning by accidental drinking of trichloroethylene. Br Med J 2:367.
Nakajima T, Kamijo Y, Usuda N, . 2000. Sex-dependent regulation of hepatic peroxisome proliferation in mice by trichloroethylene via peroxisome proliferator-activated receptor α (PPARα). Carcinogenesis 21(4):677–682.10753203
Nakajima T, Murayama N, Owa O, . 1990a. [Trichloroethylene concentration in work environment in relation to the development of pneumatosis cystoides intestinalis.] Sangyo Igaku 32:454–460. (Japanese)2287093
Nakajima T, Wang RS, Elovaara E, . 1992a. A comparative study on the contribution of cytochrome P-450 isozymes to metabolism of benzene, toluene and trichloroethylene in rat liver. Biochem Pharmacol 43:251–257.1739413
Nakajima T, Wang RS, Elovaara E, . 1993. Cytochrome P-450-related differences between rats and mice in the metabolism of benzene, toluene and trichloroethylene in liver microsomes. Biochem Pharmacol 45:1079–1085.8461037
Nakajima T, Wang RS, Katakura Y, . 1992b. Sex-, age- and pregnancy-induced changes in the metabolism of toluene and trichloroethylene in rat liver in relation to the regulation of cytochrome P-450IIE1 and cytochrome P-450IIC11 content. J Pharmacol Exp Ther 261:869–874.1602390
Nakajima T, Wang RS, Murayama N, . 1990b. Three forms of trichloroethylene-metabolizing enzymes in rat liver induced by ethanol, phenobarbital, and 3-methylcholanthrene. Toxicol Appl Pharmacol 102:546–552.2315921
Nakayama H, Kobayashi M, Takahashi M, . 1988. Generalized eruption with severe liver dysfunction associated with occupational exposure to trichloroethylene. Contact Dermatitis 19:48–51.2972510
Narotsky MG, Kavlock RJ. 1995. A multidisciplinary approach to toxicological screening: II. Developmental toxicity. J Toxicol Environ Health 45:145–171.7783251
Narotsky MG, Weller EA, Chinchilli VM, . 1995. Nonadditive developmental toxicity in mixtures of trichloroethylene, di(2-ethylhexyl) phthalate, and heptachlor in a 5 x 5 x 5 design. Fund Appl Toxicol 27:203–216.
*NAS. 1980. Drinking water and health. Volume 3. National Academy of Sciences, Safe Drinking Water Committee. Washington, DC: National Academy Press.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: 15–35.
NCI. 1976. Carcinogenesis bioassay of trichloroethylene (CAS No. 79-01-6). Bethesda, MD: National Cancer Institute, Division of Cancer Cause and Prevention, Carcinogenesis Program, Carcinogen Bioassay and Program Resources Branch. NCI-CG-TR-2, DHEW Publ. No. (NIH) 76-802.
NCI. 1985. Final report. Monograph on human exposure to chemicals in the workplace: Trichloroethylene. National Cancer Institute. Division of Cancer Etiology. Bethesda, MD. PB86147220.
Neely WB, Branson DR, Blau GE. 1974. Partition coefficients to measure bioconcentration potential of organic chemicals in fish. Environ Sci Technol 8:1113–1115.
Neghab M, Qu S, Bai CL, . 1997. Raised concentration of serum bile acids following occupational exposure to halogenated solvents, 1,1,2-trichloro-1,2,2-trifluoroethane and trichloroethylene. Int Arch Occup Environ Health 70(3):187–194.9298401
*Nelson JL, Zenick H. 1986. The effect of trichloroethylene on male sexual behavior: Possible opioid role. Neurobehav Toxicol Teratol 8:441–445.3785506
Nelson MA, Bull RJ. 1988. Induction of strand breaks in DNA by trichloroethylene and metabolites in rat and mouse liver in vivo. Toxicol Appl Pharmacol 94:45–54.3376113
Nelson MJK, Montgomery SO, Mahaffey WR, . 1987. Biodegradation of trichloroethylene and involvement of an aromatic biodegradative pathway. Appl Environ Microbiol 53:949–954.3606099
Nelson MJK, Montgomery SO, Pritchard PH. 1988. Trichloroethylene metabolism by microorganisms that degrade aromatic compounds. Appl Environ Microbiol 54:604–606.3355147
Neta G, Stewart PA, Rajaraman P, . 2012. Occupational exposure to chlorinated solvents and risks of glioma and meningioma in adults. Occup Environ Med 69(11):793–801. 10.1136/oemed-2012-100742.22864249
Nichols WK, Covington MO, Seiders CD, . 1992. Bioactivation of halogenated hydrocarbons by rabbit pulmonary cells. Pharmacol Toxicol 71:335–339.1448445
Nicoara S, Culea M, Palibroda N, . 1994. Volatile organic chemical pollutants in laboratory indoor air. Indoor Environ 3:83–86.
Nietert PJ, Sutherland SE, Silver RM, . 1998. Is occupational organic solvent exposure a risk factor for scleroderma? Arthritis Rheum 41(6):1111–1118.9627022
Niklasson M, Tham R, Larsby B, . 1993. Effects of toluene, styrene, trichloroethylene, and trichloroethane on the vestibulo- and opto-oculo motor system in rats. Neurotoxicol Teratol 15:327–334.8277926
NIOSH. 1990. NOES National Occupational Exposure Survey (1981-1983). Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. December 7, 1990.
NIOSH. 1994a. Method 1022, issue 2. Trichloroethylene. NIOSH manual of analytical methods. National Institute for Occupational Safety and Health. NIOSH Publication Number 2003-154. http://www.cdc.gov/niosh/docs/2003-154/pdfs/1022.pdf. June 2, 2011.
NIOSH. 1994b. Method 3701, issue 2. Trichloroethylene by portable GC. NIOSH manual of analytical methods. National Institute for Occupational Safety and Health. NIOSH Publication Number 2003-154. http://www.cdc.gov/niosh/docs/2003-154/pdfs/3701.pdf. June 2, 2011.
NIOSH. 1994c. Documentation for immediately dangerous to life or health concentrations (IDLHs). National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/idlh/79016.html. November 4, 2011.
NIOSH. 2011. NIOSH pocket guide to chemical hazards-trichloroethylene. Centers for Disease Control and Prevention. http://wwwosha.cdc.gov/niosh/npg/npgd0629.html. May 7, 2013.
NIOSH. 2013. Appendix C-Supplementary exposure limits. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/nengapdxc.html. May 14, 2013.
Noland-Gerbec EA, Pfohl RJ, Taylor DH, . 1986. 2-Deoxyglucose uptake in the developing rat brain upon pre- and postnatal exposure to trichloroethylene. Neurotoxicology 7:157–164.3822256
Nomiyama K. 1971. Estimation of trichloroethylene exposure by biological materials. Int Arch Arbeitsmed 27:281–292.5577540
Nomiyama K, Nomiyama H. 1971. Metabolism of trichloroethylene in humans: Sex difference in urinary excretion of trichloroacetic acid and trichloroethanol. Int Arch Arbeitsmed 28:37–48.5088555
Nomiyama K, Nomiyama H. 1974a. Respiratory elimination of organic solvents in man. Benzene, toluene, n-hexane, trichloroethylene, acetone, ethyl acetate and ethyl alcohol. Int Arch Arbeitsmed 32:85–91.4813697
Nomiyama K, Nomiyama H. 1974b. Respiratory retention, uptake, and excretion of organic solvents in man. Int Arch Arbeitsmed 32:75–83.4813696
Nomiyama K, Nomiyama H. 1977. Dose-response relationship for trichloroethylene in man. Int Arch Occup Environ Health 39:237–248.914369
*Nordström M, Hardell L, Magnuson A, . 1998. Occupational exposures, animal exposure and smoking as risk factors for hairy cell leukaemia evaluated in a case-control study. Br J Cancer 77(11):2048–2052.9667691
*Novotna E, David A, Malek B. 1979. [An epidemiological study of hepatic tumor incidence in subjects working with trichloroethylene. I. Negative result of retrospective investigations in subjects with primary liver cancer.] Prac Lek 31:121–123. (Czech)
NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
NRC. 2006. Assessing the human health risks of trichloroethylene: Key scientific issues. Washington, DC: National Research Council. National Academies Press. http://www.nap.edu/openbook.php?record_id=11707. January 20, 2014.
NRC. 2009. Contaminated water supplies at Camp Lejeune: Assessing potential health effects. Washington, DC: National Research Council, Board on Environmental Studies and Toxicology. 90–183. PB2009115325. http://www.nap.edu/catalog.php?record_id=12618#toc. November 6, 2015.
*NTP. 1983. National Toxicology Program--technical report series no. 232. Carcinogenesis bioassay of pentachloroethane in Fischer-344/N rats and B6C3F1 mice. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health.
NTP. 1985. Final report. Trichloroethylene: Reproduction and fertility assessment in CD-1 mice when administered in the feed. Research Triangle Park, NC: National Toxicology Program, National Institute of Environmental Health Sciences.
NTP. 1986. Final report. Trichloroethylene: Reproduction and fertility assessment in Fischer-344 rats when administered in the feed. Research Triangle Park, NC: National Toxicology Program, National Institute of Environmental Health Sciences. NTP-86-085.
NTP. 1988. National Toxicology Program--technical report series no. 273. Toxicology and carcinogenesis studies of trichloroethylene (CAS No. 79-01-6) in four strains of rats (ACI, August, Marshall, Osborne-Mendel) (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH publication no. 88-2529.
NTP. 1990. National Toxicology Program--technical report series no. 243. Carcinogenesis studies of trichloroethylene (without epichlorohydrinin) (CAS No. 79-01-6) in Fischer-344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services. Public Health Service. National Institutes of Health. NIH publication no. 90-1799.
NTP. 1997. National Toxicology Program. Substances, mixtures and exposure circumstances proposed for listing in or delisting (removing) from the report on carcinogens, Ninth edition. Call for public comments. Fed Regist 62:37272–37273.
*NTP. 2014. Report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. 13^th^ Edition. http://ntp.niehs.nih.gov/ntp/roc/content/profiles/trichloroethylene.pdf. December 12, 2014.
*NTP. 2015. Report on carcinogens monograph on trichloroethylene. National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/monographs/finaltce_508.pdf. October 21, 2015.
NTP. 2016. Trichloroethylene. Report on carcinogens, fourteenth edition. National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service. http://ntp.niehs.nih.gov/go/roc. September 26, 2018.
Nunes J, Ehrich M, Robertson J. 2001. Toxicosis associated with dual oral exposure of rats to lead and trichloroethylene. Toxicol Pathol 29(4):451–457.11560250
NYSDEC. 2003. Vapor sampling summary report table. Vapor and groundwater sampling results. New York State Department of Conservation. http://www.dec.ny.gov/docs/remediation_hudson_pdf/analyticalresults.pdf. May 9, 2013.
Odum J, Foster JR, Green T. 1992. A mechanism for the development of Clara cell lesions in the mouse lung after exposure to trichloroethylene. Chem Biol Interact 83:135–153.1505057
Ogata M, Takatsuka Y, Tomokuni K. 1971. Excretion of organic chlorine compounds in the urine of persons exposed to vapours of trichloroethylene and tetrachloroethylene. Br J Ind Med 28:386.5124840
Ohio River Valley Sanitation Commission. 1980. Assessment of water quality conditions. Ohio River Mainstream 1978-9. Cincinnati, OH: Ohio River Valley Water Sanit Comm 34 T-53.
Ohio River Valley Sanitation Commission. 1982. Assessment of water quality conditions. Ohio River Mainstream 1978-9. Cincinnati, OH: Ohio River Valley Water Sanit Comm. Appendix D: Table 13.
Ojajärvi A, Partanen T, Ahlbom A, . 2001. Risk of pancreatic cancer in workers exposed to chlorinated hydrocarbon solvents and related compounds: A meta-analysis. Am J Epidemiol 153(9):841–850.11323314
*Ojajärvi A, Partanen T, Ahlbom A, . 2007. Estimating the relative risk of pancreatic cancer associated with exposure agents in job title data in a hierarchical Bayesian meta-analysis. Scand J Work Environ Health 33(5):325–335.17973058
Okamoto T, Shiwaku K. 1994. Fatty acid composition in liver, serum, and brain of rat inhalated with trichloroethylene. Exp Toxicol Pathol 46:133–141.7987071
Okino T, Nakajima T, Nakano M. 1991. Morphological and biochemical analyses of trichloroethylene hepatotoxicity: Differences in ethanol- and phenobarbital-pretreated rats. Toxicol Appl Pharmacol 108:379–389.2020965
Okouchi S. 1986. Volatilization coefficient for stripping trichloroethylene, 1,1,1-trichloroethane and tetrachloroethylene from water. Water Sci Technol 18:137–138.
Olaguer EP, Jr. 2002. The distribution of the chlorinated solvents dichloromethane, perchloroethylene, and trichloroethylene in the global atmosphere. Environ Sci Pollut Res Int 9(3):175–182.12094530
Oldenhuis R, Oedzes JY, van der Waarde JJ, . 1991. Kinetics of chlorinated hydrocarbon degradation by Methylosinus trichosporium OB3b and toxicity of trichloroethylene. Appl Environ Microbiol 57:7–14.2036023
Ong CN, Koh D, Foo SC, . 1993. Volatile organic solvents in correction fluids: Identification and potential hazards. Bull Environ Contam Toxicol 50:787–793.8495053
Oppelt ET. 1987. Incineration of hazardous waste. A critical review. J Air Pollut Control Assoc 37:558–586.
*Orsi L, Monnereau A, Dananche B, . 2010. Occupational exposure to organic solvents and lymphoid neoplasms in men: Results of a French case-control study. Occup Environ Med 67(10):664–672. 10.1136/oem.2009.049460.20837648
OSHA. 1993. Air contaminants final rule. Occupational Safety and Health Administration. Fed Regist 58:35338–35351.
OSHA. 2013a. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.119, Appendix A. http://www.osha.gov/law-regs.html. April 24, 2013.
OSHA. 2013b. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000, Table Z-2. http://www.osha.gov/law-regs.html. April 24, 2013.
Otson R, Williams DT. 1982. Headspace chromatographic determination of water pollutants. Anal Chem 54:942–946.
Otson R, Williams DT, Bothwell PD. 1982. Volatile organic compounds in water at thirty Canadian potable water treatment facilities. J Assoc Off Anal Chem 65:1370–1374.
Otsuki N, Homma T, Fujiwara H, . 2016. Trichloroethylene exposure aggravates behavioral abnormalities in mice that are deficient in superoxide dismutase. Regul Toxicol Pharmacol 79:83–90. 10.1016/j.yrtph.2016.05.007.27166294
Ou J, Ou Z, McCarver DG, . 2003. Trichloroethylene decreases heat shock protein 90 interactions with endothelial nitric oxide synthase: Implications for endothelial cell proliferation. Toxicol Sci 73(1):90–97.12657742
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Ozonoff D, Colten ME, Cupples A, . 1987. Health problems reported by residents of a neighborhood contaminated by a hazardous waste facility. Am J Ind Med 11:581–597.3591806
Paddle GM. 1983. Incidence of liver cancer and trichloroethylene manufacture: Joint study by industry and a cancer registry. Br Med J 286:846.6403111
Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15:1475–1481.
Palmer RB, Phillips SD. 2007. Chlorinated hydrocarbons. In: Shannon MW, Borron SW, Burns MJ. Haddad and Winchester’s clinical management of poisoning and drug overdose. 4th ed. Philadelphia, PA: Saunders Elsevier, 1347–1361.
Pantucharoensri S, Boontee P, Likhitsan P, . 2004. Generalized eruption accompanied by hepatitis in two Thai metal cleaners exposed to trichloroethylene. Ind Health 42(3):385–388.15295912
Parchman LG, Magee PN. 1982. Metabolism of ^14^C trichloroethylene to ^14^CO_2_ and interaction of a metabolite with liver DNA in rats and mice. J Toxicol Environ Health 9:797–813.6811765
Park KS, Sorenson DL, Sims J. 1988. Volatilization of wastewater trace organics in slow rate land treatment systems. Hazard Waste Hazard Mat 5:219–229.
Parker GS, Rosen SL. 1981. Cancer incidence and environmental hazards 1969-1978. Massachusetts Department of Public Health.
Parsons F, Barrio-Lage GB, Rice R. 1985. Biotransformation of chlorinated organic solvents in static microcosms. Environ Toxicol Chem 4:739–742.
*Parsons F, Wood PR, Demarco J. 1984. Transformations of tetrachloroethene and trichloroethene in microcosms and groundwater. J Am Water Works Assoc 76:56–59.
*Partanen T, Heikkila P, Hernberg S, . 1991. Renal cell cancer and occupational exposure to chemical agents. Scand J Work Environ Health 17(4):231–239.1925434
Pavlostathis SG, Mathavan GN. 1992. Application of headspace analysis for the determination of volatile organic compounds in contaminated soils. Environ Technol 13:23–33.
Paykoc ZV, Powell JF. 1945. The excretion of sodium trichloroacetate. J Pharmacol Exp Ther 85:289–293.21010735
Pearson CR, McConnell G. 1975. Chlorinated C_1_ and C_2_ hydrocarbons in the marine environment. Proc R Soc Lond [Biol] 189:305–332.238199
Peden-Adams MM, Eudaly JG, Heesemann LM, . 2006. Developmental immunotoxicity of trichloroethylene (TCE): Studies in B6C3F1 mice. J Environ Sci Health A Tox Hazard Subst Environ Eng 41(3):249–271.16484062
Peden-Adams MM, Eudaly JG, Lee AM, . 2008. Lifetime exposure to trichloroethylene (TCE) does not accelerate autoimmune disease in MRL +/+ mice. (Comment and author response in: J Environ Sci Health A 44:116-122). J Environ Sci Health A Tox Hazard Subst Environ Eng 43(12):1402–1409.18780217
*Peers AM. 1985. Method 5: The determination of trichloroethylene and tetrachloroethylene in air. IARC Sci Publ 68:205–211.
Pekari K, Aitio A. 1985a. Method 29: Determination of trichloroacetic acid in urine. IARC Sci Publ 68:467–472.
Pekari K, Aitio A. 1985b. Method 30: Determination of 2,2,2-trichloroethanol in urine. IARC Sci Publ 68:473–478.
Pellizzari ED, Hartwell TD, Harris BS, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28:322–328.7082873
Pembleton WE. 1974. Trichloroethylene anesthesia re-evaluated. Anesth Analg 53:730–733.4472417
Peng J, Bewtra JK, Biswas N. 1994. Volatilization of selected organic compounds from quiescent water. J Environ Eng 120:662–669.
Perbellini L, Olivato D, Zedde A, . 1991. Acute trichloroethylene poisoning by ingestion: Clinical and pharmacological aspects. Intensive Care Med 17:234–235.1744309
Perocco P, Prodi G. 1981. DNA damage by haloalkanes in human lymphocytes cultured in vitro. Cancer Lett 13:213–218.6457684
Persson B, Fredrikson M. 1999. Some risk factors for non-Hodgkin’s lymphoma. Int J Occup Med Environ Health 12(2):135–142.10465904
*Persson B, Dahlander AM, Fredriksson M, . 1989. Malignant lymphomas and occupational exposures. Br J Ind Med 46(8):516–520. http://www.ncbi.nlm.nih.gov/pubmed/2775671.2775671
Pesch B, Haerting J, Ranft U, . 2000. Occupational risk factors for renal cell carcinoma: Agentspecific results from a case-control study in Germany. MURC Study Group. Multicenter urothelial and renal cancer study. Int J Epidemiol 29(6):1014–1024.11101542
*Pessayre D, Cobert B, Decatoire V, . 1982. Hepatotoxicity of trichloroethylene-carbon tetrachloride mixtures in rats. Gastroenterology 83:761–772.7106507
Petersen LW, Rolston DE, Moldrup P, . 1994. Volatile organic vapor diffusion and adsorption in soils. J Environ Qual 23:799–805.
Pfaffenberger CD, Peoples AJ, Enos HF. 1980. Distribution of volatile halogenated organic compounds between rat blood serum and adipose tissue. Int J Environ Anal Chem 8:55–65.7399799
Phoon WH, Chan MOY, Rajan VS, . 1984. Stevens-Johnson syndrome associated with occupational exposure to trichloroethylene. Contact Dermatitis 10:270–276.6734188
*Plaa GL. 1988. Experimental evaluation of haloalkanes and liver injury. Fundam Appl Toxicol 10:563–570.3294072
Poet TS, Corley RA, Thrall KD, . 2000. Assessment of the percutaneous absorption of trichloroethylene in rats and humans using MS/MS real-time breath analysis and physiologically based pharmacokinetic modeling. Toxicol Sci 56(1):61–72.10869454
*Polakowska B, Byczkowska Z. 1991. [Cerebellar syndrome after long-term exposure to organic solvents. Case report]. Med Pr 42:355–359. (Polish)1808444
*Poole C, Dreyer NA, Satterfield MH, . 1993. Kidney cancer and hydrocarbon exposures among petroleum refinery workers. Environ Health Perspect 101(Suppl 6):53–62.
*Popper H, Schaffner F. 1959. Drug induced hepatic injury. Ann Intern Med 51:1230–1252.14434187
*Powell JF. 1945. Trichloroethylene: Absorption, elimination and metabolism. Br J Ind Med 2:142–145.
PPG. 2005. Trichloroethylene. PPG Chlor-alkali & derivatives. Product bulletin. PPG Industries. http://www.ppg.com/chemicals/chloralkali/products/Documents/English/Trichlorethylene.pdf. June 2, 2011.
Pratt GC, Palmer K, Wu CY, . 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825.11017885
Pratt GC, Wu CY, Bock D, . 2004. Comparing air dispersion model predictions with measured concentrations of VOCs in urban communities. Environ Sci Technol 38(7):1949–1959.15112793
Prendergast JA, Jones RA, Jenkins LJ Jr, . 1967. Effects on experimental animals of long-term inhalation of trichloroethylene, carbon tetrachloride, 1,1,1-trichloroethane, dichlorodifluoromethane, and 1,1-dichloroethylene. Toxicol Appl Pharmacol 10:270–289.4962252
Prentice RL. 1986. Comment [Letter]. J Am Stat Assoc 81:600–601.
Price PJ, Hassett CM, Mansfield JI. 1978. Transforming activities of trichloroethylene and proposed industrial alternatives. In Vitro 14:290–293.669729
Priest RJ, Horn RC. 1965. Trichloroethylene intoxication: A case of acute hepatic necrosis possibly due to this agent. Arch Environ Health 11:361–365.14334043
Prout MS, Provan WM, Green T. 1985. Species differences in response to trichloroethylene. I. Pharmacokinetics in rats and mice. Toxicol Appl Pharmacol 79:389–400.4035686
*Pulciani S, Santos E, Lauver AV, . 1982a. Oncogenes in solid human tumours. Nature 300:539–542.7144906
*Pulciani S, Santos E, Lauver AV, . 1982b. Oncogenes in human tumor cell lines. Molecular cloning of a transforming gene from human bladder carcinoma cells. Proc Natl Acad Sci USA 79:2845–2849.6953433
Purdue MP, Bakke B, Stewart P, . 2011. A case-control study of occupational exposure to trichloroethylene and non-Hodgkin lymphoma. Environ Health Perspect 119(2):232–238.21370516
Purdue MP, Stewart PA, Friesen MC, . 2017. Occupational exposure to chlorinated solvents and kidney cancer: A case-control study. Occup Environ Med 74(4):268–274. 10.1136/oemed-2016-103849.27803178
*Raaschou-Nielsen O, Hansen J, Christensen JM, . 2001. Urinary concentrations of trichloroacetic acid in Danish workers exposed to trichloroethylene, 1947-1985. Am J Ind Med 39(3):320–327.11241565
Raaschou-Nielsen O, Hansen J, McLaughlin JK, . 2003. Cancer risk among workers at Danish companies using trichloroethylene: A cohort study. Am J Epidemiol 158(12):1182–1192.14652303
Radican L, Blair A, Stewart P, . 2008. Mortality of aircraft maintenance workers exposed to trichloroethylene and other hydrocarbons and chemicals: Extended follow-up. J Occup Environ Med 50(11):1306–1319.19001957
Radican L, Wartenberg D, Rhoads GG, . 2006. A retrospective occupational cohort study of end-stage renal disease in aircraft workers exposed to trichloroethylene and other hydrocarbons. J Occup Environ Med 48(1):1–12.16404204
Rake J, Visser G, Labrune P, . 2002. Glycogen storage disease type I: Diagnosis, management, clinical course and outcome. Results of the European Study on Glycogen Storage Disease Type I (ESGSD I). Eur J Pediatr 161(1):S20–S34.12373567
Ramdhan DH, Kamijima M, Yamada N, . 2008. Molecular mechanism of trichloroethylene-induced hepatotoxicity mediated by CYP2E1. Toxicol Appl Pharmacol 231(3):300–307.18565563
Ramdhan DH, Kamijima M, Wang D, . 2010. Differential response to trichloroethylene-induced hepatosteatosis in wild-type and PPARα-humanized mice. Environ Health Perspect 118(11):1557–1563.20709644
*Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
Ramsey JD, Flanagan RJ. 1982. Detection and identification of volatile organic compounds in blood by headspace gas chromatography as an aide to the diagnosis of solvent abuse. J Chromatogr 240:423–444.7096519
Rasanen I, Viinamaki J, Vuori E, . 2010. Headspace in-tube extraction gas chromatography-mass spectrometry for the analysis of hydroxylic methyl-derivatized and volatile organic compounds in blood and urine. J Anal Toxicol 34(3):113–121.20406534
Rascu A, Bucur L, Naghi E, . 2003. Systemic dermatitis and obstructive respiratory syndrome following occupational sensitization to trichloroethylene. Rom J Intern Med 41(4):439–446.15526526
Rasmussen K, Arlien-Soborg P, Sabroe S. 1993a. Clinical neurological findings among metal degreasers exposed to chlorinated solvents. Acta Neurol Scand 87:200–204.8475690
Rasmussen K, Brogren CH, Sabroe S. 1993b. Subclinical affection of liver and kidney function and solvent exposure. Int Arch Occup Environ Health 64:445–448.8458661
Rasmussen K, Jeppesen HJ, Sabroe S. 1993c. Psychometric tests for assessment of brain function after solvent exposure. Am J Ind Med 24:553–565.8266931
Rasmussen K, Jeppesen HJ, Sabroe S. 1993d. Solvent-induced chronic toxic encephalopathy. Am J Ind Med 23:779–792.8506855
Rasmussen K, Sabroe S, Wohlert M, . 1988. A genotoxic study of metal workers exposed to trichloroethylene: Sperm parameters and chromosome aberrations in lymphocytes. Int Arch Occup Environ Health 60:419–423.3410552
Rasmussen RA, Harsch DE, Sweany PH, . 1977. Determination of atmospheric halocarbons by a temperature-programmed gas chromatographic freezeout concentration method. J Air Pollut Control Assoc 27:579–581.
Rastkari N, Yunesian M, Ahmadkhaniha R. 2011. Exposure assessment to trichloroethylene and perchloroethylene for workers in the dry cleaning industry. Bull Environ Contam Toxicol 86(4):363–367.21416139
Rathbun RE. 1998. Transport, behavior, and fate of volatile organic compounds in streams. U.S. Geological Survey 1–151.
Ray K, Sahana CC, Chaudhuri SB, . 1993. Effects of trichloroethylene anaesthesia on salivary paracetamol elimination. Indian J Physiol Pharmacol 37(1):79–81.8449552
*Rayburn JR, DeYoung DJ, Bantle JA. 1991. Altered developmental toxicity caused by three carrier solvents. J Appl Toxicol 11:253–260.1939998
Rebert CS, Boyes WK, Pryor GT, . 1993. Combined effects of solvents on the rat’s auditory system: Styrene and trichloroethylene. Int J Psychophysiol 14:49–59.8432679
Rebert CS, Day VL, Matteucci MJ, . 1991. Sensory-evoked potentials in rats chronically exposed to trichloroethylene: Predominant auditory dysfunction. Neurotoxicol Teratol 13:83–90.2046630
Reichert D, Liebaldt G, Henschler D. 1976. Neurotoxic effects of dichloroacetylene. Arch Toxicol 37:23–38.1036906
Reif JS, Burch JB, Nuckols JR, . 2003. Neurobehavioral effects of exposure to trichloroethylene through a municipal water supply. Environ Res 93(3):248–258.14615234
Reimche LD, Sankaran K, Hindmarsh KW, . 1989. Chloral hydrate sedation in neonates and infants-clinical and pharmacological considerations. Dev Pharmacol Ther 12(2):57–64.2714158
Reinhard M, Goodman NL, Barker JF. 1984. Occurrence and distribution of organic chemicals in two landfill leachate plumes. Environ Sci Technol 18:953–961.
Reinhardt CF, Azar A, Maxfield ME, . 1971. Cardiac arrhythmias and aerosol “sniffing.” Arch Environ Health 22:265–279.5099701
Reinhardt CF, Mullen LS, Maxfield ME. 1973. Epinephrine-induced cardiac arrhythmia potential of some common industrial solvents. J Occup Med 15:953–955.4763670
RePORTER. 2018. Trichloroethylene exposure and autoimmune hepatitis. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. September 27, 2018.
Reynolds SD, Malkinson AM. 2010. Clara cell: Progenitor for the bronchiolar epithelium. Int J Biochem Cell Biol 42(1):1–4.19747565
*Reynolds SH, Stowers SJ, Patterson RM, . 1987. Activated oncogenes in B6C3F1 mouse liver tumors: Implications for risk assessment. Science 237:1309–1316.3629242
Ripp SL, Overby LH, Philpot RM, . 1997. Oxidation of cysteine S-conjugates by rabbit liver microsomes and cDNA-expressed flavin-containing mono-oxygenases: Studies with S-(1,2-dichlorovinyl)-L-cysteine, S-(1,2,2-trichlorovinyl)-L-cysteine, S-allyl-L-cysteine, and S-benzyl-L-cysteine. Mol Pharmacol 51(3):507–515.9058607
Ritz B. 1999. Cancer mortality among workers exposed to chemicals during uranium processing. J Occup Environ Med 41(7):556–566.10412097
Robbiano L, Baroni D, Carrozzino R, . 2004. DNA damage and micronuclei induced in rat and human kidney cells by six chemicals carcinogenic to the rat kidney. Toxicology 204(2–3):187–195.15388244
Robbiano L, Mereto E, Migliazzi Morando A, . 1998. Increased frequency of micronucleated kidney cells in rats exposed to halogenated anaesthetics. Mutat Res 413(1):1–6.9602852
Roberts PV, Dandliker PG. 1983. Mass transfer of volatile organic contaminants from aqueous solution to the atmosphere during surface aeration. Environ Sci Technol 17:484–489.22283168
*Rodenbeck SE. 1997. An evaluation of the relationship between maternal exposure to trichloroethylene in drinking water and birth weight at the Tucson International Airport area national priorities list site, Pima County, Arizona. Dissertation, Tulane University.
Rodenbeck SE, Sanderson LM, Rene A. 2000. Maternal exposure to trichloroethylene in drinking water and birth-weight outcomes. Arch Environ Health 55(3):188–194.10908102
Rodriguez CE, Mahle DA, Gearhart JM, . 2007. Predicting age-appropriate pharmacokinetics of six volatile organic compounds in the rat utilizing physiologically based pharmacokinetic modeling. Toxicol Sci 98(1):43–56.17426107
*Rogan WJ. 1986. Comment [Letter]. J Am Stat Assoc 81:602–603.
Rosa C. 2003. Exposure to trichloroethylene in an insignia manufacturing facility. Appl Occup Environ Hyg 18(9):646–648.12909531
Rossberg M, Lendle W, Pfleiderer G, . 2006. Chlorinated hydrocarbons. http://onlinelibrary.wiley.com/doi/10.1002/14356007.a06_223.pub2/pdf. January 26, 2011.
Rossi AM, Migliore L, Barali R, . 1983. In vivo and in vitro mutagenicity studies of a possible carcinogen, trichloroethylene, and its two stabilizers, epichlorohydrin and 1,2-epoxybutane. Teratog Carcinog Mutagen 3:75–87.6132459
*Rott B, Viswanathan R, Freitage D, . 1982. Comparison of the applicability of various tests for screening the degradability of environmental chemicals. Chemosphere 11:1–10.
Rowe BL, Toccalino PL, Moran MJ, . 2007. Occurrence and potential human-health relevance of volatile organic compounds in drinking water from domestic wells in the United States. Environ Health Perspect 115(11):1539–1546.18007981
Ruckart P, Bove F, Maslia M. 2013. Evaluation of exposure to contaminated drinking water and specific birth defects and childhood cancers at Marine Corps Base Camp Lejeune, North Carolina: A case-control study. Environ Health 12(1):104. 10.1186/1476-069X-12-104.24304547
*Rubinstein HS, Painter E, Harne OG. 1939. Neural depressing effect of trichloroethylene. J Lab Clin Med 1238–1241.
Ruckart PZ, Bove FJ, Shanley E, 3rd, . 2015. Evaluation of contaminated drinking water and male breast cancer at Marine Corps Base Camp Lejeune, North Carolina: A case control study. Environ Health 14:74. 10.1186/s12940-015-0061-4 26376727
Ruder AM, Yiin JH, Waters MA, . 2013. The Upper Midwest Health Study: Gliomas and occupational exposure to chlorinated solvents. Occup Environ Med 70(2):73–80. 10.1136/oemed-2011-100588.23104734
Ruijten MW, Verberk MM, Salle HJ. 1991. Nerve function in workers with long term exposure to trichloroethene. Br J Ind Med 48:87–92.1998613
Rusyn I, Chiu WA, Lash LH, . 2014. Trichloroethylene: Mechanistic, epidemiologic and other supporting evidence of carcinogenic hazard. Pharmacol Ther 141(1):55–68. 10.1016/j.pharmthera.2013.08.004.23973663
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manag Res 2:119–130.
Saberi Hosnijeh F, Christopher Y, Peeters P, . 2013. Occupation and risk of lymphoid and myeloid leukaemia in the European Prospective Investigation into Cancer and Nutrition (EPIC). Occup Environ Med 70(7):464–470. 10.1136/oemed-2012-101135.23576671
Saghir SA, Schultz IR. 2002. Low-dose pharmacokinetics and oral bioavailability of dichloroacetate in naive and GST-zeta-depleted rats. Environ Health Perspect 110(8):757–763.
Sahoo D, Smith JA. 1997. Enhanced trichloroethene desorption from long-term contaminated soil using Triton X-100 and pH increases. Environ Sci Technol 31(7):1910–1915.
Saihan EM, Burton JL, Heaton KW. 1978. A new syndrome with pigmentation, scleroderma, gynaecomastia, Raynaud’s phenomenon and peripheral neuropathy. Br J Dermatol 99(4):437–440.213095
Saisho K, Hasegawa Y, Saeki M, . 1994. Bioaccumulation of volatile chlorinated hydrocarbons in blue mussel, Mytilus edulis, and killifish, Oryzias latipes. Eisei Kagaku 40:274–278. (Japanese)
Sallmén M, Lindbohm ML, Anttila A, . 1998. Time to pregnancy among the wives of men exposed to organic solvents. Occup Environ Med 55(1):24–30.9536159
Sallmén M, Lindbohm ML, Kyyronen P, . 1995. Reduced fertility among women exposed to organic solvents. Am J Ind Med 27(5):699–713.7611306
Salvini M, Binaschi S, Riva M. 1971. Evaluation of the psychophysiological functions in humans exposed to trichloroethylene. Br J Ind Med 28:293–295.5557850
Sanders VM, Tucker AN, White KL Jr, . 1982. Humoral and cell-mediated immune status in mice exposed to trichloroethylene in drinking water. Toxicol Appl Pharmacol 62:358–368.7071855
Sapkota A, Williams D, Buckley TJ. 2005. Tollbooth workers and mobile source-related hazardous air pollutants: How protective is the indoor environment? Environ Sci Technol 39(9):2936–2943.15926536
Sato A. 1993. Confounding factors in biological monitoring of exposure to organic solvents. Int Arch Occup Environ Health 65:S61–S67.8406940
Sato A, Nakajima T. 1978. Differences following skin or inhalation exposure in the absorption and excretion kinetics of trichloroethylene and toluene. Br J Ind Med 35:43–49.629888
Sato A, Nakajima T. 1987. Pharmacokinetics of organic solvent vapors in relation to their toxicity. Scand J Work Environ Health 13:81–93.3299685
Sato A, Endoh K, Kaneko T, . 1991. A simulation study of physiological factors affecting pharmacokinetic behavior of organic solvent vapours. Br J Ind Med 48:342–347.2039747
Sato A, Nakajima T, Fujiwara Y, . 1977. A pharmacokinetic model to study the excretion of trichloroethylene and its metabolites after an inhalation exposure. Br J Ind Med 34:56–63.843464
Sato A, Nakajima T, Koyama Y. 1981. Dose-related effects of a single dose of ethanol on the metabolism in rat liver of some aromatic and chlorinated hydrocarbons. Toxicol Appl Pharmacol 60:8–15.7281179
*Sato A, Yamaguchi K, Nakajima T. 1986. Occupational trichloroethylene exposure as an etiological factor of Pneumatosis cystoides intestinalis. Toxicol Lett 81(Suppl):16–17.
Sauer TC. 1981. Volatile organic compounds in open ocean and coastal surface waters. Organic Geochem 3:91–101.
Saunders RA. 1967. A new hazard on closed environmental atmospheres. Arch Environ Health 14:380–384.4951670
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286. 10.1016/j.tins.2008.03.003.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3(10.3389/fphar.2012.00046):Article 46. 10.3389/fphar.2012.00046.
Savolainen H, Pfaffli P, Tengen M, . 1977. Trichloroethylene and 1,1,1- trichloroethane: Effects on brain and liver after five days intermittent inhalation. Arch Toxicol 38:229–237.578726
Saygun M, Cakmak A, Ekici A, . 2007. Five annual observations of respiratory findings in gun factory workers exposed to solvents. J Occup Environ Med 49(8):909–912.17693789
Schattner A, Malnick SDH. 1990. Anicteric hepatitis and uveitis in a worker exposed to trichloroethylene. Postgrad Med J 66:730–731.2235804
*Schaumburg FD. 1990. Banning trichloroethylene: Responsible reaction or overkill? Environ Sci Technol 24:17–22.
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
*Schlehofer B, Heuer C, Blettner M, . 1995. Occupation, smoking and demographic factors, and renal cell carcinoma in Germany. Int J Epidemiol 24(1):51–57.7797356
Schroll R, Bierling B, Cao G, . 1994. Uptake pathways of organic chemicals from soil by agricultural plants. Chemosphere 28:297–303.
Schultz I, Merdink J, Gonzalez-Leon A, . 2002. Dichloroacetate toxicokinetics and disruption of tyrosine catabolism in B6C3F1 mice: Dose-response relationships and age as a modifying factor. Toxicology 173(3):229–247.11960676
Schultz MG, Sapp JH, 2nd, Cusack CD, . 2010. The National Exposure Registry: History and lessons learned. J Environ Health 72(7):20–25.20235405
Schultz B, Kjeldsen P. 1986. Screening of organic matter in leachates from sanitary landfills using gas chromatography combined with mass spectrometry. Water Res 20:967–970.
Schuttmann W. 1970. [Liver damage after occupational exposure to trichloroethylene.] Dtsch Z Verdau Stoffwechselkr 30:43–45. (German)5501426
Schwarzenbach RP, Giger W, Hoehn E, . 1983. Behavior of organic compounds during infiltration of river water to ground water. Field studies. Environ Sci Technol 17:472–479.22283166
Schwetz BA, Leong KJ, Gehring PJ. 1975. The effect of maternally inhaled trichloroethylene, perchloroethylene, methylchloroform, and methylene chloride on embryonal and fetal development in mice and rats. Toxicol Appl Pharmacol 32:84–96.1135881
Scott CS, Jinot J. 2011. Trichloroethylene and cancer: Systematic and quantitative review of epidemiologic evidence for identifying hazards. Int J Environ Res Public Health 8(11):4238–4272.22163205
*Seage AJ, Burns MW. 1971. Pulmonary edema following exposure to trichloroethylene. Med J Aust 2:484–486.5096198
Secchi GC, Chiappino G, Lotto A, . 1968. [Actual chemical composition of commercial trilenes and their hepatotoxic effects: Clinical and enzymological study.] Med Lav 59(8–9):486–497. (Italian)4318125
*Seidler A, Mohner M, Berger J, . 2007. Solvent exposure and malignant lymphoma: A population-based case-control study in Germany. J Occup Med Toxicol 2:2 17407545
*Seiji K, Inoue O, Jin C, . 1989. Dose-excretion relationship in tetrachloroethylene-exposed workers and the effect of tetrachloroethylene co-exposure on trichloroethylene metabolism. Am J Ind Med 16:675–684.2596489
Seiji K, Jin C, Watanabe T, . 1990. Sister chromatid exchanges in peripheral lymphocytes of workers exposed to benzene, trichloroethylene, or tetrachloroethylene, with references to smoking habits. Int Arch Occup Environ Health 62:171–176.2323835
*Seip HM, Alstad J, Carlberg GE, . 1986. Measurement of mobility of organic compounds in soils. Sci Total Environ 50:87–101.
*Selden A, Ahlborg G. 1991. Mortality and cancer morbidity after exposure to military aircraft fuel. Aviat Space Environ Med 62(8):789–794.1930063
Selden A, Hultberg B, Ulander A, . 1993. Trichloroethylene exposure in vapour degreasing and the urinary excretion of N-acetyl-β-D-glucosaminidase. Arch Toxicol 67:224–226.8494503
*Seo M, Ikeda K, Okamura T, . 2008a. Enhancing effect of chlorinated organic solvents on histamine release and inflammatory mediator production. Toxicology 243(1–2):75–83.18006135
Seo M, Kobayashi R, Nagase H. 2011. Immunotoxic effects of trichloroethylene and tetrachloroethylene. J Health Sci 57(6):488–496.
Seo M, Kobayashi R, Okamura T, . 2012. Enhancing effects of trichloroethylene and tetrachloroethylene on type I allergic responses in mice. J Toxicol Sci 37(2):439–445.22467035
Seo M, Yamagiwa T, Kobayashi R, . 2008b. Augmentation of antigen-stimulated allergic responses by a small amount of trichloroethylene ingestion from drinking water. Regul Toxicol Pharmacol 52(2):140–146.18721841
Sexton K, Adgate JL, Church TR, . 2005. Children’s exposure to volatile organic compounds as determined by longitudinal measurements in blood. Environ Health Perspect 113(3):342–349.15743726
Sexton K, Adgate JL, Fredrickson AL, . 2006. Using biologic markers in blood to assess exposure to multiple environmental chemicals for inner-city children 3-6 years of age. Environ Health Perspect 114(3):453–459.16507471
Shimada T, Swanson AF, Leber P, . 1985. Activities of chlorinated ethane and ethylene compounds in the Salmonella microsome mutagenesis and rat hepatocyte/DNA repair assays under vapor phase exposure conditions. Cell Biol Toxicol 1:159–179.3917197
*Shindell S, Ulrich S. 1985. A cohort study of employees of a manufacturing plant using trichloroethylene. J Occup Med 27:577–579.4032094
*Shipman AJ, Whim BP. 1980. Occupational exposure to trichloroethylene in metal cleaning processes and to tetrachloroethylene in the drycleaning industry in the U K. Ann Occup Hyg 23:197–204.7436231
Shu XO, Stewart P, Wen WQ, . 1999. Parental occupational exposure to hydrocarbons and risk of acute lymphocytic leukemia in offspring. Cancer Epidemiol Biomarkers Prev 8:783–791.10498397
Shusterman D. 2018. Trichloroethane, trichloroethylene and tetrachloroethylene. In: Olson R, Olson IB, Anderson NL, ., eds. Poisoning and drug overdose: Section II: Specific poisons and drugs: Diagnosis and treatment. Seventh ed. New York, NY: McGraw-Hill.
*Sidorin GI, Suvorov IM, Lukovnikova LV, . 1992. [On the pathogenesis of trichloroethylene poisoning.] Gig Tr Prof Zabol 2:32–34. (Russian)
Siegel J, Jones RA, Coon RA, . 1971. Effects on experimental animals of acute, repeated, and continuous inhalation exposures to dichloroacetylene mixtures. Toxicol Appl Pharmacol 18:168–174.5542822
*Siemiatycki J. 1991. Risk factors for cancer in the workplace. Boca Raton, FL: CRC Press, 46–49, 142–145.
*Siemiatycki J, Dewar R, Nadon L, . 1994. Occupational risk factors for bladder cancer: Results from a case-control study in Montreal, Quebec, Canada. Am J Epidemiol 140(12):1061–1080.7998589
Silver SR, Pinkerton LE, Fleming DA, . 2014. Retrospective cohort study of a microelectronics and business machine facility. Am J Ind Med 57(4):412–424. 10.1002/ajim.22288.24375784
Silverman AP, Williams H. 1975. Behaviour of rats exposed to trichloroethylene vapours. Br J Ind Med 32:308–315.1238103
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. In: Scott BB, ed. Progress in Genetic Toxicology. Vol. 2. New York, NY: Elsevier/North Holland Press, 249–258.
Simmons JE, Boyes WK, Bushnell PJ, . 2002. A physiologically based pharmacokinetic model for trichloroethylene in the male Long-Evans rat. Toxicol Sci 69(1):3–15.12215655
Singh HB, Salas LJ, Smith AJ, . 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612.
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16:872–880.22236265
Singthong S, Pakkong P, Choosang K, . 2015. Occupational health risks among trichloroethylene-exposed workers in a clock manufacturing factory. Glob J Health Sci 7(1):161–172. 10.5539/gjhs.v7n1p161.25946943
*Sinks T, Lushniak B, Haussler BJ, . 1992. Renal cell cancer among paperboard printing workers. Epidemiology 3(6):483–489.1420513
Sittig M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. Park Ridge, NJ: Noyes Publications, 843–845.
Sjoberg B. 1952. Thermal decomposition of chlorinated hydrocarbons. Sven Kem Tidskr 64:63–79.
Sjogren B, Plato N, Alexandersson R, . 1991. Pulmonary reactions caused by welding-induced decomposed trichloroethylene. Chest 99:237–238.1984962
Skender L, Karacic V, Bosner B, . 1993. Assessment of exposure to trichloroethylene and tetrachloroethylene in the population of Zagreb, Croatia. Int Arch Occup Environ Health 65:S163–S165.8406918
Skender L, Karacic V, Bosner B, . 1994. Assessment of urban population exposure to trichloroethylene and tetrachloroethylene by means of biological monitoring. Arch Environ Health 49:445–451.7818286
Skender LJ, Karacic V, Prpic-Majic D. 1991. A comparative study of human levels of trichloroethylene and tetrachloroethylene after occupational exposure. Arch Environ Health 46:174–178.2039273
Slacik-Erben R, Roll R, Franke G, . 1980. Trichloroethylene vapors do not produce dominant lethal mutations in male mice. Arch Toxicol 45:37–44.6893145
Smith GF. 1966. Trichloroethylene: A review. Br J Ind Med 23:249–262.5332897
Smith GF. 1970. The investigation of the mental effects of trichloroethylene. Ergonomics 13(5):580–586.5494866
Smith LR, Dragun J. 1984. Degradation of volatile chlorinated aliphatic priority pollutants in groundwater. Environ Int 10:291–298.
*Smith JH, Bomberger DC Jr, Haynes DL. 1980. Prediction of the volatilization rates of high-volatility chemicals from natural water bodies. Environ Sci Tech 14:1332–1337.
*Smith MK, Randall J, Read EJ, . 1989. Teratogenic activity of trichloroacetic acid in the rat. Teratology 40:445–451.2623633
Smyth HF, Carpenter CP, Weil CS, . 1969. Range-finding toxicity data. List VII. Am Ind Hyg Assoc J 30:470–476.5823428
Snedecor G, Hickman JC, Mertens JA. 2004. Chloroethylenes and chloroethanes. In: Kirk Othmer encyclopedia of chemical technology. Vol. 6. John Wiley & Sons, Inc., 253–278.
Snodgrass WR. 1992. Physiological and biochemical differences between children and adults as determinants of toxic response to environmental pollutants. In: Guzelian PS, Henry CJ, Olin SS, eds. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC. International Life Sciences Institute, 35–42.
*Sorgo G. 1976. [Trichloroethylene, carbon tetrachloride, and gasoline intoxication as etiological factors in the development of arterio- and coronary sclerosis.] Arch Toxicol 35:295–318. (German)989298
Soucek B, Vlachova D. 1960. Excretion of trichloroethylene metabolites in human urine. Br J Ind Med 17:60–64.13832993
*Spirtas R, Stewart PA, Lee JS, . 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility: I. Epidemiological results. Br J Ind Med 515–530.1878308
Squillace PJ, Moran MJ. 2007. Factors associated with sources, transport, and fate of volatile organic compounds and their mixtures in aquifers of the United States. Environ Sci Technol 41(7):2123–2130.17438752
SRI. 2011. 2011 Directory of chemical producers. Menlo Park, CA: HIS Global, Inc., 901.
Stackelberg PE, Kauffman LJ, Ayers MA, . 2001. Frequently co-occurring pesticides and volatile organic compounds in public supply and monitoring wells, southern New Jersey, USA. Environ Toxicol Chem 20(4):853–865.11345463
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*Starek A. 1991. [The effect of trichloroethylene on the metabolism and toxicity of benzene in rats.] Folia Medica Cracoviensia 32:169–184. (Polish)1845315
*Stauffer TB, MacIntyre WG. 1986. Sorption of low-polarity organic compounds on oxide minerals and aquifer material. Environ Toxicol Chem 5:949–955.
Steinberg W. 1981. Residual neuropsychological effects following exposure to trichloroethylene (TCE): A case study. Clin Neuropsychol 3:1–4.
*Steinberg AD, DeSesso JM. 1993. Have animal data been used inappropriately to estimate risks to humans from environmental trichloroethylene? Regul Toxicol Pharmacol 18:137–153.8278637
Stenner RD, Merdink JL, Stevens DK, . 1997. Enterohepatic recirculation of trichloroethanol glucuronide as a significant source of trichloroacetic acid. Metabolites of trichloroethylene. Drug Metab Dispos 25(5):529–535.9152590
Stephens JA. 1945. Poisoning by accidental drinking of trichloroethylene. Br Med J 2:218–219.
*Steup DR, Hall P, McMillan DA, . 1993. Time course of hepatic injury and recovery following coadministration of carbon tetrachloride and trichloroethylene in Fischer-344 rats. Toxicol Pathol 21:327–334.8248722
Steup DR, Wiersma D, McMillan DA, . 1991. Pretreatment with drinking water solutions containing trichloroethylene or chloroform enhances the hepatotoxicity of carbon tetrachloride in Fischer 344 rats. Fund Appl Toxicol 16:798–809.
Stevens DK, Eyre RJ, Bull RJ. 1992. Adduction of hemoglobin and albumin in vivo by metabolites of trichloroethylene, trichloroacetate, and dichloroacetate in rats and mice. Fundam Appl Toxicol 19:336–342.1459365
Stewart RD, Dodd HC. 1964. Absorption of carbon tetrachloride, trichloroethylene, tetrachloroethylene, methylene chloride, and 1,1,1-trichloroethane through the human skin. Am Ind Hyg Assoc J 25:439–446.14209666
*Stewart BW, LeMesurier SM, Lykke AW. 1979. Correlation of biochemical and morphological changes induced by chemical injury to the lung. Chem Biol Interact 26:321–338.509695
Stewart RD, Dodd HC, Gay HH, . 1970. Experimental human exposure to trichloroethylene. Arch Environ Health 20:64–71.5409662
Stewart RD, Hake CL, Le Brun AI, . 1974a. Effects of trichloroethylene on behavioral performance capabilities. In: Behavioral toxicology. Early detection of occupational hazards. HEW Publication no. (NIOSH) 74-126. Cincinnati, OH: U.S. Department of Health, Education and Welfare. Public Health Service. Center for Disease Control. National Institute for Occupational Safety and Health, 96–129.
*Stewart RD, Hake CL, Peterson JE. 1974b. Use of breath analysis to monitor trichloroethylene exposures. Arch Environ Health 29:6–13.4843023
Stewart RD, Hake CL, Peterson JE. 1974c. “Degreasers’ flush”: Dermal response to trichloroethylene and ethanol. Arch Environ Health 29:1–5.4276444
*Stopps GJ, McMaughlin M. 1967. Psychophysiological testing of human subjects exposed to solvent vapors. Am Ind Hyg Assoc J 28:43–50.6032934
*Story DL, Meierhenry EF, Tyson CA, . 1986. Differences in rat liver enzyme-altered foci produced by chlorinated aliphatics and phenobarbital. Toxicol Ind Health 2:351–362.3296316
*Stott WT. 1988. Chemically induced proliferation of peroxisomes: Implications for risk assessment. Regul Toxicol Pharmacol 8:9–35.
Stott WT, Quast JF, Watanabe PG. 1982. Pharmacokinetics and macromolecular interactions of trichloroethylene in mice and rats. Toxicol Appl Pharmacol 62:137–151.7064149
Strachan WMJ, Edwards CJ. 1984. Organic pollutants in Lake Ontario. In: Nriagu JO, Simmons MS, eds. Toxic contaminants in the Great Lakes. New York, NY: John Wiley and Sons, 239–264.
*Stutz DR, Janusz SJ. 1988. Protocol 50. Hazardous materials injuries—A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 300–301.
Su C, Goldberg ED. 1976. Environmental concentration and fluxes of some halocarbons. In: Windom HL, Duce RA, eds. Lexington, MA: Marine Pollutant Transfer, 353–374.
Su YH, Liu T, Liang YC. 2010. Transport via xylem of trichloroethylene in wheat, corn, and tomato seedlings. J Hazard Mater 182(1–3):472–476.20619535
*Suflita JM, Gibson SA, Beeman RE. 1988. Anaerobic biotransformations of pollutant chemicals in aquifers. J Ind Microbiol 3:179–194.
Sujatha TV, Hegde MJ. 1998. C-mitotic effects of trichloroethylene (TCE) on bone marrow cells of mice. Mutat Res 413(2):151–158.9639695
Sullivan DA, Jones AD, Williams JG. 1985. Results of the U.S. Environmental Protection Agency’s Air Toxics Analysis in Philadelphia. In: Proceedings of the 78th Annual Meeting of the Air Pollution Control Association. Vol. 2, 1–15.
*Sung TI, Chen PC, Jyuhn-Hsiarn Lee L, . 2007. Increased standardized incidence ratio of breast cancer in female electronics workers. BMC Public Health 7:102. 10.1186/1471-2458-7-102.17559641
*Swan SH, Robins JM. 1986. Comment [Letter]. J Am Stat Assoc 81:604–609.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tabrez S, Ahmad M. 2009. Some enzymatic/nonenzymatic antioxidants as potential stress biomarkers of trichloroethylene, heavy metal mixture, and ethyl alcohol in rat tissues. Environ Toxicol 26(2):207–216.
Takaki A, Suzuki H, Iwasaki Y, . 2008. A 27-year-old man who died of acute liver failure probably due to trichloroethylene abuse. J Gastroenterol 43(3):239–242.18373167
Talbot EO, Marshall LP, Rager JR, . 2015. Air toxics and the risk of autism spectrum disorder: The results of a population based case-control study in southwestern Pennsylvania. Environ Health 14:80. 10.1186/s12940-015-0064-1.26444407
Tang XJ, Li LY, Huang JX, . 2002. Guinea pig maximization test for trichloroethylene and its metabolites. Biomed Environ Sci 15(2):113–118.12244752
Tang X, Que B, Song X, . 2008. Characterization of liver injury associated with hypersensitive skin reactions induced by trichloroethylene in the guinea pig maximization test. J Occup Health 50(2):114–121.18403861
Tao L, Yang S, Xie M, . 2000. Effect of trichloroethylene and its metabolites, dichloroacetic acid and trichloroacetic acid, on the methylation and expression of c-Jun and c-Myc protooncogenes in mouse liver: Prevention by methionine. Toxicol Sci 54(2):399–407.10774822
Taskinen H, Anttila A, Lindbohm ML, . 1989. Spontaneous abortions and congenital malformations among the wives of men occupationally exposed to organic solvents. Scand J Work Environ Health 15(5):345–352.2799322
Taskinen H, Kyyronen P, Hemminki K, . 1994. Laboratory work and pregnancy outcome. J Occup Med 36(3):311–319.8195901
Taylor DH, Lagory KE, Zaccaro DJ, . 1985. Effect of trichloroethylene on the exploratory and locomotor activity of rats exposed during development. Sci Total Environ 47:415–420.4089608
Templin MV, Parker JC, Bull RJ. 1993. Relative formation of dichloroacetate and trichloroacetate from trichloroethylene in male B6C3F1 mice. Toxicol Appl Pharmacol 123:1–8.8236248
Templin MV, Stevens DK, Stenner RD, . 1995. Factors affecting species differences in the kinetics of metabolites of trichloroethylene. J Toxicol Environ Health 44:435–447.7723076
Tewari YB, Miller MM, Wasik SP, . 1982. Aqueous solubility and octanol/water partition coefficient of organic compounds at 25.0°C. J Chem Eng Data 27:451–454.
Thiele DL, Eigenbrodt EH, Ware AJ. 1982. Cirrhosis after repeated trichloroethylene and 1,1,1-trichloroethane exposure. Gastroenterology 83(4):926–929.7106523
Thierstein ST, Hanigan JJ, Faaul MD, . 1960. Trichloroethylene anesthesia in obstetrics: Report of 10,000 cases, with fetal mortality and electrocardiographic data. Obstet Gynecol 15:560–565.13837833
Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York: McGraw Hill Book Co., Chapter 15.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thorburn TG, Paterson P, Doward WA, . 2004. A fatal chemical burn associated with the industrial use of trichloroethylene vapour. Burns 30(4):405–406.15145204
Thrall KD, Poet TS. 2000. Determination of biokinetic interactions in chemical mixtures using real-time breath analysis and physiologically based pharmacokinetic modeling. J Toxicol Environ Health A 59(8):653–670.10839498
*Tikkanen J, Heinonen OP. 1991. Risk factors for ventricular septal defect in Finland. Public Health 105:99–112.2068244
Todd J. 1954. Trichloroethylene poisoning with paranoid psychosis and Lilliputian hallucination. Br Med J 1:439–440.13126536
Tola S, Vilhunen R, Jarvinen E, . 1980. A cohort study on workers exposed to trichloroethylene. J Occup Med 22:737–740.7441393
*Tolot F, Viallier J, Roullett A, . 1964. [Hepatic toxicity of trichloroethylene.] Arch Mal Prof 25:9–15. (French)14138904
Tong Z, Board PG, Anders MW. 1998. Glutathione transferase zeta catalyses the oxygenation of the carcinogen dichloroacetic acid to glyoxylic acid. The Biochemical journal 331 (Pt 2):371–374.9531472
Toraason M, Clark J, Dankovic D, . 1999. Oxidative stress and DNA damage in Fischer rats following acute exposure to trichloroethylene or perchloroethylene. Toxicology 138(1):43–53.10566590
TRI17. 2018. Trichloroethylene. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 26, 2018.
Triebig G, Essing HG, Schaller KH, . 1976. [Biochemical and psychological examinations of trichloroethylene exposed volunteers (author’s transl)]. Zbl Bakt Hyg I Abt Orig B 163(5–6):383–416.
Triebig G, Learl S, Kimmel W, . 1977. Psychopathometric results of follow-up studies on individuals exposed to trichloroethylene. Zbl Bakt Hyg I Abt Orig 164:314–327.
Triebig G, Reichenbach TH, Flugel KA. 1978. [Biochemical examinations and measurements of the conduction velocity in persons chronically exposed to trichloroethylene.] Int Arch Occup Environ Health 42:31–40. (German)711348
Troster AI, Ruff RM. 1990. Neuropsychological sequelae of exposure to the chlorinated hydrocarbon solvents trichloroethylene and trichloroethane. Arch Clinal Neuropsychol 5(1):31–47.
Troutman WG. 1988. Additional deaths associated with the intentional inhalation of typewriter correction fluid. Vet Hum Toxicol 30:130–132.3381485
Tse SYH, Mak IT, Weglicki WB, . 1990. Chlorinated aliphatic hydrocarbons promote lipid peroxidation in vascular cells. J Toxicol Environ Health 31:217–226.2231779
Tsuruta H. 1978. Percutaneous absorption of trichloroethylene in mice. Ind Health 16:145–148.
Tu AS, Murray TA, Hatch KM, . 1985. In vitro transformation of BALB/C-3T3 cells by chlorinated ethanes and ethylenes. Cancer Lett 28:85–92.4027960
Tucker AN, Sanders VM, Barnes DW, . 1982. Toxicology of trichloroethylene in the mouse. Toxicol Appl Pharmacol 62:351–357.7071854
Uehleke H, Poplawski-Tabarelli S, Bonse G, . 1977. Spectral evidence for 2,2,3-trichloro-oxirane formation during microsomal trichloroethylene oxidation. Arch Toxicol 37:95–105.18130
Ulander A, Selden A, Ahlborg G. 1992. Assessment of intermittent trichloroethylene exposure in vapor degreasing. Am Ind Hyg Assoc J 53:742–743.1442565
Umezu T, Yonemoto J, Soma Y, . 1997. Behavioral effects of trichloroethylene and tetrachloroethylene in mice. Pharmacol Biochem Behav 58(3):665–671.9329056
Urano K, Murata C. 1985. Adsorption of principal chlorinated organic compounds on soil. Chemosphere 14:293–299.
USGS. 1987. Purgeable organic compounds, total recoverable, gas chromatographic/mass spectrometric, purge and trap (O-3115-83) Techniques of Water-Resources Investigations of the United States Geological Survey. Chapter A3. Methods for the determination of organic substances in water and fluvial sediments. United States Geological Survey. 67–71. http://pubs.usgs.gov/twri/twri5a3/pdf/twri_5-A3.pdf. June 2, 2011.
USGS. 1998. Organic compounds and parameter codes: Volatile organic compounds, whole water, gas chromatography/mass spectrometry, purge and trap, O-4127-96. Methods of Analysis by the U.S. Geological Survey National Water Quality Laboratory. Determination of 86 volatile organic compounds in water by gas chromatography/mass spectrometry, including detections less than reporting limits. Denver, CO: U.S. Geological Survey Open-File Report 97–829. http://nwql.usgs.gov/pubs/OFR/OFR-97-829.pdf June 2, 2011.
USGS. 2003. Quality and sources of shallow ground water in areas of recent residential development in Salt Lake Valley, Salt Lake County, Utah. U.S. Geological Survey, U.S. Department of the Interior. http://pubs.usgs.gov/wri/wri034028/PDF/WRI034028.pdf. February 3, 2011.
USGS. 2006. Volatile organic compounds in the Nation’s ground water and drinking-water supply wells. U.S. Geological Survey, U.S. Department of the Interior. http://pubs.usgs.gov/circ/circ1292/pdf/circular1292.pdf. February 3, 2011.
USGS. 2012. Assessment of soil-gas contamination at three former fuel-dispensing sites, Fort Gordon, Georgia, 2010-2011. U.S. Geological Survey, U.S. Department of the Interior. http://pubs.usgs.gov/of/2012/1082/pdf/2012-1082.pdf. February 3, 2011.
Utesch RC, Weir FW, Bruckner JV. 1981. Development of an animal model of solvent abuse for use in evaluation of extreme trichloroethylene inhalation. Toxicology 19:169–182.7196605
Vaidya VS, Ozer JS, Dieterle F, . 2010. Kidney injury molecule-1 outperforms traditional biomarkers of kidney injury in preclinical biomarker qualification studies. Nat Biotechnol 28(5):478–485.20458318
*Vamvakas S, Dekant W, Berthold K, . 1987. Enzymatic transformation of mercapturic acids derived from halogenated alkenes to reactive and mutagenic intermediates. Biochem Pharmacol 36:2741–3748.3307787
*Van Duuren BL. 1989. IARC carcinogenicity evaluations of vinylidine chloride, methylene dichloride and trichloroethylene. Environ Res 49:333–334.2753012
Van Duuren BL, Goldschmidt BM, Loewengart G, . 1979. Carcinogenicity of halogenated olefinic and aliphatic hydrocarbons in mice. J Natl Cancer Inst 63:1433–1439.292813
Varshney M, Chandra A, Jain R, . 2015. Occupational health hazards of trichloroethylene among workers in relation to altered mRNA expression of cell cycle regulating genes (p53, p21, bax and bcl-2) and PPARA. Toxicol Rep 2:748–757. 10.1016/j.toxrep.2015.04.002.28962410
Vartiainen T, Pukkala E, Rienoja T, . 1993. Population exposure to tri- and tetrachloroethylene and cancer risk: Two cases of drinking water pollution. Chemosphere 27:1171–1181.
Vattemi G, Tonin P, Filosto M, . 2005. Human skeletal muscle as a target organ of trichloroethylene toxicity. JAMA 294(5):554–556.16077048
Veeramachaneni DN, Palmer JS, Amann RP. 2001. Long-term effects on male reproduction of early exposure to common chemical contaminants in drinking water. Hum Reprod 16(5):979–987.11331649
Veith GD, Macek KJ, Petrocelli SR, . 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. In: Eaton JG, Parrish PR, Hendricks AC, eds. Proceedings of the Third Annual Symposium on Aquatic Toxicology, New Orleans, LA, Oct 17-18, 1978. Philadelphia, PA: American Society for Testing and Waste Materials, 116–129.
Vermeulen R, Zhang L, Spierenburg A, . 2012. Elevated urinary levels of kidney injury molecule-1 among Chinese factory workers exposed to trichloroethylene. Carcinogenesis 33(8):1538–1541.22665366
Vernon RJ, Ferguson RK. 1969. Effects of trichloroethylene on visual-motor performance. Arch Environ Health 18:894–900.5770690
*Vernot EH, Macewen JD, Haun CC, . 1977. Acute toxicity and skin corrosion data for some organic and inorganic compounds and aqueous solutions. Toxicol Appl Pharmacol 42:417–423.595018
Verschueren K. 1983. Handbook of environmental data on organic chemicals. New York: Van Nostrand Reinhold Co., 1131–1135.
Vesterberg O, Astrand I. 1976. Exposure to trichloroethylene monitored by analysis of metabolites in blood and urine. J Occup Med 18:224–226.1271124
*Vesterberg O, Gorczak J, Krasto M. 1976. Exposure to trichloroethylene. II. Metabolites in blood and urine. Scand J Work Environ Health 4:212–219.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Villaschi S, Giovanetti A, Lombardi CC, . 1991. Damage and repair of mouse bronchial epithelium following acute inhalation of trichloroethylene. Exp Lung Res 15:601–614.
*Vizcaya D, Christensen KY, Lavoue J, . 2013. Risk of lung cancer associated with six types of chlorinated solvents: results from two case-control studies in Montreal, Canada. Occup Environ Med 70(2):81–85. 10.1136/oemed-2012-101155.23104733
Vlaanderen J, Straif K, Pukkala E, . 2013. Occupational exposure to trichloroethylene and perchloroethylene and the risk of lymphoma, liver, and kidney cancer in four Nordic countries. Occup Environ Med 70(6):393–401. 10.1136/oemed-2012-101188.23447073
Vogel TM, McCarty PL. 1985. Biotransformation of tetrachloroethylene to trichloroethylene, dichloroethylene, vinyl chloride and carbon dioxide under methanogenic conditions. Appl Environ Microbiol 49:1080–1083.3923927
von Grote J, Hurlimann C, Scheringer M, . 2003. Reduction of occupational exposure to perchloroethylene and trichloroethylene in metal degreasing over the last 30 years: Influences of technology innovation and legislation. J Expo Anal Environ Epidemiol 13(5):325–340.12973361
*Wadden RA, Scheff PA, Franke JE. 1989. Emission factors for trichloroethylene vapor degreasers. Am Ind Hyg Assoc J 50:496–500.2801518
Wakeham SG, Davis AC, Karas JL. 1983. Microcosm experiments to determine the fate and persistence of volatile organic compounds in coastal seawater. Environ Sci Tech 17:611–617.
Wallace LA. 1986. Personal exposures, indoor and outdoor air concentrations and exhaled breath concentrations of selected volatile organic compounds measured for 600 residents of New Jersey, North Dakota, North Carolina, and California. Toxicol Environ Chem 12:215–236.
Wallace LA, Pellizzari ED, Hartwell TD, . 1985. Personal exposures, indoor-outdoor relationships, and breath levels of toxic air pollutants measured for 355 persons in New Jersey. Atmos Environ 19:1651–1661.
Wallace LA, Pellizzari ED, Hartwell TD, . 1986a. Total exposure assessment methodology (TEAM) study: Personal exposures, indoor-outdoor relationships, and breath levels of volatile organic compounds in New Jersey. Environ Int 12:369–387.
Wallace LA, Pellizzari ED, Hartwell TD, . 1986b. Concentrations of 20 volatile organic compounds in the air and drinking water of 350 residents of New Jersey compared with concentrations in their exhaled breath. J Occup Med 28:603–608.3746480
Wallace LA, Pellizzari ED, Hartwell TD, . 1986c. Results from the first three seasons of the TEAM study: Personal exposures, indoor-outdoor relationships, and breath levels of toxic air pollutants measured for 355 persons in New Jersey. In: Kopfler FC, Craun G, eds. Environmental epidemiology. Lewis Publishers Inc., 181–200.
Wallace LA, Pellizzari ED, Hartwell TD, . 1989. The influence of personal activities on exposure to volatile organic compounds. Environ Res 50:37–55.2792060
Wallace LA, Pellizzari ED, Leaderer B, . 1987. Emissions of volatile organic compounds from building materials and consumer products. Atmos Environ 21:385–393.
Wallace LA, Pellizzari ED, Sheldon L, . 1986d. The total exposure assessment methodology (TEAM) study: Direct measurement of personal exposures through air and water for 600 residents of several U.S. cities. In: Cohen Y, ed. Pollutants in a multimedia environment. New York, NY: Plenum Publishing Corp., 289–315.
Waller PA, Clauw D, Cupps T, . 1994. Fascitis (not scleroderma) following prolonged exposure to an organic-solvent (trichloroethylene). J Rheumatol 21:1567–1570.7983667
Walles SAS. 1986. Induction of single-strand breaks in DNA of mice by trichloroethylene and tetrachloroethylene. Toxicol Lett 31:31–35.3715914
Walton BT, Anderson TA. 1990. Microbial degradation of trichloroethylene in the rhizosphere: Potential application to biological remediation of waste sites. Appl Environ Microbiol 56:1012–1016.2339867
Wang G, Stacey NH. 1990. Elevation of individual serum bile acids on exposure to trichloroethylene or α-naphthylisothiocyanate. Toxicol Appl Pharmacol 105:209–215.2219116
Wang T, Lenahan R. 1984. Determination of volatile halocarbons in water by purged-closed loop gas chromatography. Bull Environ Contam Toxicol 32:429–438.6713137
Wang G, Ansari GA, Khan MF. 2007a. Involvement of lipid peroxidation-derived aldehyde-protein adducts in autoimmunity mediated by trichloroethene. J Toxicol Environ Health A 70(23):1977–1985.17966069
Wang G, Cai P, Ansari GA, . 2007b. Oxidative and nitrosative stress in trichloroethene-mediated autoimmune response. Toxicology 229(3):186–193.17123686
Wang G, Konig R, Ansari GA, . 2008. Lipid peroxidation-derived aldehyde-protein adducts contribute to trichloroethene-mediated autoimmunity via activation of CD4+ T cells. Free Radic Biol Med 44(7):1475–1482.18267128
Wang H, Zhang JX, Ye LP, . 2016. Plasma Kallikrein-Kinin system mediates immune-mediated renal injury in trichloroethylene-sensitized mice. J Immunotoxicol 13(4):567–579. 10.3109/1547691x.2016.1142019.27027470
Wang R, Zhang Y, Lan Q, . 2009. Occupational exposure to solvents and risk of non-Hodgkin lymphoma in Connecticut women. Am J Epidemiol 169(2):176–185. 10.1093/aje/kwn300.19056833
Wartenberg D, Reyner D, Scott CS. 2000. Trichloroethylene and cancer: Epidemiologic evidence. Environ Health Perspect 108(Suppl 2):161–176.10807550
Waseem M, Ali M, Dogra S, . 2001. Toxicity of trichloroethylene following inhalation and drinking contaminated water. J Appl Toxicol 21(6):441–444.11746189
Waskell L. 1978. A study of the mutagenicity of anesthetics and their metabolites. Mutat Res 57:141–153.351387
Watanabe S, Fukui T. 2000. Suppressive effect of curcumin on trichloroethylene-induced oxidative stress. J Nutr Sci Vitaminol (Tokyo) 46(5):230–234. http://www.journalarchive.jst.go.jp/jnlpdf.php?cdjournal=jnsv1973&cdvol=46&noissue=5&startpage=230&lang=en&from=jnltoc. March 31, 2011.11234915
*Waters RM, Orth OS, Gillespie NA. 1943. Trichloroethylene anesthesia and cardiac rhythm. Anesthesiology 4:1–5.
Watson RE, Jacobson CF, Williams AL, . 2006. Trichloroethylene-contaminated drinking water and congenital heart defects: A critical analysis of the literature. Reprod Toxicol 21:117–147.16181768
Weisel CP, Alimokhtari S, Sanders PF. 2008. Indoor air VOC concentrations in suburban and rural New Jersey. Environ Sci Technol 42(22):8231–8238.19068799
*Weiss NS. 1996. Cancer in relation to occupational exposure to trichloroethylene. Occup Environ Med 53:1–5.8563851
*Werch SC, Marquardt GH, Mallach JF. 1955. The action of trichloroethylene on the cardiovascular system. Am J Obstet Gynecol 69:352–364.13228508
Werner M, Birner G, Dekant W. 1996. Sulfoxidation of mercapturic acids derived from tri- and tetrachloroethene by cytochromes P450 3A: A bioactivation reaction in addition to deacetylation and cysteine conjugate β-lyase mediated cleavage. Chem Res Toxicol 9(1):41–49.8924615
*Wernisch M, Paya K, Palasser A. 1991. [Cardiac arrest after inhalation of shoemaker’s glue.] Wien Med Wochenschr 141:71–74. (German)2058157
Wershaw RL, Aiken GR, Imbrigiotta TE, . 1994. Displacement of soil pore water by trichloroethylene. J Environ Qual 23:792–798.
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Wester RC, Maibach HI. 1987. Percutaneous absorption of organic solvents. In: Maibach HI, ed. Occupational and industrial dermatology, 2nd ed. Chicago, IL: Year Book Medical Publishers, Inc., 213–226.
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76:52–59.
White JF, Carlson GP. 1979. Influence of alterations in drug metabolism on spontaneous and epinephrine-induced cardiac arrhythmias in animals exposed to trichloroethylene. Toxicol Appl Pharmacol 47:515–527.442092
White JF, Carlson GP. 1981. Epinephrine-induced cardiac arrhythmias in rabbits exposed to trichloroethylene: Potentiation by ethanol. Toxicol Appl Pharmacol 60:466–471.7292485
White JF, Carlson GP. 1982. Epinephrine-induced cardiac arrhythmias in rabbits exposed to trichloroethylene: Potentiation by caffeine. Fundam Appl Toxicol 2:125–129.6193021
White RF, Feldman RG, Eviator, II, . 1997. Hazardous waste and neurobehavioral effects: A developmental perspective. Environ Res 73(1–2):113–124.9311537
*WHO. 1981. Recommended health-based limits in occupational exposure to selected organic solvents. In: World Health Organization Technical Report Series 664. Geneva, Switzerland: World Health Organization.
*WHO. 1984. Guidelines for drinking water quality. Volume 1. Recommendations. Geneva, Switzerland: World Health Organization.
*WHO. 1985. Environmental health criteria 50: Trichloroethylene. Geneva, Switzerland: World Health Organization.
*WHO. 1990. WHO neurobehavioral core test battery. In: Johnson BL, ed. Proceedings of the Third International Symposium on Neurobehavioral Methods in Environmental and Occupational Health, Washington, DC, December 14-17, 1988. Chelsea, MI: Lewis Publishers, 225–244.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 24, 2013.
WHO. 2011. Guidelines for drinking-water quality. 4th ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/publications/2011/dwq_guidelines/en/index.html. April 24, 2013.
Wideroff L, Gridley G, Chow W-H, . 1997. Cancer incidence in a population-based cohort of patients hospitalized with diabetes mellitus in Denmark. J Natl Cancer Inst 89:1360–1365.9308706
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Williams P, Benton L, Warmerdam J, . 2002. Comparative risk analysis of six volatile compounds in California drinking water. Environ Sci Technol 36:4721–4728.12487291
*Wilmer JW, Albee RR, Nitschke KD, . 1992. Acute neurophysiological effects of trichloroethylene in rats. The Dow Chemical Company, Health and Environmental Sciences, Toxicology Research Laboratory, Midland, MI.
Wilson JT, Wilson BH. 1985. Biotransformation of trichloroethylene in soil. Appl Environ Microbiol 49:242–243.3919642
Wilson BH, Smith GB, Rees JF. 1986. Biotransformations of selected alkylbenzenes and halogenated aliphatic hydrocarbons in methanogenic aquifer material: A microcosm study. Environ Sci Technol 20:997–1002.22257397
Wilson JT, Enfield CG, Dunlap WJ, . 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10:501–506.
Wilson JT, McNabb JF, Balkwill DL, . 1983a. Enumeration and characterization of bacteria indigenous to a shallow water-table aquifer. Ground Water 21:134–142.
*Wilson JT, McNabb JF, Wilson RH, . 1983b. Biotransformation of selected organic pollutants in ground water. Dev Ind Microbiol 24:225–233.
Windemuller FJB, Ettema JH. 1978. Effect of combined exposure to trichloroethylene and alcohol on mental capacity. Int Arch Occup Environ Health 41:77–85.631909
Windham GC, Shusterman D, Swan SH, . 1991. Exposure to organic solvents and adverse pregnancy outcome. Am J Ind Med 20:241–259.1951371
Windholz M. 1983. The Merck index. 10th ed. Rahway, NJ: Merck and Co., Inc., 1378.
*Wise MG, Fisher JG, de la Pena AM. 1983. Trichloroethane (TCE) and central sleep apnea: A case study. J Toxicol Environ Health 11:101–104.6827617
Withey JR, Collins BT, Collins PG. 1983. Effect of vehicle on the pharmacokinetics and uptake of four halogenated hydrocarbons from the gastrointestinal tract of the rat. J Appl Toxicol 3:249–253.6662999
Wolfgang GH, Gandolfi AJ, Stevens JL, . 1989. N-acetyl S-(1,2-dichlorovinyl)-L-cysteine produces a similar toxicity to S-(1,2-dichlorovinyl)-L-cysteine in rabbit renal slices: Differential transport and metabolism. Toxicol Appl Pharmacol 101(2):205–219.2815079
*Wood JA, Porter ML. 1987. Hazardous pollutants in class II landfills. J Air Pollut Control Assoc 37:609–615.
*Wright JR, Bouwer EJ. 1986. Anoxic transformations of halogenated aliphatics. In: Young RA, ed. HazPro ’86: Proceedings of the HazPro ’86 Conference. Professional Certification Symposium and Exposition. Northbrook, IL: Pudvan Publishing Co., 495–497.
*Wright PFA, Thomas WD, Stacey NH. 1991. Effects of trichloroethylene on hepatic and splenic lymphocytotoxic activities in rodents. Toxicology 70:231–242.1763417
Xiao H-K, Levine SP, D’Arcy JB, . 1990. Comparison of the Fourier Transform Infrared (FTIR) spectrophotometer and the Miniature Infrared Analyzer (MIRAN®) for the determination of trichloroethylene (TCE) in the presence of Freon®-113 in workplace air. Am Ind Hyg Assoc J 51:395–401.2382642
Xu H, Tanphaichitr N, Forkert PG, . 2004. Exposure to trichloroethylene and its metabolites causes impairment of sperm fertilizing ability in mice. Toxicol Sci 82(2):590–597.15375293
Xu X, Yang R, Wu N, . 2009. Severe hypersensitivity dermatitis and liver dysfunction induced by occupational exposure to trichloroethylene. Ind Health 47(2):107–112.19367038
Xu XY, Liu YF, Lu LW, . 2012. Altered expression of hepatic metabolic enzyme and apoptosis-related gene transcripts in human hepatocytes treated with trichloroethylene. Hum Exp Toxicol 31(9):861–867.22751198
Yagi O, Uchiyama H, Iwasaki K. 1992. Biodegradation rate of chloroethylene in soil environment. Water Sci Technol 25:419–424.
*Yamazaki H, Yamaguchi T, Yamaguchi A, . 1992. Effect of halocarbons and styrene on thrombin and calcium ionosphere induced activation of rabbit platelets. Chemosphere 25:665–673.
Yang X, Jiang Y, Li J, . 2012. Lentivirus-mediated silencing of I2PP2A through RNA interference attenuates trichloroethylene-induced cytotoxicity in human hepatic L-02 cells. Toxicol Lett 209(3):232–238.22245669
Yao P, Hongqian C, Qinghe M, . 2016. Lack of TAK1 in dendritic cells inhibits the contact hypersensitivity response induced by trichloroethylene in local lymph node assay. Toxicol Appl Pharmacol 307:72–80. 10.1016/j.taap.2016.07.019.27473013
Yauck JS, Malloy ME, Blair K, . 2004. Proximity of residence to trichloroethylene-emitting sites and increased risk of offspring congenital heart defects among older women. Birth Defects Res A Clin Mol Teratol 70(10):808–814.15390315
Yoshida M, Fukabori S, Hara K, . 1996. Concentrations of trichloroethylene and its metabolites in blood and urine after acute poisoning by ingestion. Hum Exp Toxicol 15(3):254–258.8839215
Yu JF, Feng YY, Shen XF. 2017. Potential immunotoxic effects of trichloroethylene-induced IV allergic reaction in renal impairment. Cen-Eur J Imunol 42(2):140–149. 10.5114/ceji.2017.69354.
Yu JF, Leng J, Shen T, . 2012. Possible role of complement activation in renal impairment in trichloroethylene-sensitized guinea pigs. Toxicology 302(2–3):172–178.22728725
Yu KO, Barton HA, Mahle DA, . 2000. In vivo kinetics of trichloroacetate in male Fischer 344 rats. Toxicol Sci 54(2):302–311.10774812
Zenick H, Blackburn K, Hope E, . 1984. Effects of trichloroethylene exposure on male reproductive function in rats. Toxicology 31:237–250.6740699
Zhang GH, Stevens JL. 1989. Transport and activation of S-(1,2-dichlorovinyl)-L-cysteine and N-acetyl-S-(1,2-dichlorovinyl)-L-cysteine in rat kidney proximal tubules. Toxicol Appl Pharmacol 100(1):51–61.2763302
*Zhang L, Bassig BA, Mora JL, . 2013. Alterations in serum immunoglobulin levels in workers occupationally exposed to trichloroethylene. Carcinogenesis 34(4):799–802.23276795
*Zhao Y, Krishnadasan A, Kennedy N, . 2005. Estimated effects of solvents and mineral oils on cancer incidence and mortality in a cohort of aerospace workers. Am J Ind Med 48(4):249–258.16167347
Zhou YH, Cichocki JA, Soldatow VY, . 2017. Editor’s highlight: Comparative dose-response analysis of liver and kidney transcriptomic effects of trichloroethylene and tetrachloroethylene in B6C3F1 mouse. Toxicol Sci 160(1):95–110. 10.1093/toxsci/kfx165.28973375
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zielinski A. 1973. [General health state of women professionally exposed to trichloroethylene vapours]. Med Pr 24:263–271.
Ziglio G, Beltramelli G, Pregliasio F. 1984. A procedure for determining plasmatic trichloroacetic acid in human subjects exposed to chlorinated solvents at environmental levels. Arch Environ Contam Toxicol 13:129–134.6721579
Zoccolillo L, Amendola L, Insogna S, . 2010. On-line analysis of volatile chlorinated hydrocarbons in air by gas chromatography-mass spectrometry. J Chromatogr A 1217(24):3890–3895.20444461