# PEER REVIEW

A peer review panel was assembled for trichloroethylene. The panel are experts who have knowledge of trichloroethylene’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended. The panel consisted of the following members who reviewed prepublic comment draft 3 of the Toxicological Profile for Trichloroethylene:

1. Dr. H.M. Bolt, Professor, Institut für Arbeitsphysiologie an der Universität Dortmund, Dortmund, Germany;
2. Dr. James Bruckner, Department of Pharmaceutical and Biomedical Sciences, College of Pharmacy and Interdisciplinary Toxicology Program, University of Georgia, Athens, Georgia; and
3. Dr. Gloria Post, Research Scientist Office of Science, New Jersey Department of Environmental Protection, Trenton, New Jersey.

In addition, the following reviewers provided comments on the carcinogenicity discussions in postpublic comment draft 2 of the Toxicological Profile for Trichloroethylene:

1. Dr. James Bruckner, Department of Pharmaceutical and Biomedical Sciences, College of Pharmacy and Interdisciplinary Toxicology Program, University of Georgia, Athens, Georgia;
2. Dr. Hermann M. Bolt, Leibniz Research Centre for Working Environmental and Human Factors, Dortmund, Germany; and
3. Dr. Mark Purdue, National Institutes of Health, Bethesda, Maryland.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments and ATSDR’s responses to the comments, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.