# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance-specific estimates that are intended to serve as screening levels. They are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

The chronic-duration oral MRL of 0.0005 mg/kg/day was based on the results of three oral exposure studies reporting immunological, endocrine, and developmental effects in rats or mice (Johnson et al. 2003; Keil et al. 2009; Peden-Adams et al. 2006) and a PBPK model developed by EPA (2011e), which was used to calculate the idPOD human equivalency doses (HED_99_).

The ATSDR chronic-duration oral MRL of 0.0005 mg/kg/day was adopted as the ATSDR intermediate-duration oral MRL for trichloroethylene.

The chronic-duration inhalation MRL of 0.0004 ppm was based on the results of two oral exposure studies that reported endocrine and developmental effects in rats and mice (Johnson et al. 2003; Keil et al. 2009) and a PBPK model developed by EPA, which was used to calculate the idPOD and route-to-route extrapolation to human equivalency concentrations (HEC_99_) for these studies.

The ATSDR chronic-duration inhalation MRL of 0.0004 ppm was adopted as the ATSDR intermediate-duration inhalation MRL for trichloroethylene.

EPA has derived an oral reference dose (RfD) of 5x10^-4^ mg/kg/day for chronic exposure to trichloroethylene based on drinking water studies in rats and mice (IRIS 2011).

EPA has derived a chronic inhalation reference concentration (RfC) of 0.002 mg/m^3^ (0.0004 ppm) for chronic exposure to trichloroethylene based on drinking water studies in rats and mice (IRIS 2011).

The international and national regulations, advisories, and guidelines regarding trichloroethylene in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations and Guidelines Applicable to Trichloroethylene

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 1^a^ | IARC 2014
WHO | Air quality guidelines^b^ | 2.3 μg/m^3^ | WHO 2010
WHO | Drinking water quality guidelines | 0.02 mg/L^c^ | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 10 ppm | ACGIH 2012
ACGIH | STEL | 25 ppm | ACGIH 2012
AIHA | ERPG-1^c,d^ | 100 ppm | AIHA 2011
AIHA | ERPG-2^c^ | 500 ppm | AIHA 2011
AIHA | ERPG-3^c^ | 5,000 ppm | AIHA 2011
DOE | PAC-1^e^ | 130 ppm | DOE 2012
DOE | PAC-2^e^ | 450 ppm | DOE 2012
DOE | PAC-3^e^ | 3,800 ppm | DOE 2012
EPA | AEGL-1^f^ | | EPA 2013c
EPA | 10-minutes | 260 ppm | EPA 2013c
EPA | 30-minutes | 180 ppm | EPA 2013c
EPA | 60-minutes | 130 ppm | EPA 2013c
EPA | 4-hours | 84 ppm | EPA 2013c
EPA | 8-hours | 77 ppm | EPA 2013c
EPA | AEGL-2^f^ | | EPA 2013c
EPA | 10-minutes | 960 ppm | EPA 2013c
EPA | 30-minutes | 620 ppm | EPA 2013c
EPA | 60-minutes | 450 ppm | EPA 2013c
EPA | 4-hours | 270 ppm | EPA 2013c
EPA | 8-hours | 240 ppm | EPA 2013c
EPA | AEGL-3^f^ | | EPA 2013c
EPA | 10-minutes | 6,100 ppm | EPA 2013c
EPA | 30-minutes | 6,100 ppm | EPA 2013c
EPA | 60-minutes | 3,800 ppm | EPA 2013c
EPA | 4-hours | 1,500 ppm | EPA 2013c
EPA | 8-hours | 970 ppm | EPA 2013c
EPA | Hazardous air pollutant | Yes | EPA 2013d; 42 USC 7412
EPA | NAAQS | No data | EPA 2013g
NIOSH | REL (potential occupational carcinogen) | 2 ppm (60-minute ceiling as anesthetic gas) 25 ppm (10-hour TWA for all other exposures) | NIOSH 2013
NIOSH | IDLH | 1,000 ppm (potential occupational carcinogen) | NIOSH 1994c
OSHA | PEL (8-hour TWA) for general industry | 100 ppm | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
OSHA | Acceptable ceiling concentration | 200 ppm | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
OSHA | Acceptable maximum peak above the acceptable ceiling concentration for an 8-hour shift | 300 ppm for 5 minutes in any 2 hours | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
OSHA | Highly hazardous chemicals | No data | OSHA 2013a; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2012a; 40 CFR 116.4
EPA | Drinking water contaminant candidate list | No data | EPA 2009c; 74 FR 51850
EPA | Drinking water standards and health advisories | | EPA 2012b
EPA | DWEL | 0.2 mg/L | EPA 2012b
EPA | Cancer risk at 10^-4^ | 0.3 mg/L | EPA 2012b
EPA | Public health goal | Zero | EPA 2012b
EPA | National primary drinking water standards | | EPA 2009d
EPA | MCL^g^ | 0.005 mg/L | EPA 2009d
EPA | Public health goal | Zero | EPA 2009d
EPA | National recommended water quality criteria: human health for the consumption of (at 10^-4^ risk) | | EPA 2009e
EPA | Water + organism | 2.5 μg/L | EPA 2009e
EPA | Organism only | 30 μg/L | EPA 2009e
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No data | EPA 2012d; 40 CFR 117.3
FDA | Allowable trichloroethylene level in bottled water | 0.005 mg/L | FDA 2018; 21 CFR 165.110
c. Food
FDA | EAFUS^h^ | Yes | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | A2^i^ | ACGIH 2012
ACGIH | BEI (end of shift end of workweek) | | ACGIH 2012
ACGIH | Trichloroethylene acid in urine | 15 mg/L | ACGIH 2012
ACGIH | Trichloroethylene in blood (without hydrolysis) | 0.5 mg/L | ACGIH 2012
EPA | Carcinogenicity classification | Carcinogenic to humans | IRIS 2011
EPA | RfC | 0.002 mg/m^3^ | IRIS 2011
EPA | RfD | 5x10^-4^ mg/kg/day | IRIS 2011
EPA | Oral slope factor | 4.6x10^-2^ per mg/kg/day | IRIS 2011
EPA | Inhalation unit risk | 4.1x10^-6^ per μg/m^3^ | IRIS 2011
EPA | Identification and listing of hazardous waste | U228 | EPA 2012c; 40 CFR 261, Appendix VIII
EPA | Inert pesticide ingredients in pesticide products approved for nonfood use only | No data | EPA 2013e
EPA | Master Testing List | Yes^j^ | EPA 2013f
EPA | RCRA waste minimization PBT priority chemical list | No data | EPA 1998; 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | Yes | EPA 2012e; 40 CFR 264, Appendix IX
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity pursuant to Section 311(b)(2) of the Clean Water Act, Section 307(a) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA | 200 pounds | EPA 2012f; 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | 01/01/1987 | EPA 2012h; 40 CFR 372.65
EPA | Extremely hazardous substances and its threshold planning quantity | No data | EPA 2012g; 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | No data | EPA 2012i; 40 CFR 712.30
EPA | TSCA health and safety data reporting | No data | EPA 2012j; 40 CFR 716.120
NTP | Carcinogenicity classification | Known to be a human carcinogen | NTP 2016

a Group 1: carcinogenic to humans.

b The concentration of airborne trichloroethylene associated with an excess lifetime cancer risk of 1 in 1,000,000.

c ERPG-1: maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing other than mild transient adverse health effects or perceiving a clearly defined, objectionable odor; ERPG-2: maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing or developing irreversible or other serious health effects or symptoms that could impair an individual’s ability to take protective action; ERPG-3: is the maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing or developing life-threatening health effects (AIHA 2011).

d Odor should be detectable near ERPG-1.

e PAC-1: mild, transient health effects; PAC-2: irreversible or other serious health effects that could impair the ability to take protective action; PAC-3: life-threatening health effects (DOE 2012).

f AEGL-1: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic, nonsensory effects; however, these effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting, adverse health effects or an impaired ability to escape; AEGL-3: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening adverse health effects or death (EPA 2013c).

g Potential health effects from long-term exposure above the MCL could cause liver problems and increased risk of cancer; common sources of contaminant in drinking water include discharges from metal degreasing sites and other factories (EPA 2009d).

h The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

i A2: suspected human carcinogen.

j Chemical testing program underway and voluntary testing agreement under SIDS for health and ecological effects and chemical fate.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; BEI = biological exposure indices; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; SIDS = screening information data set; STEL = short-term exposure level; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization