# 7 ANALYTICAL METHODS

The purpose of this chapter is to describe the analytical methods that are available for detecting, measuring, and/or monitoring trichloroethylene, its metabolites, and other biomarkers of exposure and effect to trichloroethylene. The intent is not to provide an exhaustive list of analytical methods. Rather, the intention is to identify well-established methods that are used as the standard methods of analysis. Many of the analytical methods used for environmental samples are the methods approved by federal agencies and organizations such as EPA and the National Institute for Occupational Safety and Health (NIOSH). Other methods presented in this chapter are those that are approved by groups such as the Association of Official Analytical Chemists (AOAC) and the American Public Health Association (APHA). Additionally, analytical methods are included that modify previously used methods to obtain lower detection limits and/or to improve accuracy and precision.

## 7.1 BIOLOGICAL MATERIALS

Several methods are available for the analysis of trichloroethylene in biological media. The method of choice depends on the nature of the sample matrix; cost of analysis; required precision, accuracy, and detection limit; and turnaround time of the method. The main analytical method used to analyze for the presence of trichloroethylene and its metabolites, trichloroethanol and TCA, in biological samples is separation by gas chromatography (GC) combined with detection by mass spectrometry (MS) or electron capture detection (ECD) (Delinsky et al. 2005). Trichloroethylene and/or its metabolites have been detected in exhaled air, blood, urine, breast milk, and tissues. A head-space in-tube extraction GC/MS method was developed for detection of volatile low molecular weight compounds in blood and/or urine samples. Tenax® adsorbent resin is used for adsorption and porous, open tubular GC is employed for separation (Rasanen et al. 2010). Details on sample preparation, analytical method, and sensitivity and accuracy of selected methods are provided in Table 7-1.

Several studies have analyzed breath samples for trichloroethylene. Preconcentration on Tenax®-GC cartridges, followed by thermal desorption onto a cryogenic trap connected to the gas chromatograph, was used to analyze exhaled air in several TEAM studies (Wallace et al. 1986a, 1986b, 1986c, 1986d). Vapors were thermally released directly onto the gas chromatograph column for separation and detection by electron impact mass spectrometry (EIMS). A similar study analyzed for trichloroethylene in expired air by directly injecting a portion of the collected sample from a Tedlar® bag into a gas chromatograph equipped with an ECD (Monster and Boersma 1975). Sensitivity was better with GC/MS, but precision was greater with GC/ECD. No recovery data were given for the GC/ECD technique, so accuracy could not be compared. GC/ECD was also used to measure trichloroethanol, a metabolite of trichloroethylene, in expired air (Monster and Boersma 1975). The sensitivity and precision were comparable to that of trichloroethylene measurement.

Table 7-1 Analytical Methods for Determining Trichloroethylene in Biological Materials

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Exhaled air | Collected in Tedlar® bag; injected into GC | GC/ECD (both trichloroethylene and trichloro-ethanol) | 5 ppb (trichloroethylene); 2 ppb (trichloro-ethanol) | Not reported | Monster and Boersma 1975
Exhaled air | Collected on Tenax®-GC, thermally desorbed; injected into GC | HRGC/MS | 0.3 ppb | 95–99 | Wallace et al. 1986a
Blood | Blood transferred to a pre-weighed SPME headspace vial using a 2-mL pre-cleaned glass syringe, agitated, and then transferred to the GC injection port | (SPME-GC– MS/MS | 0.027 µg/L | 78–99 | Aranda-Rodriguez et al. 2015
Blood | Digested with H_2_SO_4_: dimethyl sulfate at 60°C for 4 hours; headspace gas injected into GC | GC/ECD (trichloroethylene, trichloro-ethanol, and trichloro-acetic acid) | 3 ppb (trichloroethylene); 60 ppb (trichloro-ethanol); 30 ppb trichloro-acetic acid) | Not reported | Monster and Boersma 1975
Blood | Thermally decarboxylated; subjected to static headspace analysis | GC/ECD (for metabolite TCA) | 2 ppb | 101–109 | Ziglio et al. 1984
Blood | Enzyme hydrolysis of sample; decarboxy-lation of TCA; headspace gas analyzed | GC/ECD | 20 ppb | 95 (trichloro-ethanol); 102 (trichloro-ethanol); 94 (TCA) | Christensen et al. 1988
Blood, plasma, and serum | Sample in sealed vial subjected to static headspace analysis | GC/ECD | 100 ppb | Not reported | Ramsey and Flanagan 1982
Urine | Thermally decarboxylated; reacted with pyridine | Spectro-photometry (for metabolite TCA) | <800 ppb | 93.5 | Pekari and Aitio 1985a
Urine | Enzyme hydrolysis of sample; decarboxy-lation of TCA; headspace gas analyzed | GC/ECD | 20 ppb | 96 (trichloro-ethanol); 98 (TCA) | Christensen et al. 1988
Urine | Hydrolyzed with H_2_SO_4_; extracted with isooctane; injected into GC | GC/ECD (for metabolite trichloro-ethanol) | 75 ppb | 98.2 | Pekari and Aitio 1985b
Tissue | Mixed with a proteolytic enzyme; incubated at 65°C; headspace gas analyzed | GC/ECD | Not reported | Not reported | Ramsey and Flanagan 1982
Tissue | Homogenized with saline and isooctane at 4°C; headspace gas analyzed | GC/ECD | 8.4 ppb | 86–91 | Chen et al. 1993
Liquid, solid, and oily matrices including animal tissues | Water added to the sample (soil, tissue, or oil), followed by vacuum distillation and cryogenic trapping | VD/GC/MS (Method 8261) | – | – | EPA 2007h
Human milk | Purged warm; trapped in Tenax®-GC; thermally desorbed | HRGC/MS | Qualitative identification | Not reported | Pellizzari et al. 1982

ECD = electron capture detector; GC = gas chromatography; HRGC = high-resolution gas chromatography; H_2_SO_4_ = sulfuric acid; MS = mass spectrometry; SPME-GC–MS/MS = solid-phase microextraction gas chromatography coupled with isotope-dilution mass spectrometry in selected reaction monitoring mode; TCA = trichloroacetic acid

The method most frequently used to determine the presence of trichloroethylene or its metabolites in biological tissues and fluids is headspace analysis, followed by GC/MS or GC/ECD (Christensen et al. 1988; Monster and Boersma 1975; Pekari and Aitio 1985a, 1985b; Ziglio et al. 1984). In headspace analysis, the gaseous layer above the sample is injected into the gas chromatograph. Headspace gases can be preconcentrated prior to GC analysis (Michael et al. 1980) or injected directly into the gas chromatograph (Collins et al. 1986; Ramsey and Flanagan 1982). Analysis of blood and urine for the trichloroethylene metabolites TCA, trichloroethanol, and trichloroethanol-β-glucuronide has been done primarily by headspace GC/ECD (Christensen et al. 1988). Trichloroethanol-β-glucuronide in the samples was first hydrolyzed to trichloroethanol by β-glucuronidase; TCA was then decarboxylated to chloroform. A headspace sample was then analyzed for trichloroethanol and chloroform. The method had relatively high accuracy and acceptable precision. Detection limits were generally in the low-ppb range. Whole-tissue analysis has been performed by GC/ECD after enzyme treatment (Ramsey and Flanagan 1982) and after homogenization in the presence of an extractive solvent (Chen et al. 1993). A method that measures biomarkers of exposure to VOC parent compounds such as trichloroethylene has been reported. The trichloroethylene, metabolite N-acetyl-S-(1,2-dichlorovinyl)-L-cysteine, has been effectively quantified in urine using ultra high performance liquid chromatography coupled with electrospray ionization tandem mass spectrometry (UPLC-ESI/MSMS) (Alwis et al. 2012).

Purge-and-trap methods have also been used to analyze biological fluids for the presence of trichloroethylene. Breast milk and blood were analyzed for trichloroethylene by purging onto a Tenax® gas chromatograph to concentrate the volatiles, followed by thermal desorption and analysis by GC/MS (Antoine et al. 1986; Pellizzari et al. 1982). However, the breast milk analysis was only qualitative, and recoveries appeared to be low for those chemicals analyzed (Pellizzari et al. 1982). Precision (Antoine et al. 1986) and sensitivity (Pellizzari et al. 1982) were comparable to headspace analysis. Quantitative analysis of trichloroethylene in breast milk is performed using GC/MS after the samples undergo homogenization, lipid hydrolysis, centrifugation, and extraction. The methods limit of detection is 1.5 ng/mL (Beamer et al. 2012).

Additional information regarding methods for monitoring trichloroethylene in biological samples is available in the CDC Fourth National Report on Human Exposure to Environmental Chemicals (CDC 2018).

## 7.2 ENVIRONMENTAL SAMPLES

Analysis of environmental samples is similar to that of biological samples. The most common methods of analyses are GC coupled to MS, ECD, a Hall’s electrolytic conductivity detector (HECD), or a flame-ionization detector (FID) (Delinsky et al. 2005). Preconcentration of samples is usually done for air by sorption on a solid sorbent and by the purge-and-trap method for liquid and solid matrices. Alternatively, headspace above liquid and solid samples may be analyzed without preconcentration. Details of commonly used analytical methods for several types of environmental samples are presented in Table 7-2.

The primary methods of analyzing for trichloroethylene in air are GC combined with MS and GC with ECD. Air samples are usually pumped through a sample collection column, with Tenax®-GC and coconut charcoal, the most common adsorbents. Trichloroethylene is thermally desorbed from the collection column and concentrated on a cryogenic trap column located on the gas chromatograph. Vapors are heat-released from the trapping column directly to the gas chromatograph (Krost et al. 1982; Wallace et al. 1986a, 1986b, 1986c, 1986d). Grab-samples of air can also be obtained and preconcentrated on a cryogenic column (Makide et al. 1979; Rasmussen et al. 1977). The limit of detection for both GC/ECD and GC/MS is in the low- to sub-ppb range (Krost et al. 1982; Makide et al. 1979; Rasmussen et al. 1977; Wallace et al. 1986a, 1986d). With careful technique, precision for both is acceptable (Krost et al. 1982; Rasmussen et al. 1977; Wallace et al. 1986a, 1986b, 1986c, 1986d). Accuracy of the two analytical methods could not be compared because no recovery data were located for GC/ECD. NIOSH Methods 3071 and 1022 describe techniques for detection of trichloroethylene in air which combine GC with photoionization detection (PID) or flame ionization detection (FID) (NIOSH 1994a, 1994b). Sample detection limits are in the low ppm range. The detection and measurement of trichloroethylene in air can also be adequately performed using infrared spectrometry instead of GC (Xiao et al. 1990). EPA Method 0031is used to analyze and prepare VOCs, such as trichloroethylene, in gaseous emissions from stationary sources such as hazardous waste incinerators. The concentration of each compound in the emission should not exceed the upper concentration limit of 1.5 ppm. The target detection limit is 0.1 µg/m³ (ng/L) (EPA 1996c). Improvements in the sensitivity of analytical methods for volatile chlorinated hydrocarbons in air have been reported by Zoccolillo et al. (2010). The method is based on cryofocusing trap injection combined with GC/MS. The detection limit for trichloroethylene was reported as 0.1 parts per trillion by volume (pptv). A novel method for the detection of trichloroethylene in indoor air, in the presence of multiple interferences, is reported by Kim et al. (2011, 2012). The method involves a micro-fabricated GC and microsensor array detection. The limit of detection for the sensors used range from 0.8 to 2.4 ppb in a 1-L sample and from 0.04 to 0.12 ppb in a 20-L sample (Kim et al. 2011, 2012).

Table 7-2 Analytical Methods for Determining Trichloroethylene in Environmental Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Air | Sample is collected using Tedlar bags and a flow rate of 0.02– 0.05 L/minute or higher | Portable GC/PID (Method 3701) | 0.1 ppm | — | NIOSH 1994b
Air | Sample is collected using a solid sorbent tube with coconut shell charcoal and a flow rate of 0.01–0.2 L/minute | GC/FID (Method 1022) | 27 ppm | 92–94 | NIOSH 1994a
Air | Collected in stainless steel canister; preconcentrated in cooled adsorbent; thermally desorbed | GC/ECD | 1 ppt | Not reported | Makide et al. 1979
Air | Adsorbed on Tenax®-GC thermally desorbed to on-column cold trap; heat-released | HRGC/MS | 1.9 ppt | Not reported | Krost et al. 1982
Air | Collected in stainless steel canister; preconcentrated by cryogenic trapping; thermally desorbed | GC/ECD | 0.3 ppt | Not reported | Rasmussen et al. 1977
Air | Adsorbed on Tenax®-GC; thermally desorbed to on-column cold trap; heat-released | HRGC/MS | 15 ppt | 95–99 | Wallace et al. 1986a
Air | Collected in canisters with a diaphragm pump; cryofocusing trap injection | GC/MS | 0.1 pptv | — | Zoccolillo et al. 2010
Effluent gas | Sampling is done using a heated glass-lined probe with an isolation valve, charcoal trap, and water cooled glass condenser; adsorption is on a set of Tenax®-GC traps and an Anasorb®-747 trap | GC/MS (Method 0031) | 0.1 µg/m³ | — | EPA 1996c
Water | Sample is purged and trapped and then thermally desorbed | GC/PID (Method 502.2) | 0.3–0.5 ppb | 97–101 | EPA 1995a
Water | Sample is purged and trapped and then thermally desorbed | GC/ELCD (Method 502.2) | 0.02–0.04 ppb | 96–98 | EPA 1995a
Water | Sample is purged and trapped and then thermally desorbed | Preparation only (Method 5030C) | — | — | EPA 2003
Water | Sample is purged and trapped and then thermally desorbed | GC/MS (Method 524.2) | 0.02–0.19 ppb | 90–106 | EPA 1995b
Water | Headspace-free samples collected in amber glass vials with polytetrafluoroethylene-faced septa, purged and trapped, and then thermally desorbed | GC/MS (Method 524.3) | 0.035 ppb | 91.6–107 | EPA 2009b
Water | Sample is extracted using methyl tert-butyl ether or pentane and injected into the GC column | GC/ECD (Method 551.1) | 0.002–0.042 ppb | 93–101 | EPA 1995c
Water | Sample is purged and trapped and then thermally desorbed | GC/MS (Method 6200B) | 0.045 ppb | 105 | APHA 1998a
Water | Sample is purged and trapped | GC/ECD (Method 6200C) | 0.012 ppb | 80 | APHA 1998b
Water | Sample is purged and trapped | GC/PID (Method 6200C) | 0.014 ppb | 57 | APHA 1998b
Water | Sample is purged and trapped and then thermally desorbed | GC/MS (Method O-3115) | 3 ppb | 70–130 | USGS 1987
Water | Sample is purged and trapped and then thermally desorbed | GC/MS (Method O-4127-96) | 0.028 ppb | 92.1–111 | USGS 1998
Water | Purged and trapped on Tenax®-GC; thermally desorbed | HRGC/HSD | 0.5 ppb | 91 | APHA 1985
Water | Purged and trapped on coconut charcoal/Tenax®/silica gel; thermally desorbed | GC/MS | 1.9 ppb | 101 | EPA 1982b, 1982e
Water | Purged and trapped on coconut charcoal/Tenax®/silica gel; thermally desorbed | GC/HSD | 0.12 ppb | 106 | EPA 1982b, 1982e
Water | Equilibrated in sealed vial at room temperature; headspace gas injected into GC | GC/ECD | 0.04 ppb | 105 | Dietz and Singley 1979
Water | Purged at room or elevated temperature; trapped in closed loop; injected into GC | GC/ECD | 0.2 ppb | 104 | Wang and Lenahan 1984
Water | Purged and trapped on Tenax®-GC; thermally desorbed | GC/HECD; GC/FID | <0.1 ppb (HECD); 0.1 ppb (FID) | 98 (HECD); 79 (FID) | Otson and Williams 1982
Water | Purged and trapped on Tenax®-GC; thermally desorbed | GC/HECD | 0.05 ppb | 50–90 | Wallace et al. 1986a
Water | Sample directly injected | GC/UV | 1 ppb | 39 | Motwani et al. 1986
Waste water (municipal and industrial discharges) | Sample is purged and trapped with direct aqueous injection; then thermally desorbed onto column | GC/ECD or MCD (Method 601) | 0.12 ppb | 87 | EPA 2001a
Waste water (municipal and industrial discharges) | Sample is purged and trapped; the trap is backflushed and heated to desorb compounds onto column | GC/MS (Method 624) | 4.1 ppb | 104 | EPA 2010c
Water/Waste water | Grab sample is collected in glass containers, purged and trapped with isotopic dilution, and then thermally desorbed | GC/MS (Method 1624) | 10 ppb/10 μg/L | Labeled compound recovery: 35–196 | EPA 2007a
Groundwater, aqueous sludges, caustic liquors, soils, sediments | Purge-and-trap (EPA Method 624) or direct injection (EPA Method 5030) | GC/MS | 5 μg/L (groundwater; 5 μg/kg (soil/sediment) | 71–157% | EPA 1994c
Groundwater, surface water, waste water | Purge-and-trap (EPA Method 624) or direct injection (EPA Method 5030) | GC with electrolytic conductivity detector (HECD) | 0.001 μg/L | 35–146 | EPA 1994b Method 8010B
Soil | Equilibrated in sealed vial; headspace gas injected into GC | GC/PID | 100 ppb | Not reported | Hewitt et al. 1992
Soil | Equilibrated in sealed vial; headspace gas injected into GC | GC/FID | Not reported | 80 | Pavlostathis and Mathavan 1992
Solid waste | Sample can be directly injected or prepared by purge and trap, headspace, or vacuum distillation | GC/PID (Method 8021B) | 0.2 ppb | 100 | EPA 1996a
Solid waste | Sample can be directly injected or prepared by purge and trap, headspace, or vacuum distillation | GC/HECD (Method 8021B) | 0.1 ppb | 96 | EPA 1996a
Soils/sediments and solid waste | Samples collected in crimp-seal or screw-top headspace vial, preserved and fortified, rotated for diffusion, equilibrated and mixed; headspace gas is forced into GC by pressurizing with helium (Method 5021) | GC/MS (Method 8260B) | 0.1–3.4 µg/kg | | EPA 1996b 1996d
Solid waste | Sample can be directly injected or prepared by purge and trap, headspace, or vacuum distillation (EPA Methods 5030/5035, 5032, 5041) | GC/MS (Method 8260B) | — | — | EPA 1996b; 1996e, 1996f, 1996g, 1996h
Liquid and solid waste | Equilibrated in sealed vial; headspace gas injected into GC | GC/HSD | 0.03 ppb | 106 | EPA 1982c
Building materials and consumer products^a^ | Collected by adsorption onto sorbent; thermally desorbed | HRGC/MS | 0.02 ppt | Not reported | Wallace et al. 1987
Food | Undigested or H_2_SO_4_-digested samples at 90°C subjected to static headspace analysis | HRGC/ECD; GC/MS | 0.23 ppb | 90–100 | Entz and Hollifield 1982
Food | Extraction with isooctane; clean-up on Florisil column if needed | GC/ECD; GC/HECD | 6 ppb (GC/ECD); 13 ppb (GC/HECD) | >50 | Daft 1988
Grains, grain-based foods | Purged and trapped on Tenax®/XAD-4 resin; desorb with hexane | GC/ECD | Low- to sub-ppb | 86–100 | Heikes and Hopper 1986
Liquid, solid, and oily matrices including animal tissues | Water is added to the sample (soil, tissue, or oil); followed by vacuum distillation and cryogenic trapping (Method 5023) | VD/GC/MS (Method 8261) | — | — | EPA 1996e, 2007

a Sample is air from an environmental chamber containing the building material or consumer product.

ECD = electron capture detector; ELCD = electrolytic conductivity detector; FID = flame ionization detection; GC = gas chromatography; HECD = Hall electrolytic conductivity detector; HRGC = high-resolution gas chromatography; HSD = halogen-specific detector; H_2_SO_4_ = sulfuric acid; MS = mass spectrometry; PID = photo ionization detection; pptv = parts per trillion by volume; USGS = United States Geological Survey; UV = ultraviolet detection; VD = vacuum distillation

Trichloroethylene can be detected in drinking water, groundwater, waste water, and leachate from solid waste. In most methods, trichloroethylene is liberated from the liquid matrix by purging with an inert gas and concentrated by trapping on a suitable solid sorbent. Trichloroethylene is thermally desorbed and backflushed onto the gas chromatograph column with an inert gas. Detection of trichloroethylene is generally by HECD (or other halogen-specific detector) or MS (APHA 1985, 1998a, 1998b; EPA 1982b, 1982c, 1982e, 1995a, 1995b, 1995c, 2001a, 2001c, 2007a, 2009b; Otson and Williams 1982; USGS 1987, 1998; Wallace et al. 1986a, 1986c, 1986d). The limit of detection is in the sub-ppb range for halogen-specific detectors (APHA 1985; EPA 1982b, 1982c, 1982e) and in the low-ppb range for MS (EPA 1982b, 1982e). An experiment with a purge-closed loop sample extraction system, followed by GC/ECD, GC/HECD, or GC/FID analysis, yielded a sensitivity and reproducibility comparable to headspace analysis (Otson and Williams 1982; Wang and Lenahan 1984).

Headspace analysis has also been used to determine trichloroethylene in water samples. High accuracy and excellent precision were reported when GC/ECD was used to analyze headspace gases over water (Dietz and Singley 1979). Direct injection of water into a portable GC suitable for field use employed an ultraviolet detector (Motwani et al. 1986). While detection was comparable to the more common methods (low ppb), recovery was very low. Solid waste leachates from sanitary landfills have been analyzed for trichloroethylene and other volatile organic compounds (Schultz and Kjeldsen 1986). Detection limits for the procedure, which involves extraction with pentane followed by GC/MS analysis, are in the low-ppb and low-ppm ranges for concentrated and unconcentrated samples, respectively. Accuracy and precision data were not reported.

Analysis of soils and sediments is typically performed with aqueous extraction followed by headspace analysis or the purge-and-trap methods described above. Comparison of these two methods has found them equally suited for on-site analysis of soils (Hewitt et al. 1992). The major limitation of headspace analysis has been incomplete desorption of trichloroethylene from the soil matrix, although this was shown to be alleviated by methanol extraction (Pavlostathis and Mathavan 1992). A head-space method using helium to force the gas into the GC reports detection limits of 0.1–3.4 µg/kg (EPA 1996B).

Several procedures for determination of trichloroethylene in food were located. GC/ECD and GC/halogen-specific detector (HSD) are most commonly used to analyze solid samples for trichloroethylene contamination. Extraction, purge-and-trap, and headspace analysis have all been used to prepare samples. Analysis of headspace gases by GC coupled with ECD, MS, or HSD has proven relatively sensitive (low- to sub-ppb range) and reproducible for a variety of foods (Entz and Hollifield 1982; EPA 1982b, 1982e). GC/MS has also been used to analyze building materials and consumer products (Wallace et al. 1987). GC/HSD of headspace gases is the EPA-recommended method for solid matrices (EPA 1982c). Foods have also been analyzed for trichloroethylene by GC/ECD/HECD following isooctane extraction. Sensitivity was comparable to headspace methods, but recovery (>50%) and precision (18–59%) were not as good (Daft 1988). In both preparation techniques, increased lipid content of the matrix adversely affected accuracy and precision. A purge-and-trap technique proved useful for analyzing grains and grain-based foods with high sensitivity and good recovery (Heikes and Hopper 1986).

## 7.3 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of trichloroethylene is available. Where adequate information is not available, ATSDR, in conjunction with NTP, is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of trichloroethylene.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 7.3.1 Identification of Data Needs

Methods for Determining Biomarkers of Exposure and Effect.

Exposure. Methods are available for monitoring exposure to trichloroethylene by measuring trichloroethylene in breath and blood; trichloroethanol in breath, blood, and urine; and TCA in blood and urine (Christensen et al. 1988; Monster and Boersma 1975; Pellizzari et al. 1982; Ramsey and Flanagan 1982; Wallace et al. 1986a, 1986b, 1986c, 1986d). Available methods are sensitive for measuring levels of trichloroethylene and its metabolites at which health effects have been observed to occur, for example, in workers known to be overexposed to trichloroethylene (Christensen et al. 1988; Monster and Boersma 1975; Ziglio et al. 1984). These methods have also been used to measure background levels of trichloroethylene and its metabolites in individuals believed not to have been exposed to higher-than-expected levels of trichloroethylene (e.g., office workers and housewives). The methods are generally reliable, although increased precision for most methods would increase reliability. However, trichloroethylene is pervasive in the environment, and background levels for the general population are ill defined. Levels may vary considerably within the environment, making it difficult to differentiate between normal background exposure and excess exposure. Further research on the relationship between levels found in living environments and levels found in biological media would help in better defining background levels of the chemical. This would also aid in determining if improved methods of monitoring exposure are needed.

Effect. Improved methods of tissue analysis, giving greater sensitivity and reproducibility, would help in determining the quantitative relationship between observed toxic effect on specific organs and levels of trichloroethylene in these organs. Trichloroethylene is known to affect the kidney. To determine the potential for human kidney damage resulting from workplace air exposure to trichloroethylene, urinary total protein and β2-microglobulin can be measured. To detect renal glomerular dysfunction, urinary total protein is analyzed by the Coomassie blue dye binding method using a protein assay. To detect renal tubular dysfunction, an enzyme immunoassay is used to measure β2-microglobulin (Nagaya et al. 1989b).

Methods for Determining Parent Compounds and Degradation Products in Environmental Media. Existing methods for determining trichloroethylene in air and water, the media of most concern for human exposure, are sensitive, reproducible, and reliable for measuring background levels in the environment (see Table 7-1). These methods can also be used to measure levels of trichloroethylene and its metabolites at which health effects occur. Research investigating the relationship between levels measured in air and water and observed health effects could increase our confidence in existing methods and/or indicate where improvements are needed. Methods for solid matrices vary in accuracy and precision depending on the method and the matrix (e.g., sludge, soil, sediment, building material). No detailed descriptions of methods specifically for soil were located. Soil analyses presumably were done using a method for solid waste (e.g., EPA Method 8010). Data specifically for soil might be useful in evaluating the reliability of soil data and in determining if additional methods are needed. Improved methods of detecting trichloroethylene in plants and foods, especially those with higher fat content, would aid in determining the contribution of trichloroethylene exposure from these sources. This would be especially important in determining the potential for contamination of populations living adjacent to hazardous waste sites and other potential sources of exposure to higher than background levels of trichloroethylene.

### 7.3.2 Ongoing Studies

The Division of Laboratory Sciences at the National Center for Environmental Health, Centers for Disease Control and Prevention continues to develop and refine methods for the analysis of trichloroethylene and other volatile organic compounds in blood (CDC 2018). These methods use purge and trap methodology, high-resolution gas chromatography, and magnetic sector mass spectrometry, which give detection limits in the low parts per trillion (ppt) range.