# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

The chemical formula, structure, synonyms, and identification numbers for trichloroethylene are listed in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Important physical and chemical properties of trichloroethylene are listed in Table 4-2.

Table 4-1 Chemical Identity of Trichloroethylene

Characteristic | Information
Chemical name | Trichloroethylene
Synonym(s) | Acetylene trichloride; 1-chloro-2,2-dichloroethylene; 1,1-dichloro-2-chloroethylene; ethylene trichloride; TCE; 1,1,2-trichloroethylene; trichloroethene | CAS 2011; ChemIDplus 2013
Registered trade name(s) | Algylen; Anamenth; Benzinol; Blancosolv; Cecolene; Chlorilen; Chlorylen; Densinfluat; Dow-tri; Fleck-flip; Flock FLIP; Fluate; Germalgene; Lanadin; Lethurin; Narcogen; Narkosoid; Nialk; Perm-A-chlor; Petzinol; Philex; Threthylen; Threthylene; Trethylene; Tri; Triasol; Trichloran; Trichloren; Triclene; Trielene; Trielin; Trieline; Trilen; Trilene; Trimar; Vestrol; Vitran; Westrosol | ChemIDplus 2013; IARC 1995
Chemical formula | C_2_HCl_3_ | ChemIDplus 2013
Chemical structure | [image] | ChemIDplus 2013
Identification numbers:
CAS registry | 79-01-6 | ChemIDplus 2013
NIOSH RTECS | KX4550000 | NIOSH 2011
EPA hazardous waste | U228; F002; D040 | HSDB 2013
DOT/UN/NA/IMDG shipping | UN1710; IMO6.1 | HSDB 2013
HSDB | 133 | HSDB 2013
NCI | NCI-C04546 | HSDB 2013

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Trichloroethylene^a^

Property | Information
Molecular weight | 131.39
Color | Clear, colorless
Physical state | Liquid
Melting point | −84.7°C
Boiling point | 87.2°C
Density at 20°C | 1.4642 g/cm^3^
Vapor density (air=1) | 4.53
Odor | Ethereal; chloroform-like; sweet
Odor threshold:
Water | No data
Air | 21.4 ppm
Solubility:
Water at 25°C | 1,280 mg/L^b^
Organic solvents | Soluble in ethanol, diethyl ether, acetone, and chloroform
Partition coefficients:
Log K_ow_ | 2.61
Log K_oc_ | 49–460^c^
Vapor pressure at 20°C | 69 mm Hg at 25°C^d^
Henry’s law constant at 25°C | 9.85×10^−3^ atm-m^3^/mol at 25°C^e^
Autoignition temperature | 420°C
Flashpoint | No data
Flammability limits | 8.0–10.5%
Conversion factors | 1 mg/m^3^=0.18 ppm^f^; 1 ppm=5.46 mg/m^3f^
Explosive limits | No data

a All information obtained from HSDB 2013, except where noted.

b Horvath et al. 1999.

c Brigmon et al. 1998; Chiou and Kile 1998; Garbarini and Lion 1986; Mouvet 1993; Rathbun 1998; Sahoo and Smith 1997.

d Boublik et al. 1984.

e Leighton and Calo 1981.

f Calculated based on molecular weight.