# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## Trichloroethylene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Trichloroethylene
CAS Numbers: | 79-01-6
Date: | June 2019
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 61, 86
Species: | Mouse, Rat

[underlined: Minimal Risk Level]: 0.0004 [ ] mg/kg/day [X] ppm

The ATSDR chronic-duration inhalation MRL of 0.0004 ppm for trichloroethylene was adopted as the ATSDR intermediate-duration inhalation MRL (see chronic-duration inhalation MRL worksheet for more information). The ATSDR chronic-duration inhalation MRL is based, in part, on results of PBPK modeling exercises that simulated 100 weeks of exposure for humans (EPA 2011e). Sample simulations for a 52-week exposure (within the range of an ATSDR-defined intermediate-duration exposure [15–364 days]) resulted in the same internal dose point of departure (idPOD) as the idPOD resulting from simulations for the 100-week exposure.

[underlined: Agency Contact (Chemical Manager)]: G. Daniel Todd, Ph.D.

## Trichloroethylene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Trichloroethylene
CAS Numbers: | 79-01-6
Date: | June 2019
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 61, 86
Species: | Mouse, Rat

[underlined: Minimal Risk Level]: 0.0004 [ ] mg/kg/day [X] ppm

The chronic-duration inhalation MRL is based on the results of two critical oral exposure studies that reported decreased thymus weight in female mice (Keil et al. 2009) and fetal heart malformations in rats (Johnson et al. 2003). In the EPA assessment for trichloroethylene (EPA 2011e), EPA developed a PBPK model, which was used to calculate the idPOD and perform route-to-route extrapolation to human equivalency concentrations (HECs) for these studies. The resulting HEC_99_ values were 0.033 ppm based on thymus weight and 0.0037 ppm based on fetal heart malformations. The HEC_99_ of 0.033 ppm for thymus weight was divided by a total uncertainty factor of 100 (to account for use of a LOAEL and to account for species extrapolation and human variability using a PBPK model); the resulting candidate chronic RfC was 0.00033 ppm. The HEC_99_ of 0.0037 ppm for fetal heart malformations was divided by a total uncertainty factor of 10 (to account for species extrapolation and human variability using a PBPK model); the resulting candidate chronic RfC was 0.00037 ppm. EPA (2011e) selected the midpoint value of the studies (0.0004 ppm, rounded up from 0.00035 ppm) as the chronic RfC for trichloroethylene. ATSDR agreed that this was a reasonable approach. The resulting chronic-duration inhalation MRL is 0.0004 ppm.

Keil et al. (2009)

[underlined: Reference]: Keil DE, Peden-Adams MM, Wallace S, . 2009. Assessment of trichloroethylene (TCE) exposure in murine strains genetically-prone and non-prone to develop autoimmune disease. J Environ Sci Health A Tox Hazard Subst Environ Eng 44(5):443–453.19241258

[underlined: Experimental design]: Groups of 9-week-old female B6C3F1 mice (9–10/group) were administered trichloroethylene in the drinking water at 0, 1,400, or 14,000 ppb (1.4 or 14 ppm) in 1% emulphor vehicle for 30 weeks. During the exposure period, serum levels of total IgG and autoantibodies (anti-ssDNA, -dsDNA, and -glomerular antigen [GA]) were monitored. Body weights were recorded 1 day prior to the initiation of trichloroethylene exposure and again at exposure termination. At sacrifice, the spleen, thymus, liver, and kidneys were weighed. Spleen and thymus were processed for assessment of cell counts and activity. Kidneys were processed for histopathologic evaluation; renal pathology was scored by grading glomerular inflammation, crescent formation, and necrosis in histopathology slides.

[underlined: Effect noted in study and corresponding doses]: Decreased thymus weight (30% lower than controls) and increased serum levels of IgG and selected autoantibodies at 1.4 ppm trichloroethylene in the drinking water (EPA-estimated dose of 0.35 mg/kg/day).

[underlined: Dose and end point used for MRL derivation]: A PBPK model was used to calculate the idPOD (idPOD=0.139 mg trichloroethylene metabolized/kg^3/4^/day) from the applied dose LOAEL of 0.35 mg/kg/day. The mouse idPOD was converted to a HEC_99_ (HEC_99_=0.033 ppm) for lifetime continuous exposure derived from combined interspecies, intraspecies, and route-to-route extrapolation using the PBPK model for trichloroethylene.

[ ] NOAEL [ ] LOAEL [X] HEC_99_

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 3.16 for extrapolation from animals to humans because a PBPK model was used
- [X] 3.16 for human variability because a PBPK model was used to characterize human toxicokinetic variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? EPA estimated doses using the average of subchronic and chronic reference values for generic body weight and water consumption rates for female B6C3F1 mice.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

Johnson et al. (2003)

[underlined: Reference]: Johnson PD, Goldberg SY, Mays MZ, . 2003. Threshold of trichloroethylene contamination in maternal drinking waters affecting fetal heart development in the rat. Environ Health Perspect 111(3):289–292.12611656

[underlined: Experimental design]: Groups of pregnant Sprague-Dawley rats (9–13/exposure level) were administered trichloroethylene in the drinking water throughout gestation (GDs 1–22) at concentrations of 0, 0.0025, 0.25, 1.5, or 1,000 ppm. At termination on GD 22, dams and fetuses were examined for gross abnormalities and fetuses were weighed, measured for crown-rump length, and sexed. Fetal hearts and great vessels were examined for gross malformations and prepared for histopathologic evaluations.

[underlined: Effect noted in study and corresponding doses]: Increased incidences of fetuses with cardiac malformations at maternal exposure levels ≥0.25 ppm (estimated maternal doses ≥0.048 mg/kg/day).

[underlined: Dose and end point used for MRL derivation]: Using a benchmark response (BMR) of 1% extra risk that was preferred due to accounting for intralitter effects using a nested model, and pups being the unit of measure, EPA (2011e) calculated a rat lower 95% confidence limit on the benchmark dose (BMDL_01_) of 0.0207 mg/kg/day from the fetal heart malformation incidence data. The highest dose group (1,000-fold higher than next highest) was dropped to improve model fit. The rat BMDL_01_ was 0.0207 mg/kg/day. A PBPK model was used to calculate the idPOD of 0.0142 mg trichloroethylene metabolized by oxidation/kg body weight^3/4^/day. The rat idPOD was converted to a HEC_99_ of 0.0037 ppm for continuous lifetime exposure derived from route-to-route extrapolation and combined interspecies and intraspecies extrapolation using the PBPK model.

[ ] NOAEL [ ] LOAEL [X] HEC_99_

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3.16 for extrapolation from animals to humans because a PBPK model was used
- [X] 3.16 for human variability because a PBPK model was used to characterize human toxicokinetic variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Studies in humans and animals have identified a number of potential targets of trichloroethylene toxicity, including the central nervous system, liver, kidney, immune system, male reproductive system, and the developing fetus. The toxicity of trichloroethylene does not appear to be route-specific; similar effects have been observed following inhalation and oral exposure. The most sensitive toxicity targets appear to be the immune system, the developing fetus, and the kidneys. Immunological effects include alterations in thymus weight and immune function. Decreases in thymus weights were observed in mice exposed to 0.35 mg/kg/day trichloroethylene in drinking water for 30 weeks (Keil et al. 2009) and an impaired response to SRBCs and delayed hypersensitivity were observed in the pups of mice exposed to 0.37 mg/kg/day trichloroethylene in drinking water on GDs 0–21 and for 3 or 8 weeks postpartum (Peden-Adams et al. 2006). At higher doses, other studies have reported increases in splenic lymphocytes (Blossom and Doss 2007) and impaired immune function (Blossom et al. 2008; Sanders et al. 1982). Developmental toxicity studies have demonstrated a number of effects including increases in the occurrence of cardiac malformations in the offspring of rats exposed to 0.048 mg/kg/day trichloroethylene on GDs 0–21 (Johnson et al. 2003) or 0.218 mg/kg/day trichloroethylene in drinking water prior to mating and during gestation (Dawson et al. 1993; Johnson et al. 1998); at higher doses, neurobehavioral effects, decreases in pup body weight, and perinatal mortality have been observed (Manson et al. 1984; NTP 1986; Taylor et al. 1985). Observed renal effects include toxic nephropathy in rats administered via gavage 500 mg/kg trichloroethylene 5 days/week for 2 years (NTP 1988).

EPA employed a PBPK model to calculate an idPOD for plausible internal dose-metrics based on present understanding of the role different trichloroethylene metabolites play in trichloroethylene toxicity and the mode of action for toxicity. The PBPK model was used to estimate interspecies and intraspecies pharmacokinetic variability and resulted in HEC_99_ values for candidate critical effects.

[underlined: Agency Contact (Chemical Manager)]: G. Daniel Todd, Ph.D.

## Trichloroethylene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Trichloroethylene
CAS Numbers: | 79-01-6
Date: | June 2019
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 54, 56, 69
Species: | Mouse, Rat

[underlined: Minimal Risk Level]: 0.0005 [X] mg/kg/day [ ] ppm

The ATSDR chronic-duration oral MRL of 0.0005 mg/kg/day for trichloroethylene was adopted as the ATSDR intermediate-duration oral MRL (see chronic-duration oral MRL worksheet for more information). The ATSDR chronic-duration oral MRL is based, in part, on results of PBPK modeling exercises that simulated 100 weeks of exposure for humans (EPA 2011e). Sample simulations for a 52-week exposure (within the range of an ATSDR-defined intermediate-duration exposure [15–364 days]) resulted in the same idPOD as the idPOD resulting from simulations for the 100-week exposure.

[underlined: Agency Contact (Chemical Manager)]: G. Daniel Todd, Ph.D.

## Trichloroethylene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Trichloroethylene
CAS Numbers: | 79-01-6
Date: | June 2019
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 54, 56, 69
Species: | Mouse, Rat

[underlined: Minimal Risk Level]: 0.0005 [X] mg/kg/day [ ] ppm

The chronic-duration oral MRL is based on the results of three critical oral exposure studies that reported immunotoxicity (decreased plaque-forming cell response and increased delayed-type hypersensitivity) in mice (Peden-Adams et al. 2006), decreased thymus weight in female mice (Keil et al. 2009), and fetal heart malformations in rats (Johnson et al. 2003). In the EPA assessment for trichloroethylene (EPA 2011e), independent candidate chronic RfD values were calculated for each of these effects. The Peden-Adams et al. (2006) immunotoxicity LOAEL of 0.37 mg/kg/day was divided by a total uncertainty factor of 1,000 (to account for use of a LOAEL, interspecies extrapolation, and human variability), resulting in a candidate chronic RfD of 0.00037 mg/kg/day. The Keil et al. (2009) thymus weight LOAEL of 0.35 mg/kg/day was used to derive a PBPK model-based human equivalent dose (HED_99_) of 0.048 mg/kg/day, which was divided by a total uncertainty factor of 100 (to account for use of a LOAEL, interspecies extrapolation, and human variability using a PBPK model), resulting in a candidate chronic RfD of 0.00048 mg/kg/day. The Johnson et al. (2003) fetal heart malformation data were subjected to benchmark dose analysis. The resulting BMDL_01_ (1% extra risk) of 0.0207 mg/kg/day was used to calculate a PBPK model-based HED_99_ of 0.0051 mg/kg/day, which was divided by a total uncertainty factor of 10 (to account for interspecies extrapolation and human variability using a PBPK model). The resulting candidate chronic RfD was 0.00051 mg/kg/day. EPA (2011e) elected to use a chronic RfD value of 0.0005 mg/kg/day and noted that this value was supported by results for multiple effects. ATSDR agreed that this was a reasonable approach. Therefore, the chronic-duration oral MRL is 0.0005 mg/kg/day.

Peden-Adams et al. (2006)

[underlined: Reference]: Peden-Adams MM, Eudaly JG, Heesemann LM, . 2006. Developmental immunotoxicity of trichloroethylene (TCE): studies in B6C3F1 mice. J Environ Sci Health A Tox Hazard Subst Environ Eng 41(3):249–271.16484062

[underlined: Experimental design]: Groups of C3H/HeJ male and C57BL/6N female mice (5/sex/group) were administered trichloroethylene in the drinking water at 0, 1.4, or 14 ppm, beginning at pairing (1:1) and continuing for 7 days of mating and throughout gestation (at least for the dams) and lactation. Pups (strain B6C3F1 is produced from the paired parental strains) were evaluated for body length (crown-rump), and timing of eye opening and ear unfolding. At weaning of the pups at 3 weeks of age, 5–7 pups/treatment group, were weighed and sacrificed to assess kidney, liver, thymus, and spleen weights. Trichloroethylene-related effects on the immune system were assessed by measuring splenic lymphocyte proliferation, NK cell activity, SRBC-specific IgM production (PFC response), splenic B220+ cells, and thymic and splenic T-cell immunophenotypes. The remaining pups (4–5 pups/treatment group) were assessed at 8 weeks of age in a manner similar to those assessed at 3 weeks of age, with additional assessments of autoantibodies to dsDNA and delayed type hypersensitivity response (indicated by foot pad swelling following subcutaneous injection of SRBC).

[underlined: Effect noted in study and corresponding doses]: Decreased PFC response was observed in 3- and 8-week-old pups and increased delayed-type sensitivity was noted in 8-week-old pups at 1.4 and 14 ppm trichloroethylene in the drinking water (author-estimated maternal doses of 0.37 and 3.7 mg/kg/day, respectively).

[underlined: Dose and end point used for MRL derivation]: 0.37 mg/kg/day for decreased PFC response and increased delayed-type sensitivity.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 10 to account for extrapolation from animals to humans
- [X] 10 to account for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Doses were estimated by the study authors.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

Keil et al. (2009)

[underlined: Reference]: Keil DE, Peden-Adams MM, Wallace S, . 2009. Assessment of trichloroethylene (TCE) exposure in murine strains genetically-prone and non-prone to develop autoimmune disease. J Environ Sci Health A Tox Hazard Subst Environ Eng 44(5):443–453.19241258

[underlined: Experimental design]: Groups of 9-week-old female B6C3F1 mice (9–10/group) were administered trichloroethylene in the drinking water at 0, 1,400, or 14,000 ppb (1.4 or 14 ppm) in 1% emulphor vehicle for 30 weeks. During the exposure period, serum levels of total IgG and autoantibodies (anti-ssDNA, -dsDNA, and -GA) were monitored. Body weights were recorded 1 day prior to the initiation of trichloroethylene exposure and again at exposure termination. At sacrifice, the spleen, thymus, liver, and kidneys were weighed. Spleen and thymus were processed for assessment of cell counts and activity. Kidneys were processed for histopathologic evaluation; renal pathology was scored by grading glomerular inflammation, crescent formation, and necrosis in histopathology slides.

[underlined: Effect noted in study and corresponding doses]: Decreased thymus weight (30% lower than controls) and increased serum levels of IgG and selected autoantibodies at 1.4 ppm trichloroethylene in the drinking water (EPA-estimated dose of 0.35 mg/kg/day).

[underlined: Dose and end point used for MRL derivation]: A PBPK model was used to calculate the idPOD (idPOD=0.139 mg trichloroethylene metabolized/kg^3/4^/day) from the applied dose LOAEL of 0.35 mg/kg/day. The mouse idPOD was converted to a HED_99_ of 0.048 mg/kg/day for lifetime continuous exposure derived from combined interspecies and intraspecies extrapolation using the PBPK model for trichloroethylene.

[ ] NOAEL [ ] LOAEL [X] HED_99_

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 3.16 for extrapolation from animals to humans because a PBPK model was used
- [X] 3.16 for human variability because a PBPK model was used to characterize human toxicokinetic variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? EPA estimated doses using the average of subchronic and chronic reference values for generic body weight and water consumption rates for female B6C3F1 mice.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

Johnson et al. (2003)

[underlined: Reference]: Johnson PD, Goldberg SY, Mays MZ, . 2003. Threshold of trichloroethylene contamination in maternal drinking waters affecting fetal heart development in the rat. Environ Health Perspect 111(3):289–292.12611656

[underlined: Experimental design]: Groups of pregnant Sprague-Dawley rats (9–13/exposure level) were administered trichloroethylene in the drinking water throughout gestation (GDs 1–22) at concentrations of 0, 0.0025, 0.25, 1.5, or 1,000 ppm. At termination on GD 22, dams and fetuses were examined for gross abnormalities and fetuses were weighed, measured for crown-rump length, and sexed. Fetal hearts and great vessels were examined for gross malformations and prepared for histopathologic evaluations.

[underlined: Effect noted in study and corresponding doses]: Increased incidences of fetuses with cardiac malformations at maternal exposure levels ≥0.25 ppm (estimated maternal doses ≥0.048 mg/kg/day).

[underlined: Dose and end point used for MRL derivation]: Using a BMR of 1% extra risk that was preferred due to accounting for intralitter effects using a nested model, and pups being the unit of measure, EPA (2011e) calculated a rat BMDL_01_ of 0.0207 mg/kg/day from the fetal heart malformation incidence data. The highest dose group (1,000-fold higher than next highest) was dropped to improve model fit. The rat BMDL_01_ was 0.0207 mg/kg/day. A PBPK model was used to calculate the idPOD of 0.0142 mg trichloroethylene metabolized by oxidation/kg body weight^3/4^/day. The rat idPOD was converted to a HED_99_ of 0.0051 mg/kg/day for continuous lifetime exposure derived from combined interspecies and intraspecies extrapolation using the PBPK model for trichloroethylene.

[ ] NOAEL [ ] LOAEL [X] HED_99_

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3.16 for extrapolation from animals to humans because a PBPK model was used
- [X] 3.16 for human variability because a PBPK model was used to characterize human toxicokinetic variation

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Studies in humans and animals have identified a number of potential targets of trichloroethylene toxicity including the central nervous system, liver, kidney, immune system, male reproductive system, and the developing fetus. The toxicity of trichloroethylene does not appear to be route-specific; similar effects have been observed following inhalation and oral exposure. The most sensitive toxicity targets appear to be the immune system, the developing fetus, and the kidneys. Immunological effects include alterations in thymus weight and immune function. Decreases in thymus weights were observed in mice exposed to 0.35 mg/kg/day trichloroethylene in drinking water for 30 weeks (Keil et al. 2009) and an impaired response to SRBCs and delayed hypersensitivity were observed in the pups of mice exposed to 0.37 mg/kg/day trichloroethylene in drinking water on GDs 0–21 and for 3 or 8 weeks postpartum (Peden-Adams et al. 2006). At higher doses, other studies have reported increases in splenic lymphocytes (Blossom and Doss 2007) and impaired immune function (Blossom et al. 2008; Sanders et al. 1982). Developmental toxicity studies have demonstrated a number of effects including increases in the occurrence of cardiac malformations in the offspring of rats exposed to 0.048 mg/kg/day trichloroethylene on GDs 0–21 (Johnson et al. 2003) or 0.218 mg/kg/day trichloroethylene in drinking water prior to mating and during gestation (Dawson et al. 1993; Johnson et al. 1998); at higher doses, neurobehavioral effects, decreases in pup body weight, and perinatal mortality have been observed (Manson et al. 1984; NTP 1986; Taylor et al. 1985). Observed renal effects include toxic nephropathy in rats administered via gavage 500 mg/kg trichloroethylene 5 days/week for 2 years (NTP 1988).

EPA employed a PBPK model to calculate an idPOD for plausible internal dose-metrics based on present understanding of the role different trichloroethylene metabolites play in trichloroethylene toxicity and the mode of action for toxicity. The PBPK model was used to estimate interspecies and intraspecies pharmacokinetic variability and resulted in HED_99_ values for candidate critical effects.

[underlined: Agency Contact (Chemical Manager)]: G. Daniel Todd, Ph.D.