# CHAPTER 8 REFERENCES

Albano E, Tomasi A, Cheeseman KH, . 1985. Use of isolated hepatocytes for the detection of free radical intermediates of halogenated hydrocarbons. In: Proceedings of the Free Radicals Liver Injury International Meeting. Oxford, England: IRL Press Limited, 7–16.
Archer WL. 1979. Other chloroethanes. In: Kirk-Othmer Encyclopedia of chemical technology. 3^rd^ ed. New York, NY: Wiley-Interscience, 722–742.
Ashworth RA, Howe GB, Mullins ME, . 1988. Air-water partitioning coefficients of organics in dilute solutions. J Hazard Mater 18:25–36. 10.1016/0304-3894(88)85057-X.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634. https://www.govinfo.gov/content/pkg/FR-1989-09-11/pdf/FR-1989-09-11.pdf. August 13, 2020.
ATSDR. 2019. 1,1,2-Trichloroethane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Barber ED, Donish WH. 1982. An exposure system for quantitative measurements of the microbial mutagenicity of volatile liquids. Environ Sci Res 25:3–18. 10.1007/978-1-4613-3455-2_2.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Bauer U. 1981a. [Human exposure to environmental chemicals: Studies on volatile organic halogenated compounds in water, air, food and human tissues, III. Results of studies]. Zentralbl Bakteriol Mikrobiol Hyg B 174:200–237. (German)7331583
Bauer U. 1981b. [Human exposure to environmental chemicals: Investigations on volatile organic halogenated compounds in water, air, food and human tissues: IV. Calculation of human exposure to organic halogenated compounds from the environment]. Zentralbl Bakteriol Mikrobiol Hyg B 174:556–583. (German)7342577
Beck MJ. 2004. An acute neurotoxicity study of 1,1,2-trichloroethane in rats. WIL Research Laboratories, Inc. WIL-417004. EPA-HQ-OPPT-2002-0056-0100 through EPA-HQ-OPPT-2002-0056-0108. https://www.regulations.gov/docketBrowser?rpp=25&so=DESC&sb=commentDueDate&po=0&dct=SR&D=EPA-HQ-OPPT-2002-0056. March 07, 2018.
Bernauer U, Birner G, Dekant W, . 1996. Biotransformation of trichloroethene: Dose-dependent excretion of 2,2,2-trichloro-metabolites and mercapturic acids in rats and humans after inhalation. Arch Toxicol 70(6):338–346. 10.1007/s002040050283.8975632
Bonnet P, Francin JM, Gradiski D, . 1980. [Determination of the median lethal concentration of principle chlorinated aliphatic hydrocarbons in the rat]. Arch Mal Prof Med Trav Secur Soc 41:317–321. (French)
Borzelleca JF. 1983. A review of volatile organic contaminant data. Proc AWWA Water Qual Technol Conf 225:244.
Bouwer EJ, McCarty PL. 1983. Transformation of 1- and 2-carbon halogenated aliphatic organic compounds under methanogenic conditions. Appl Environ Microbiol 45:1286–1294.6859849
Brender JD, Shinde MU, Zhan FB, . 2014. Maternal residential proximity to chlorinated solvent emissions and birth defects in offspring: A case-control study. Environ Health 13:96. 10.1186/1476-069X-13-96.25406847
Brodzinsky RSHB. 1982. Volatile organic chemicals in the atmosphere. An assessment of available data. Menlo Park, CA: SRI International. 98–99.
Bronzetti G, Galli A, Vellosi R, . 1987. [Genetic activity of chlorinated ethanes]. Eur J Cancer Clin Oncol 23:1737–1738. (French)
Carlson GP. 1973. Effect of phenobarbital and 3-methylcholanthrene pretreatment on the hepatotoxicity of 1,1,1-trichloroethane and 1,1,2-trichloroethane. Life Sci 13(1):67–73. 10.1016/0024-3205(73)90278-6.4356632
Carpenter CP, Smyth HF, Pozzani UC. 1949. The assay of acute vapor toxicity, and the grading and interpretation of results on 96 chemical compounds. J Ind Hyg Toxicol 31(6):343–346.15407114
CAS. 1988. CAS Registry File. Computer Printout.
CDC. 2017. Fourth national report on human exposure to environmental chemicals. Updated tables, January 2017, Volume one. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/biomonitoring/pdf/fourthreport_updatedtables_volume1_jan2017.pdf. August 13, 2020.
CDR. 2016. Chemical data reporting: 1,1,2-Trichloroethane. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. August 12, 2020.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
Comba ME, Kaiser KLE. 1983. Determination of volatile contaminants at the ng I^−1^ level in water by capillary gas chromatography with electron capture detection. Int J Anal Chem 16:17–31. 10.1080/03067318308078346.
Cramer PH, Boggess KE, Hosenfeld JM, . 1988. Determination of organic chemicals in human whole blood: Preliminary method development for volatile organics. Bull Environ Contam Toxicol 40(4):612–618. 10.1007/BF01688388.3370355
Crebelli R, Benigni R, Franekic J, . 1988. Induction of chromosome malsegregation by halogenated organic solvents in Aspergillus nidulans: Unspecific or specific mechanism? Mutat Res 201(2):401–411. 10.1016/0027-5107(88)90027-9.3050490
Crebelli R, Carere A, Leopardi P, . 1999. Evaluation of 10 aliphatic halogenated hydrocarbons in the mouse bone marrow micronucleus test. Mutagenesis 14(2):207–215. 10.1093/mutage/14.2.207.10229923
de Ceaurriz J, Bonnet P, Certin C, . 1981. [Chemicals as central nervous system depressants. Benefits of an animal model]. Cah Notes Doc 104:351–355. (French)
DeMarini DM, Brooks HG. 1992. Induction of prophage lambda by chlorinated organics: Detection of some single-species/single-site carcinogens. Environ Mol Mutagen 19(2):98–111. 10.1002/em.2850190204.1531793
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Doherty AT, Ellard S, Parry EM, . 1996. An investigation into the activation and deactivation of chlorinated hydrocarbons to genotoxins in metabolically competent human cells. Mutagenesis 11(3):247–274. 10.1093/mutage/11.3.247.8671747
Dosemeci M, Cocco P, Chow WH. 1999. Gender differences in risk of renal cell carcinoma and occupational exposures to chlorinated aliphatic hydrocarbons. Am J Ind Med 36(1):54–59. 10.1002/(sici)1097-0274(199907)36:1<54::aid-ajim8>3.0.co;2-0.10361587
Duprat P, Delsaut L, Gradiski D. 1976. [Irritating power of the principal aliphatic chloride solvents on the skin and ocular mucosa of the rabbit]. Eur J Toxicol Environ Hyg 9:171–177. (French)954854
Edelman P, Osterloh J, Pirkle J, . 2003. Biomonitoring of chemical exposure among New York City firefighters responding to the World Trade Center fire and collapse. Environ Health Perspect 111(16):1906–1911. 10.1289/ehp.6315.14644665
EPA. 1975. Preliminary assessment of suspected carcinogens in drinking water Report to Congress. Washington, DC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91012F6P.txt. August 13, 2020.
EPA. 1977. Industrial process profile for environmental use: Chapter 6 - The industrial organic chemicals industry. Cincinnati, OH: U.S. Environmental Protection Agency. PB281478. EPA600277023f.
EPA. 1980a. Survey of the Huntington and Philadelphia River water supplies for purgeable organic contaminants. Annapolis, MD: U.S. Environmental Protection Agency. EPA903981003. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20007ZCV.txt. August 13, 2020.
EPA. 1980b. Ambient water quality criteria for chlorinated ethanes. Washington, DC: U.S. Environmental Protection Agency. EPA440580029. https://www.epa.gov/wqc/ambient-water-quality-criteria-chlorinated-ethanes. August 13, 2020.
EPA. 1981. Treatability manual. Washington, DC: U.S. Environmental Protection Agency. EPA600282001A.
EPA. 1982a. Fate of priority pollutants in publicly owned treatment works. Final Report. Volume 1. Washington, DC: U.S. Environmental Protection Agency. EPA440182303. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=000012HL.txt. August 14, 2020.
EPA. 1982b. Test methods for evaluating solid waste. Physical/chemical methods. Method No. 5030. Washington, DC: U.S. Environmental Protection Agency. SW-846. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2001746A.txt. August 14, 2020.
EPA. 1986a. Test Methods for evaluating solid waste. Laboratory manual Physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency. Vol. 1B, SW-846.
EPA. 1986b. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Volume 1 - Executive Summary. Washington, DC: U.S. Environmental Protection Agency. EPA560586035.
EPA. 1987a. U.S. EPA Contract Laboratory Program statement of work for organic analysis. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1988a. Integrated Risk Information System (IRIS). Risk estimate for carcinogenicity for 1,1,2-trichloroethane. Cincinnati, OH: U.S. Environmental Protection Agency.
EPA. 1988b. National Ambient Volatile Organic Compounds (VOCs). Data base update. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB88195631. EPA600388010. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88195631.xhtml. August 13, 2020.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001K4C.txt. August 13, 2020.
EPA. 2001. Occurrence of unregulated contaminants in public water systems: An initial assessment. Washington, DC: U.S. Environmental Protection Agency. EPA815P00001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1005ONL.txt. August 13, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). Washington, DC: U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. August 13, 2020.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2010. The analysis of regulated contaminant occurrence data from public water systems in support of the second six-year review of national primary drinking water regulations. U.S. Environmental Protection Agency. EPA815B09006.
EPA. 2014. National Emissions Inventory (NEI): 1,1,2-Trichloroethane. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2014-national-emissions-inventory-nei-data. August 13, 2020.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2020a. Draft scope of the risk evaluation for 1,1,2-trichloroethane. U.S. Environmental Protection Agency. EPA740D20003. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100YZ04.txt. August 13, 2020.
EPA. 2020b. Non-confidential 2016 Chemical Data Reporting information on chemical production and use in the United States. U.S. Environmental Protection Agency. https://chemview.epa.gov/chemview. August 13, 2020.
EPA. 2020c. Use report for 1,1,2-trichloroethane (CAS RN 79-00-5). U.S. Environmental Protection Agency.
EPA. 2020d. Air Quality System (AQS) annual summary: 1,1,2-Trichloroethane. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html. August 13, 2020.
FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2020. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Foureman P, Mason JM, Valencia R, . 1994. Chemical mutagenesis testing in Drosophila. IX. Results of 50 coded compounds tested for the National Toxicology Program. Environ Mol Mutagen 23(1):51–63. 10.1002/em.2850230109.8125083
Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98(1):87–99. 10.1016/0041-008x(89)90137-3.2929023
Gehring PJ. 1968. Hepatotoxic potency of various chlorinated hydrocarbon vapours relative to their narcotic and lethal potencies in mice. Toxicol Appl Pharmacol 13:287–298. 10.1016/0041-008X(68)90102-6.5726658
Gradiski D, Bonnet P, Raoult G, . 1978. [Comparative acute inhalation toxicity of the principal chlorinated aliphatic solvents]. Arch Mal Prof Med Trav Secur Soc 39:249–257. (French)
Green T, Dow J, Ellis MK, . 1997. The role of glutathione conjugation in the development of kidney tumours in rats exposed to trichloroethylene. Chem Biol Interact 105(2):99–117. 10.1016/s0009-2797(97)00040-9.9251723
Greenberg M, Anderson R, Keene J, . 1982. Empirical test of the association between gross contamination of wells with toxic substances and surrounding land use. Environ Sci Technol 16:14–19. 10.1021/es00095a007.
Grimsrud EP, Rasmussen RA. 1975. Survey and analysis of halocarbons in the atmosphere by gas chromatography-mass spectrometry. Atmos Environ 9:1014–1017. 10.1016/0004-6981(75)90022-0.
Gupta KC, Ulsamen AG, Gammage R. 1984. Volatile organic compounds in residential air Levels, sources and toxicity. In: 77th Annual Meeting Air Pollution Control Association. Pittsburgh, PA: Air Pollution Control Association,
Hallen RT, Pyne JW, Molton PM. 1986. Transformation of chlorinated ethenes and ethanes by anaerobic microorganisms (Abstract). In: Division of Environmental Chemistry, American Chemical Society. 192nd Annual Meeting. Anaheim, CA: American Chemical Society, 344–346.
Hanasono GK, Witschi H, Plaa GL. 1975. Potentiation of the hepatotoxic responses to chemicals in alloxan-diabetic rats. Exp Biol Med 149(4):903–907. 10.3181/00379727-149-38924.
Harkov R, Kebbekus B, Bozzelli JW. 1987. Volatile organic compounds at urban sites in New Jersey. In: Lioy PJ, Daisey JM, eds. Toxic air pollutants. Chelsea, MI: Lewis Publishers Inc, 69–88.
Harkov R, Kebbekus B, Bozzelli JW, . 1983. Measurement of selected volatile organic compounds at three locations in New Jersey during the summer season. J Air Pollut Control Assoc 33:1177–1183. 10.1080/00022470.1983.10465709.
Hawley GG. 1981. 1,1,2-Trichloroethane. In: Hawley’s Condensed chemical dictionary. 10^th^ ed. New York, NY: Van Nostrand Reinhold Co, 1041.
Heikes DL, Jensen SR, Fleming-Jones ME. 1995. Purge and trap extraction with GC-MS determination of Volatile Organic Compounds in table-ready foods. J Agric Food Chem 43(11):2869–2875. 10.1021/jf00059a018.
Henschler D, Reichert D, Metzler M. 1980. Identification of potential carcinogens in technical grade 1,1,1-trichloroethane. Int Arch Occup Environ Health 47(3):263–268. 10.1007/BF00381683.7461852
IARC. 1999. 1,1,2-Trichloroethane. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 71. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol71/mono71-55.pdf. November 21, 2017.
Ikeda M, Ohtsuji H. 1972. A comparative study of the excretion of Fujiwara reaction-positive substances in urine of humans and rodent given trichloro- or tetrachloro-derivatives of ethane and ethylene. Br J Ind Med 29:99–104. 10.1136/oem.29.1.99.5060252
IOM. 2010. Summary. In: Micheel CM, Ball JR, eds. Evaluation of biomarkers and surrogate endpoints in chronic disease. Washington, DC: The National Academies Press, 1–16. 10.17226/12869.
IRIS. 2003. 1,1,2-Trichloroethane. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0198_summary.pdf. November 21, 2017.
Isnard P, Lambert S. 1988. Estimated bioconcentration factors from octanol-water partition coefficient and aqueous solubility. Chemosphere 17:21–34. 10.1016/0045-6535(88)90040-9.
Ivanetich KM, Van Den Honert LH. 1981. Chloroethanes: Their metabolism by hepatic cytochrome P- 450 in vitro. Carcinogenesis 2:697–702. 10.1093/carcin/2.8.697.7285278
Jackson DR, Garrett BC, Bishop TA. 1984. Comparison of batch and column methods for assessing leachability of hazardous waste. Environ Sci Technol 18:668–673. 10.1021/es00127a007.
Jakobson I, Holmberg B, Wahlberg JE. 1977. Variations in the blood concentration of 1,1,2-trichloroethane by percutaneous absorption and other routes of administration in the guinea pig. Acta Pharmacol Toxicol (Copenh) 41 (5):497–506. 10.1111/j.1600-0773.1977.tb02161.x.579560
Jensen S, Rosenberg R. 1975. Degradability of some chlorinated aliphatic hydrocarbons in sea water and sterilized water. Water Res 9:659–661. 10.1016/0043-1354(75)90173-6.
Jeong KM, Hsu KJ, Jeffries JB, . 1984. Kinetics of the reactions of hydroxyl with ethane, 1,1,1-trichloroethane, 1,1,2-trichloroethane, 1,1-difluoro-1,2-dichloroethane, and 1,1,1,2-tetrafluoroethane. J Phys Chem 88:1222–1226. 10.1021/j150650a041.
Kaiser KLE, Comba ME. 1986. Volatile halocarbon contaminant survey of the St. Clair River. Water Pollut Res J Can 21:323–331. 10.2166/wqrj.1986.028.
Kallman MJ, Kaempf GL. 1984. Efficacy of choice testing to predict chronic ingestion of drinking solutions adulterated with chemicals. Pharmacol Biochem Behav 20(2):195–200. 10.1016/0091-3057(84)90241-7.6718447
Kallman MJ, Lynch MR, Landauer MR. 1983. Taste aversions to several halogenated hydrocarbons. Neurobehav Toxicol Teratol 5:23–27.6856006
Kawasaki M. 1980. Experiences with the test scheme under the chemical control law of Japan: An approach to structure-activity correlations. Ecotoxicol Environ Saf 4(4):444–454. 10.1016/0147-6513(80)90046-9.7472248
King L, Sherbin G. 1986. Point sources of toxic organics to the upper St. Clair River. Water Pollut Res J Can 21:433–446. 10.2166/wqrj.1986.038.
Kirkpatrick DT. 2001. Acute inhalation toxicity (with histopathology) study of 1,1,2-trichloroethane (1,1,2-TCE) in rats. WIL Research Laboratories, Inc. HAP Task Force. WIL-417001. EPA-HQ-OPPT-2002-0056-0039. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0056-0039.
Kirkpatrick DT. 2002. A 90-day inhalation toxicity study of 1,1,2-trichloroethane (1,1,2-TCE) in rats (with satellite groups for pharmacokinetic evaluations in rats and mice). WIL Research Laboratories, Inc. HAP Task Force. WIL-417002. EPA-HQ-OPPT-2002-0046-0003. https//www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0046-0003. March 07, 2018.
Klaassen CD, Plaa GL. 1966. Relative effects of various chlorinated hydrocarbons on liver and kidney function in mice. Toxicol Appl Pharmacol 9:139–151. 10.1016/0041-008X(66)90038-X.5967557
Klecka GM, Gonsior SJ. 1983. Nonenzymatic reductive dechlorination of chlorinated methanes and ethanes in aqueous solution. Dow Chemical. Report ES-645.
Kluwe WM, McCormack KM, Hook JB. 1978. Potentiation of hepatic and renal toxicity of various compounds by prior exposure to polybrominated biphenyls. Environ Health Perspect 23:241–246. 10.1289/ehp.7823241.209982
Konietzko H. 1984. Chlorinated ethanes: Sources, distribution, environmental impact and health effects. Hazard Assess Chem: Curr Dev 3:401–448.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kronevi T, Wahlberg J, Holmberg B. 1977. Morphological lesions in guinea pigs during skin exposure to 1,1,2-trichloroethane. Acta Pharmacol Toxicol (Copenh) 41(4):298–305. 10.1111/j.1600-0773.1977.tb02669.x.579060
Lazarew NW. 1929. Uber die narkotsche Wirkungskraft der Dampfe der chlorderivaten des methans, des Athans und des Anthylens. Arch Exp Pathol Pharmacol 141:19–24. (German)
Lioy PJ, Atherholt T, Bozzelli J, . 1983. The New Jersey project on Airborne Toxic Elements and Organic Substances (ATEOS): A summary of the 1981 summer and 1982 winter studies. J Water Pollut Control Fed 33:649–657. 10.1080/00022470.1983.10465621.
Lorah MM, Voytek MA. 2004. Degradation of 1,1,2,2-tetrachloroethane and accumulation of vinyl chloride in wetland sediment microcosms and in situ porewater: Biogeochemical controls and associations with microbial communities. J Contam Hydrol 70(1–2):117–145. 10.1016/j.jconhyd.2003.08.010.15068871
Mabey WR, Barich V, Mill T. 1983. Hydrolysis of polychlorinated alkanes. In: Symp Amer Chem Soc Div Environ Chem 186th Natl Mtg. Washington, DC: American Chemical Society, 359–361.
MacDonald JR, Gandolfi AJ, Sipes IG. 1982. Acetone potentiation of 1,1,2-trichloroethane hepatotoxicity. Toxicol Lett 13(1–2):57–69. 10.1016/0378-4274(82)90139-4.7179309
Maurissen JP, Andrus AK, Johnson KA, . 2005. 1,1,2-Trichloroethane: Subchronic neurotoxicity study in F344/DUCRL rats. Parts 1-4. Dow Chemical Company. Study ID: 041056. EPA-HQ-OPPT-2002-0046-0013 through EPA-HQ-OPPT-2002-0046-0016. https://www.regulations.gov/docketBrowser?rpp=25&so=DESC&sb=commentDueDate&po=0&dct=SR&D=EPA-HQ-OPPT-2002-0046. August 14, 2020.
Mazzullo M, Colacci A, Grilli S, . 1986. 1,1,2-Trichloroethane: Evidence of genotoxicity from short-term tests. Jpn J Cancer Res 77(6):532–539.2426232
Mersch-Sundermann V. 1989. [Examination of the mutagenicity of organic microcontaminations on the environment. Part II. The mutagenicity of halogenated aliphatic hydrocarbons in the Salmonella-microsome-test (Ames-test) with reference to the contamination of ground and drinking water]. Zentralbl Bakteriol Mikrobiol Hyg B 187:230–243. (German)2494817
Milman HA, Story DL, Riccio ES, . 1988. Rat liver foci and in vitro assays to detect initiating and promoting effects of chlorinated ethanes and ethylenes. Ann N Y Acad Sci 534:521–530. 10.1111/j.1749-6632.1988.tb30143.x.3389679
Mirsalis JC, Tyson CK, Steinmetz KL, . 1989. Measurement of unscheduled DNA synthesis and S-phase synthesis in rodent hepatocytes following in vivo treatment: Testing of 24 compounds. Environ Mol Mutagen 14(3):155–164. 10.1002/em.2850140305.2792091
Mitoma C, Tyson CA, Riccio ES. 1985. Investigation of the species sensitivity and mechanism of crcinogenicity of halogenated hydrocarbons (Final report). SRI International. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0509408. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0509408.xhtml. August 13, 2020.
Mitre. 1987. National priority list technical database. McLean, VA: The Mitre Corporation.
Miyagawa M, Takasawa H, Sugiyama A, . 1995. The in vivo-in vitro replicative DNA synthesis (RDS) test with hepatocytes prepared from male B6C3F1 mice as an early prediction assay for putative nongenotoxic (Ames-negative) mouse hepatocarcinogens. Mutat Res 343(2–3):157–183. 10.1016/0165-1218(95)90082-9.7791810
Molton PM, Hallen RT, Pyne JW. 1987. Study of vinyl chloride formation at landfill sites in California. Richland, WA: Battelle Pacific Northwest Laboratories. PB87161278. Report BNWL-2311206978. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87161279.xhtml. August 28, 2020.
Moody DE, Smuckler EA. 1986. Disturbances in hepatic heme metabolism in rats administered alkyl halides. Toxicol Lett 32(3):209–214. 10.1016/0378-4274(86)90109-8.3775805
Moody DE, James JL, Clawson GA, . 1981. Correlations among the changes in hepatic microsomal components after intoxication with alkyl halides and other hepatotoxins. Mol Pharmacol 20:685–693.6173739
Moolenaar RJ, Olson RD. 1989. Written communication. Comments of the Dow Chemical Company on ATSDR’s Toxicological Profile for 1,1,2-Trichloroethane. Midland, MI: Dow Chemical Company.
Morgan KT. 1991. Approaches to the identification and recording of nasal lesions in toxicology studies. Toxicol Pathol 19(4 Pt 1):337–351. 10.1177/0192623391019004-103.1813980
Morgan A, Black A, Belcher DR. 1970. The excretion in breath of some aliphatic halogenated hydrocarbons following administration by inhalation. Ann Occup Hyg 13:219–233. 10.1093/annhyg/13.4.219.5509094
Morgan A, Black A, Belcher DR. 1972. Studies on the absorption of halogenated hydrocarbons and their excretion in breath using 38 Cl tracer techniques. Ann Occup Hyg 15:273–282. 10.1093/annhyg/15.2-4.273.4648240
Mudder TI, Musterman JL. 1982. Development of empirical structure biodegradability relationships and biodegradability testing protocol for volatile and slightly soluble priority pollutants. In: Presented before the Div Environ Chem Amer Chem Soc. Kansas City, MO: American Chemical Society, 52–53.
Mylchreest E. 2006. 1,1,2-Trichloroethane: Multigeneration reproduction study in rats. Volume 1–5. E.I. du Pont de Nemours and Company. HAP Task Force. DuPont-16013. EPA-HQ-OPPT-2002-0056-0127. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0056-0127. August 14, 2020.
NAS. 2009. Systemic exposures to volatile organic compounds and factors influencing susceptibility to their effects. In: Contaminated water supplies at Camp Lejeune: Assessing potential health effects. Washington, DC: National Academy of Sciences, 74–78.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, 15–35.
NCI. 1978. Bioassay of 1,1,2-trichloroethane for possible carcinogenicity. National Cancer Institute. PB283337. NCICGTR74. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB283337.xhtml. August 13, 2020.
Newsom JM. 1985. Transport of organic compounds dissolved in ground water. Ground Water Monit Rev 5:28–36. 10.1111/j.1745-6592.1985.tb00922.x.
Niklasson M, Tham R, Larsby B, . 1993. Effects of toluene, styrene, trichloroethylene, and trichloroethane on the vestibulo-and opto-oculo motor system in rats. Neurotoxicol Teratol 15(5):327–334. 10.1016/0892-0362(93)90034-l.8277926
NIOSH. 1988. National Occupational Exposure Survey (NOES). Computer printout. National Institute for Occupational Safety and Health.
NIOSH. 1994. 1,1,2-Trichloroethane. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/79005.html. November 21, 2017.
NIOSH. 2019. 1,1,2-Trichloroethane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0628.html. August 10, 2020.
Norpoth K, Heger M, Muller G, . 1988. Investigations on metabolism and carcinogenicity of 1,1,2-trichloroethane. J Cancer Res Clin Oncol 114(2):158–162. 10.1007/BF00417830.3350848
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments- February 2013. National Toxicology Program, U.S. Department of Health and Human Services, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. October 4, 2018.
NTP. 2015. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program, U.S. Department of Health and Human Services, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf. October 4, 2018.
NTP. 2016. CASRN index. In: Report on carcinogens. 14^th^ ed. Research Triangle Park, NC: National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
OSHA. 2019a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15:1475–1481. 10.1021/es00094a008.
Parrish CF. 1983. Solvents, industrial. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 21. 3^rd^ ed. New York, NY: John Wiley and Sons, 377–401.
Pellizzari ED. 1982. Analysis for organic vapor emissions near industrial and chemical waste disposal sites. Environ Sci Technol 16(11):781–785. 10.1021/es00105a010.22299786
Pellizzari ED, Hartwell TD, Harris BS, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28(3):322–328. 10.1007/BF01608515.7082873
Platt DS, Cockrill BL. 1969. Biochemical changes in rat liver in response to treatment with drugs and other agents. II. Effects of halothane, DDT, other chlorinated hydrocarbons, thioacetamide, dimethylnitrosamine and ethionine. Biochem Pharmacol 18(2):445–457. 10.1016/0006-2952(69)90221-4.4305095
Poet TS, Curry TL, Luders TM, . 2001. Final report. Pharmacokinetics of 1,1,2-trichloroethane in rats and mice. Battelle. Submitted to the U.S. Environmental Protection Agency under TSCA. OTS0574377.
Poet TS, Curry TL, Luders TM, . 2003. Amended report. Pharmacokinetics of 1,1,2-trichloroethane in rats and mice. Battelle. EPA HQ-OPPT-200200046.
Pozzani UC, Weil CS, Carpenter CP. 1959. The toxicological basis of Threshold Limit Values: 5. The experimental inhalation of vapor mixtures by rats, with notes up on the relationship between single dose inhalation and single dose oral data. Am Ind Hyg Assoc J 20:364–369. 10.1080/00028895909343733.14434607
Rannug U, Sundvall A, Ramel C. 1978. The mutagenic effect of 1,2-dichloroethane on Salmonella typhimurium I. Activation through conjugation with glutathione in vitro. Chem Biol Interact 20:1–16. 10.1016/0009-2797(78)90076-5.24503
Reddy TV, Chang LW, DeAngelo AB, . 1992. Effect of nongenotoxic environmental contaminants on cholesterol and DNA synthesis in cultured primary rat hepatocytes. Environ Sci 1(4):179–189.
Riddick JA, Bunger WB, Sakano TK. 1986. Organic solvents: Physical properties and methods of purification. In: Techniques of chemistry. 4^th^ ed. New York, NY: Wiley-Interscience, 65.
RIDH. 1989. Written communication regarding 1,1,2-trichloroethane levels in private well water. Providence, RI: Rhode Island Department of Health.
Rogers SE, Peterson DL, Lauer WC. 1987. Organic contaminants removal for potable reuse. J Water Pollut Control Fed 59:722–732.
Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, . 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6(3):199–205. 10.1093/mutage/6.3.199.1881351
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Sabljic A. 1987. On the prediction of soil sorption coefficients of organic pollutants from molecular structure: application of molecular topology model. Environ Sci Technol 21(4):358–366. 10.1021/es00158a004.22280175
Sanders VM, White KL, Shopp GM, . 1985. Humoral and cell-mediated immune status of mice exposed to 1,1,2-trichloroethane. Drug Chem Toxicol 8(5):357–372. 10.3109/01480548509041064.4064948
SANSS. 1988. Structure and Nomenclature Search System. Online. 7/31/88.
Sapphire Group. 2003. Physiologically based pharmacokinetic model development, simulations, and sensitivity analysis for repeated exposure to 1,1,2-trichloroethane The Sapphire Group. HAP Task Force. EPA-HQ-OPPT-2002-0046-0007. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0046-0007. August 14, 2020.
Sapphire Group. 2004a. Route-to-route extrapolation of 1,1,2-trichloroethane studies from the oral route to inhalation using physiologically based pharmacokinetic models: Immunotoxicity. The Sapphire Group. HAP Task Force. EPA-HQ-OPPT-2002-0056-0092. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0056-0092. August 14, 2020.
Sapphire Group. 2004b. Route-to-route extrapolation of 1,1,2-trichloroethane studies from the oral route to inhalation using physiologically based pharmacokinetic models: Acute neurotoxicity. The Sapphire Group. HAP Task Force. EPA-HQ-OPPT-2002-0056-0130. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0056-0130. August 14, 2020.
Sapphire Group. 2004c. Route-to-route extrapolation of 1,1,2-trichloroethane studies from the oral route to inhalation using physiologically based pharmacokinetic models: Carcinogenicity. The Sapphire Group. HAP Task Force. EPA-HQ-OPPT-2002-0046-0009. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0046-0009. August 14, 2020.
Sapphire Group. 2005a. Route-to-route extrapolation of 1,1,2-trichloroethane studies from the oral route to inhalation using physiologically based pharmacokinetic models: Subchronic neurotoxicity. The Sapphire Group. HAP Task Force. EPA-HQ-OPPT-2002-0046-0017. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0046-0017. June 14, 2020.
Sapphire Group. 2005b. Route-to-route extrapolation of 1,1,2-trichloroethane studies from the oral route to inhalation using physiologically based pharmacokinetic models: Developmental toxicity. The Sapphire Group. HAP Task Force. EPA-HQ-OPPT-2002-0046-0018. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0046-0018. August 14, 2020.
Sapphire Group. 2006. Route-to-route extrapolation of 1,1,2-trichloroethane studies from the oral route to inhalation using physiologically based pharmacokinetic models: Reproductive toxicity. The Sapphire Group. HAP Task Force. EPA-HQ-OPPT-2002-0056-0128. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0056-0128. August 14, 2020.
Sato A, Nakajima T. 1979. A structure-activity relationship of some chlorinated hydrocarbons. Arch Environ Health 34:69–75. 10.1080/00039896.1979.10667371.434934
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratog Carcinog Mutagen 6(5):361–374. 10.1002/tcm.1770060503.2878502
Seip HM, Alstad J, Carlberg GE, . 1986. Measurement of mobility of organic compounds in soils. Sci Total Environ 50:87–102. 10.1016/0048-9697(86)90353-0.
Singh HB, Salas LJ, Cavanagh LA. 1977. Distribution sources and sinks of atmospheric halogenated compounds. J Air Pollut Control Assoc 27:332–336. 10.1080/00022470.1977.10470427.
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16(12):872–880. 10.1021/es00106a010.22236265
Singh HB, Salas LJ, Smith AJ, . 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612. 10.1016/0004-6981(81)90191-8.
Smyth HF, Carpenter CP, Weil CS, . 1969. Range-finding toxicity data: List VII. Am Ind Hyg Assoc J 30(5):470–476. 10.1080/00028896909343157.5823428
STORET. 1988. STORET Water Quality Database.
Story DL, Meierhenry EF, Tyson CA, . 1986. Differences in rat liver enzyme-altered foci produced by chlorinated aliphatics and phenobarbital. Toxicol Ind Health 2(4):351–362. 10.1177/074823378600200402.3296316
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tafazoli M, Kirsch-Volders M. 1996. In vitro mutagenicity and genotoxicity study of 1,2-dichloroethylene, 1,1,2-trichloroethane, 1,3-dichloropropane, 1,2,3-trichloropropane and 1,1,3-trichloropropene, using the micronucleus test and the alkaline single cell gel electrophoresis technique (comet assay) in human lymphocytes. Mutat Res 371(3–4):185–202. 10.1016/s0165-1218(96)90107-x.9008720
Takahara K. 1986a. [Experimental study on toxicity of trichloroethane: Part 1]. Okayama Igakkai Zasshi 98:1079–1090. (Japanese)
Takahara K. 1986b. [Experimental study on toxicity of trichloroethane. III. Changes in liver function of mice after exposure to 1,1,1- and 1,1,2-trichloroethane]. Okayama Igakkai Zasshi 98:1099–1109. (Japanese)
Takahara K. 1986c. [Experimental study on toxicity of trichloroethane. II. 1,1,1- and 1,1,2-trichloroethane in expired air and in urine of mice]. Okayama Igakkai Zasshi 98:1091–1097. (Japanese)
Taningher M, Parodi S, Grilli S, . 1991. Lack of correlation between alkaline DNA fragmentation and DNA covalent binding induced by polychloroethanes after in vivo administration. Problems related to the assessment of a carcinogenic hazard. Cancer Detect Prev 15(1):35–39.2044072
Thomas R. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt D, H., eds. Handbook of chemical property estimation methods. New York, NY: McGraw Hill, 15–11 to 15–34.
Torkelson TR, Rowe VK. 1981. Halogenated aliphatic hydrocarbons. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. 28. New York, NY: John Wiley & Sons, 3510–3513; 3586–3601.
Traiger GJ, Plaa GL. 1974. Chlorinated hydrocarbon toxicity. Potentiation by isopropyl alcohol and acetone. Arch Environ Health 28(5):276–278. 10.1080/00039896.1974.10666486.4821771
TRI18. 2020. 1,1,2-Trichloroethane. Toxics Release Inventory explorer data. Washington, DC: U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. May 21, 2020.
Tsuruta H. 1975. Percutaneous absorption of organic solvents. 1. Comparative study of the in vivo percutaneous absorption of chlorinated solvents in mice. Ind Health 13:227–236. 10.2486/indhealth.13.227.
Tsuruta H, Iwasaki K, Fukuda K. 1983. Analysis of trace impurities in reagent and technical grade trichloroethylene. Ind Health 21(4):293–295. 10.2486/indhealth.21.293.6654709
Tu AS, Murray TA, Hatch KM, . 1985. In vitro transformation of BALB/C-3T3 cells by chlorinated ethanes and ethylenes. Cancer Lett 28:85–92. 10.1016/0304-3835(85)90096-5.4027960
Tyson CA, Hawk-Prather K, Story DL, . 1983. Correlations of in vitro and in vivo hepatotoxicity for five haloalkanes. Toxicol Appl Pharmacol 70(2):289–302. 10.1016/0041-008x(83)90105-9.6623471
USDHHS. 1985. Fourth annual report on carcinogens. Summary 1985. U.S. Department of Health and Human Services. NTP 85-002.
Viar Company. 1987. Contract Laboratory Program Statistical Data Base. April 13, 1987.
Vogel EW, Nivard MJ. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8(1):57–81. 10.1093/mutage/8.1.57.8450769
Vogel TM, Criddle CS, McCarty PL. 1987. ES Critical Reviews: Transformations of halogenated aliphatic compounds. Environ Sci Technol 21(8):722–736. 10.1021/es00162a001.19995052
Vogt WG, Montague LY, Carrico PJ, . 1987. VOC emission rates from solid waste landfills. In: Proceedings: Third annual symposium: United States Environmental Protection Agency symposium on solid waste testing and quality assurance: Volume I. Washington, DC: U.S. Environmental Protection Agency, 1–103--101–114.
Volkel W, Friedewald M, Lederer E, . 1998. Biotransformation of perchloroethene: dose-dependent excretion of trichloroacetic acid, dichloroacetic acid, and N-acetyl-S-(trichlorovinyl)-L-cysteine in rats and humans after inhalation. Toxicol Appl Pharmacol 153(1):20–27. 10.1006/taap.1998.8548.9875296
Wahlberg JE. 1976. Percutaneous toxicity of solvents. A comparative investigation in the guinea pig with benzene, toluene and 1,1,2-trichloroethane. Ann Occup Hyg 19(2):115–119. 10.1093/annhyg/19.2.115.1008403
Wahlberg JE. 1984a. Erythema-inducing effects of solvents following epicutaneous administration to man - studied by laser Doppler flowmetry. Scand J Work Environ Health 10:159–162. 10.5271/sjweh.2351.6236553
Wahlberg JE. 1984b. [Edema-inducing effects of solvents following topical administration]. Dermatosen Beruf Umwelt 32:91–94. (German)
Wallace LA, Pellizzari E, Hartwell T, . 1984. Personal exposure to volatile organic compounds. I. Direct measurements in breathing-zone air, drinking water, food, and exhaled breath. Environ Res 35(1):293–319. 10.1016/0013-9351(84)90137-3.6489295
Watrous WM, Plaa GL. 1972. Effect of halogenated hydrocarbons on organic ion accumulation by renal cortical slices of rats and mice. Toxicol Appl Pharmacol 22(4):528–543. 10.1016/0041-008x(72)90282-7.5045761
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76:52–59.
White KL, Sanders VM, Barnes DW, . 1985. Toxicology of 1,1,2-trichloroethane in the mouse. Drug Chem Toxicol 8(5):333–355. 10.3109/01480548509041063.4064947
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wikoff D, Urban JD, Harvey S, . 2018. Role of risk of bias in systematic review for chemical risk assessment: A case study in understanding the relationship between congenital heart defects and exposures to trichloroethylene. Int J Toxicol 37(2):125–143. 10.1177/1091581818754330.29357719
Williams G. 1983. DNA repair tests of 11 chlorinated hydrocarbon analogs. Naylor Dana Institute. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0509403. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0509403.xhtml. August 13, 2020.
Wilson DT. 2005. A prenatal developmental toxicity study of 1,1,2-trichloroethane via drinking water in rats. WIL Research Laboratories. HAP Task Force. EPA-HQ-OPPT-2002-0056-0115. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0056-0115. March 07, 2018
Wilson JT, Enfield CG, Dunlap WJ, . 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10:501–506. 10.2134/jeq1981.00472425001000040016x.
Wilson JT, McNabb, Balkwill DL, . 1983. Enumeration and characterization of bacteria indigenous to a shallow water-table aquifer. Ground Water 21:134–142. 10.1111/j.1745-6584.1983.tb00710.x.
Windholz M, ed. 1983. 1,1,2-Trichloroethane. In: The Merck index. An encyclopedia of chemicals, drugs, and biologicals. Rahway, NJ: Merck and Co., Inc., 1378.
WQP. 2020. Water quality portal data: 1,1,2-Trichloroethane. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. August 12, 2020.
Wright WH, Schaffer JM. 1932. Critical anthelmintic tests of chlorinated alkyl hydrocarbons and a correlation between the anthelmintic efficacy, chemical structure and physical properties. Am J Hyg 16:325–426. 10.1093/oxfordjournals.aje.a117867.
Xia L, Yu T. 1992. Study of the relationship between the hepatotoxicity and free radical induced by 1,1,2-trichloroethane and 1,1,1-trichloroethane in rat. Biomed Environ Sci 5(4):303–313.1489524
Yllner S. 1971. Metabolism of 1,1,2-trichloroethane-1,2-14C in the mouse. Acta Pharmacol Toxicol (Copenh) 30:248–256. 10.1111/j.1600-0773.1971.tb00656.x.4945485
Zaki MH. 1986. Groundwater contamination with synthetic organic compounds and pesticides in Suffolk County. Northeast Environ Sci 5:15–22.
Zeiger E, Anderson B, Haworth S, . 1988. Salmonella mutagenicity tests: IV. Results from the testing of 300 chemicals. Environ Mol Mutagen 11(Suppl 12):1–157. 10.1002/em.2850110602.
Zoeteman BC, Harmsen K, Linders JBH, . 1980. Persistent organic pollutants in river water and ground water of the Netherlands. Chemosphere 9:231–249. 10.1016/0045-6535(80)90080-6.