# VERSION HISTORY

Date | Description
March 2021 | Final toxicological profile released
December 2019 | Draft for public comment toxicological profile released
October 2010 | Addendum to the toxicological profile released
December 1989 | Final toxicological profile released