# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 1,1,2-trichloroethane are listed in Table 4-1.

Table 4-1 Chemical Identity of 1,1,2-Trichloroethane

Characteristic | Information | Reference
Chemical name | 1,1,2-trichloroethane | CAS 1988
Synonym(s) and registered trade name(s) | Ethane trichloride; β-Trichloroethane; Vinyl trichloride; 1,2,2-Trichloroethane | CAS 1988; SANSS 1988
Chemical formula | β-T; Cement T-339 | SANSS 1988
Chemical structure | [image] | CAS 1988
Identification numbers:
CAS Registry | 79-00-5 | CAS 1988

CAS = Chemical Abstracts Services

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 1,1,2-trichloroethane are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of 1,1,2-Trichloroethane

Property | Information | Reference
Molecular weight | 133.41 g/mol | Riddick et al. 1986
Color | Colorless | Hawley 1981
Physical state | Liquid | Hawley 1981
Melting point | −36.53°C | Riddick et al. 1986
Boiling point | 113.85°C | Riddick et al. 1986
Density at 20°C | 1.43931 | Riddick et al. 1986
| 1.4416 | Torkelson and Rowe 1981
| 1.443 | Windholz 1983
Odor | Sweet | Hawley 1981
Solubility:
Water at 20°C | 4,400 mg/L | Riddick et al. 1986
Organic solvents | Miscible with ethers, alcohols, esters, and ketones | Hawley 1981
Partition coefficients:
Log K_ow_ | 2.42 | Isnard and Lambert 1988
Log K_oc_ | 1.06–2.49^a^ (estimated) | Sabljic 1987
Vapor pressure at 25°C | 22.49 mmHg | Riddick et al. 1986
Henry’s law constant | 9.1×10^−4^ atm/m^3^-mol (25°C); 1.12×10^−3^ atm/m^3^-mol (30°C)^b^ | Ashworth et al. 1988
Autoignition temperature | 460°C | Parrish 1983
Flashpoint | None | Hawley 1981
Flammability limits | 8.4–13.3% (by volume) | Moolenaar and Olson 1989
Conversion factors:
ppm (v/v) to mg/m^3^ in air (20°C) | 1 ppm (v/v) = 5.55 = mg/m^3^
mg/m^3^ (v/v) to ppm in air (20°C) | 1 mg/m^3^ = 0.18 ppm (v/v)

a Organic matter partition coefficient.

b First value obtained using equilibrium partitioning in closed systems technique and second by the batch air-stripping method.