# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR 1,1,2-TRICHLOROETHANE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to 1,1,2-trichloroethane, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to 1,1,2-trichloroethane:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 1,1,2-trichloroethane. The inclusion criteria used to identify relevant studies examining the health effects of 1,1,2-trichloroethane are presented in Table C-1.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; Human; Laboratory mammals
Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data)
Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of 1,1,2-trichloroethane. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for 1,1,2-trichloroethane released for public comment in 2019. See Appendix B for the databases searched and the search strategy.

A total of 110 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of 1,1,2-trichloroethane.

Title and Abstract Screen. In the Title and Abstract Screen step, 110 records were reviewed; 0 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 31 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 31 documents, 38 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

A summary of the extracted data for each study is presented in the Supplemental Document for 1,1,2-trichloroethane and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.19 of the profile and in the Levels Significant Exposures tables (Tables 2-1, 2-2, and 2-3, respectively).

Table C-2 Data Extracted From Individual Studies

Citation; Chemical form; Route of exposure (e.g., inhalation, oral, dermal); Specific route (e.g., gavage in oil, drinking water); Species; Strain; Exposure duration category (e.g., acute, intermediate, chronic); Exposure duration; Frequency of exposure (e.g., 6 hours/day, 5 days/week); Exposure length; Number of animals or subjects per sex per group; Dose/exposure levels; Parameters monitored; Description of the study design and method; Summary of calculations used to estimate doses (if applicable); Summary of the study results; Reviewer’s comments on the study; Outcome summary (one entry for each examined outcome); No-observed-adverse-effect level (NOAEL) value; Lowest-observed-adverse-effect level (LOAEL) value; Effect observed at the LOAEL value

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for 1,1,2-trichloroethane identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The only available human studies evaluating noncancer effects are dermal studies (limited in scope) and one case-control study examining the association between the proximity to industrial air releases of chlorinated solvents (including 1,1,2-tricholoroethane) and birth defects (Brender et al. 2014). Animal studies examined a comprehensive set of endpoints following inhalation or oral exposure, but dermal studies were limited to acute lethality, skin irritation, and skin sensitization. Respiratory, hepatic, neurological, and

Table C-3 Overview of the Health Outcomes for 1,1,2-Trichloroethane Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Oral studies
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Dermal studies
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case series | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for 1,1,2-Trichloroethane Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 0 | 2 | 0 | 0 | 0 | 0 | 4 | 0 | 0 | 0 | 0 | 0 | 6 | 0 | 0 | 0 | 0
Acute-duration | 0 | 2 | 0 | 0 | 0 | 0 | 4 | 0 | 0 | 0 | 0 | 0 | 6 | 0 | 0 | 0 | 0
Intermediate-duration | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Intermediate-duration | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Oral studies
Acute-duration | 3 | 1 | 0 | 2 | 1 | 0 | 5 | 2 | 0 | 0 | 0 | 1 | 6 | 1 | 1 | 0 | 0
Acute-duration | 2 | 0 | 0 | 2 | 0 | 0 | 3 | 1 | 0 | 0 | 0 | 0 | 5 | 0 | 0 | 0 | 0
Intermediate-duration | 5 | 1 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 2 | 0 | 0
Intermediate-duration | 4 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0
Chronic-duration | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 0 | 0 | 2 | 2 | 2 | 0 | 0 | 2
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Dermal studies
Acute-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 4 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Acute-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Intermediate-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Intermediate-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Chronic-duration | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

immunological effects were considered sensitive outcomes, i.e., effects were observed at low concentrations or doses. Thirty-eight studies (published in 31 documents) examining these potential outcomes were carried through to Steps 4–8 of the systematic review.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (-)
- Definitely high risk of bias (– –)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of 1,1,2-trichloroethane health effects studies observed in animal experimental studies (human studies did not evaluate respiratory, hepatic, neurological or immunological outcomes) are presented in Table C-8.

Table C-8 Summary of Risk of Bias Assessment for 1,1,2-Trichloroethane—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Administered dose or exposure level adequately randomized? | Allocation to study groups adequately concealed? | Experimental conditions identical across study groups? | Research personnel blinded to the study group during the study? | Outcome data complete without attrition or exclusion from analysis? | Confidence in the exposure characterization? | Confidence in the outcome assessment?* | All measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Inhalation acute exposure
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | ++ | + | ++ | ++ | ++ | ++ | ++ | ++ | First
Kirkpatrick 2001 (rat; F344; 45–1,474 ppm) | ++ | + | ++ | ++ | ++ | ++ | ++ | ++ | First
Oral acute exposure
White et al. 1985 (mouse; CD-1; 14 days) | + | + | ++ | + | ++ | + | ++ | ++ | First
Inhalation intermediate exposure
Kirkpatrick 2002 (rat; F344 CDF Crl:BR) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
Oral intermediate exposure
White et al. 1985 (mouse; CD-1) | + | + | ++ | + | ++ | + | – | ++ | Second
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | + | + | ++ | + | + | ++ | ++ | ++ | First
NCI 1978 (mouse; B6C3F1) | + | + | ++ | + | + | ++ | ++ | ++ | First
Outcome: Hepatic effects
Inhalation acute exposure
Carlson 1973 (rat; albino) | – | + | + | + | + | – | – | + | Second
Gehring 1968 (mouse; Swiss Webster) | – | + | + | + | + | – | – | + | Second
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | ++ | + | ++ | ++ | ++ | ++ | ++ | ++ | First
Takahara 1986a (mouse) | – | + | – | + | + | – | – | + | Second
Oral acute exposure
Platt and Cockrill 1969 (rat; Wistar-derived) | + | + | + | + | + | – | – | + | Second
Tyson et al. 1983 (rat; Sprague-Dawley) | – | + | + | + | + | – | + | + | First
White et al. 1985 (mouse; CD-1; 14 days) | + | + | ++ | + | ++ | + | ++ | ++ | First
Wright and Schaffer 1932 (dog) | – – | + | – | + | + | + | – | + | Second
Xia and Yu 1992 (rat; Wistar) | + | + | – | + | – | + | – | + | Second
Inhalation intermediate exposure
Kirkpatrick 2002 (rat; F344) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
Oral intermediate exposure
White et al. 1985 (mouse; CD-1) | + | + | ++ | + | ++ | + | + | ++ | First
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | + | + | ++ | + | + | ++ | ++ | ++ | First
NCI 1978 (mouse; B6C3F1) | + | + | ++ | + | + | ++ | ++ | ++ | First
Outcome: Neurological effects
Inhalation acute exposure
Bonnet et al. 1980 (rat; Sprague-Dawley) | – | + | + | + | – | – | – | + | Second
de Ceaurriz et al. 1981 (mouse; Swiss OF1) | – | + | + | + | – | + | – | + | Second
Gehring 1968 (mouse; Swiss-Webster) | – | + | + | + | + | – | – | + | Second
Lazarew 1929 (mouse) | – | + | + | + | + | – | – | + | Second
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | ++ | + | ++ | ++ | ++ | ++ | ++ | ++ | First
Kirkpatrick 2001 (rat; F344; 45–1,474 ppm) | ++ | + | ++ | ++ | ++ | ++ | ++ | ++ | First
Oral acute exposure
Beck 2004 (rat; Crl:CD(SD)IGS) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
Borzelleca 1983 (mouse; CD-1) | – | + | + | + | – | – | – | + | Second
Kallman et al. 1983 (mouse; CD-1) | + | + | ++ | + | ++ | ++ | + | ++ | First
Kallman and Kaempf 1984 (mouse; CD-1) | + | + | ++ | + | ++ | ++ | + | ++ | First
White et al. 1985 (mouse; CD-1; once) | + | + | ++ | + | + | + | + | ++ | First
Wright and Schaffer 1932 (dog) | – – | + | – | + | + | + | – | + | Second
Oral intermediate exposure
Maurissen et al. 2005 (rat; F344/DUCRL) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | + | + | ++ | + | + | ++ | ++ | ++ | First
NCI 1978 (mouse; B6C3F1) | + | + | ++ | + | + | ++ | ++ | ++ | First
Outcome: Immunological effects
Oral acute exposure
Sanders et al. 1985 (mouse; CD-1) | + | + | ++ | + | ++ | + | ++ | ++ | First
Oral intermediate exposure
Sanders et al. 1985 (mouse; CD-1) | + | + | ++ | + | ++ | + | ++ | ++ | First
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | + | + | ++ | + | + | ++ | ++ | ++ | First
NCI 1978 (mouse; B6C3F1) | + | + | ++ | + | + | ++ | ++ | ++ | First

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to 1,1,2-trichloroethane and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to 1,1,2-trichloroethane and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions in Distiller, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-9, C-10, and C-11, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-9 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-10 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were test
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-11 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining respiratory, hepatic, neurological, and immunological effects observed in animal experimental studies are presented in Table C-12.

A summary of the initial confidence ratings for each outcome is presented in Table C-13. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-13.

Table C-12 Presence of Key Features of Study Design for 1,1,2-Trichloroethane—Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Inhalation acute exposure
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | Yes | No | Yes | Yes | High
Kirkpatrick 2001 (rat; F344; 45–1,474 ppm) | Yes | No | Yes | Yes | High
Oral acute exposure
White et al. 1985 (mouse; CD-1; 14 days) | Yes | Yes | No | Yes | Moderate
Inhalation intermediate exposure
Kirkpatrick 2002 (rat; F344 CDF Crl:BR) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
White et al. 1985 (mouse; CD-1) | Yes | Yes | No | Yes | Moderate
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | Yes | Yes | Yes | Yes | High
NCI 1978 (mouse; B6C3F1) | Yes | Yes | Yes | Yes | High
Outcome: Hepatic effects
Inhalation acute exposure
Carlson 1973 (rat; albino) | Yes | Yes | No | Yes | Moderate
Gehring 1968 (mouse; Swiss Webster) | No | Yes | No | No | Very Low
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | Yes | No | Yes | Yes | High
Takahara 1986a (mouse) | No | Yes | No | No | Very Low
Oral acute exposure
Platt and Cockrill 1969 (rat; Wistar-derived) | Yes | Yes | No | Yes | Moderate
Tyson et al. 1983 (rat; Sprague-Dawley) | No | No | No | No | Very Low
White et al. 1985 (mouse; CD-1; 14 days) | Yes | Yes | Yes | Yes | High
Wright and Schaffer 1932 (dog) | No | No | Yes | No | Very Low
Xia and Yu 1992 (rat; Wistar) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate exposure
Kirkpatrick 2002 (rat; F344) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
White et al. 1985 (mouse; CD-1) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | Yes | Yes | Yes | Yes | High
NCI 1978 (mouse; B6C3F1) | Yes | Yes | Yes | Yes | High
Outcome: Neurological effects
Inhalation acute exposure
Bonnet et al. 1980 (rat; Sprague-Dawley) | No | Yes | Yes | No | Low
de Ceaurriz et al. 1981 (mouse; Swiss OF1) | No | Yes | No | No | Very Low
Gehring 1968 (mouse; Swiss-Webster) | No | Yes | No | No | Very Low
Lazarew 1929 (mouse) | No | No | No | No | Very Low
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | Yes | No | Yes | Yes | High
Kirkpatrick 2001 (rat; F344; 45–1,474 ppm) | Yes | No | Yes | Yes | High
Oral acute exposure
Beck et al. 2004 | Yes | Yes | Yes | Yes | High
Borzelleca 1983 (mouse; CD-1) | No | No | Yes | No | Very Low
Kallman et al. 1983 (mouse; CD-1) | Yes | Yes | No | Yes | Moderate
Kallman and Kaempf 1984 (mouse; CD-1) | Yes | No | No | No | Low
White et al. 1985 (mouse; CD-1; once) | No | Yes | Yes | No | Low
Wright and Schaffer 1932 (dog) | No | No | Yes | No | Very Low
Oral intermediate exposure
Maurissen et al. 2005 (rat; F344/DUCRL) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | Yes | Yes | No | Yes | Moderate
NCI 1978 (mouse; B6C3F1) | Yes | Yes | No | Yes | Moderate
Outcome: Immunological effects
Oral acute exposure
Sanders et al. 1985 (mouse; CD-1) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Sanders et al. 1985 (mouse; CD-1) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | Yes | Yes | No | Yes | Moderate
NCI 1978 (mouse; B6C3F1) | Yes | Yes | No | Yes | Moderate

Table C-13 Initial Confidence Rating for 1,1,2-Trichloroethane Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Inhalation acute exposure
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | High | High
Kirkpatrick 2001 (rat; F344; 45–1,474 ppm) | High | High
Inhalation intermediate exposure
Kirkpatrick 2002 (rat; F344 CDF Crl:BR) | High | High
Oral acute exposure
White et al. 1985 (mouse; CD-1) | Moderate | Moderate
Oral intermediate exposure
White et al. 1985 (mouse; CD-1) | Moderate | Moderate
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | High | High
NCI 1978 (mouse; B6C3F1) | High | High
Outcome: Hepatic effects
Inhalation acute exposure
Carlson 1973 (rat; albino) | Moderate | High
Gehring 1968 (mouse; Swiss Webster) | Moderate | Very Low
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | Moderate | High
Takahara 1986a (mouse) | Moderate | Very Low
Inhalation intermediate exposure
Kirkpatrick 2002 (rat; F344) | High | High
Oral acute exposure
Platt and Cockrill 1969 (rat; Wistar-derived) | Moderate | High
Tyson et al. 1983 (rat; Sprague-Dawley) | Very Low | High
White et al. 1985 (mouse; CD-1) | High | High
Wright and Schaffer 1932 (dog) | Very Low | High
Xia and Yu 1992 (rat; Wistar) | Moderate | High
Intermediate Inhalation exposure
Kirkpatrick 2002 (rat; F344 CDF Crl:BR) | High | High
Oral intermediate exposure
White et al. 1985 (mouse; CD-1) | High | High
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | High | High
NCI 1978 (mouse; B6C3F1) | High | High
Outcome: Neurological effects
Inhalation acute exposure
Bonnet et al. 1980 (rat; Sprague-Dawley) | Low | High
de Ceaurriz et al. 1981 (mouse; Swiss OF1) | Very Low | High
Gehring 1968 (mouse; Swiss-Webster) | Very Low | High
Lazarew 1929 (mouse) | Very Low | High
Kirkpatrick 2001 (rat; F344; 58–1,527 ppm) | High | High
Kirkpatrick 2001 (rat; F344; 45–1,474 ppm) | High | High
Oral acute exposure
Beck 2004 (rat; Crl:CD(SD)IGS) | High | High
Borzelleca 1983 (mouse; CD-1) | Very Low | High
Kallman et al. 1983 (mouse; CD-1) | Moderate | High
Kallman and Kaempf 1984 (mouse; CD-1) | Low | High
White et al. 1985 (mouse; CD-1) | Low | High
Wright and Schaffer 1932 (dog) | Very Low | High
Oral intermediate exposure
Maurissen et al. 2005 (rat; F344/DUCRL) | High | High
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | Moderate | Moderate
NCI 1978 (mouse; B6C3F1) | Moderate | Moderate
Outcome: Immunological effects
Oral acute exposure
Sanders et al. 1985 (mouse; CD-1) | High | High
Oral intermediate exposure
Sanders et al. 1985 (mouse; CD-1) | High | High
Oral chronic exposure
NCI 1978 (rat; Osborne-Mendel) | Moderate | Moderate
NCI 1978 (mouse; B6C3F1) | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for respiratory, hepatic, neurological, and immunological effects are presented in Table C-14. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with 1,1,2-trichloroethane exposure is presented in Table C-15.

Table C-14 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory effects
Animal studies | High | None | High
Outcome: Hepatic effects
Animal studies | High | None | High
Outcome: Neurological effects
Animal studies | High | None | High
Outcome: Immunological effects
Animal studies | High | −1 unexplained inconsistency | Moderate

Table C-15 Confidence in the Body of Evidence for Ethylene Oxide

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects | No data | High
Hematological effects | No data | High
Neurological effects | No data | High
Immunological effects | No data | Moderate

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Table C-8). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for 1,1,2-trichloroethane, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for 1,1,2-trichloroethane is presented in Table C-16.

Table C-16 Level of Evidence of Health Effects for 1,1,2-Trichloroethane

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Animal studies
Respiratory effects following inhalation exposure | High | Health effect | High
Hepatic effects | High | Health effect | High
Neurological effects | High | Health effect | High
Immunological effects | Moderate | Health effect | Moderate

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient

Figure C-1 Hazard Identification Scheme

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for 1,1,2-trichloroethane are listed below and summarized in Table C-17.

### Presumed Health Effects

- Respiratory effects following inhalation exposure
  ○ No human data
  ○ Acute- and intermediate-duration inhalation studies identified changes in the bronchoalveolar lavage fluid (increased protein content) and nasal lesions (vacuolization and microcyst formation, respiratory epithelial metaplasia, atrophy, and/or necrosis of the olfactory epithelium) in male and female rats (Kirkpatrick 2001, 2002).
- Hepatic effects
  ○ No human data
  ○ Liver effects (namely increased ALT and/or AST, increased liver weight, and/or histopathological changes including hepatocellular vacuolization and necrosis, fatty changes, and/or swelling) were identified in numerous acute- and intermediate-duration toxicity studies (via the inhalation and oral routes of exposure; Carlson 1973; Gehring 1968; Kirkpatrick 2001, 2002; Moody et al. 1981; Takahara 1986b; Tyson et al. 1983; unpublished data from Dow Chemical Co. as provided in Torkelson and Rowe 1981; White et al. 1985). However, liver lesions were not reported in rats and mice orally exposed to 1,1,2-trichloroethane for 78 weeks (NCI 1978).
- Neurological effects
  ○ No human data
  ○ Acute-duration inhalation toxicity studies in rats and mice predominantly identified clinical signs of neurotoxicity at sublethal exposure concentrations (Bonnet et al. 1980; de Ceaurriz et al. 1981; Gehring 1968; Kirkpatrick 2001; Lazarew 1929). In addition to clinical signs, reduced motor activity, gait impairment, and taste aversion (to saccharin) were observed in acute-duration oral toxicity studies in rats and mice (Beck 2004; Borzelleca 1983; Kallman et al. 1983). However, rats treated for up to 13 weeks with 1,1,2-trichloroethane in drinking water showed no effects on FOB tests or histopathology of nervous system organs and tissues (Maurissen et al. 2005). Likewise, there was no evidence of neurological effects (based on histopathology) in rats and mice treated orally with 1,1,2-trichloroethane for 78 weeks. Few repeated-dose studies have evaluated neurobehavioral effects (NCI 1978).

### Suspected Health Effect

- Immunological effects
  ○ No human data
  ○ An intermediate-duration oral toxicity study identified a dose-related reduction in hemagglutination titers in male and female mice (Sanders et al. 1985). However, other immunological parameters (numbers of splenic antibody-forming cells, the response of splenic lymphocytes to mitogens, and macrophage activity) evaluated in the same study were not consistently affected. In addition, mice exposed to 1,1,2-trichloroethane for 14 days showed no significant, treatment-related immunological effects (based on similar humoral or cell-mediated immune response evaluations; Sanders et al. 1985). Chronic-duration studies in rats and mice identified NOAELs for immunological effects based on the absence of histopathological changes in the spleen, thymus, bone marrow, or lymph nodes; immunological function was not evaluated in these studies (NCI 1978).

Table C-17 Hazard Identification Conclusions for 1,1,2-Trichloroethane

Outcome | Hazard identification
Respiratory effects | Presumed health effect
Hepatic effects | Presumed health effect
Neurological effects | Presumed health effect
Immunological effects | Suspected health effect