# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ethylene Oxide
CAS Numbers: | 79-00-5
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.03 ppm
Critical Effect: | Necrosis of the olfactory epithelium (minimal to mild; nasal level IV)
Reference: | Kirkpatrick 2001
Point of Departure: | LOAEL of 58 ppm (LOAEL_HEC_ of 7.5 ppm)
Uncertainty Factor: | 270
LSE Graph Key: | 6
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 0.03 ppm was derived for 1,1,2-trichloroethane based on necrosis in the olfactory epithelium (nasal level IV) of male and female rats exposed to 58 ppm 1,1,2-trichloroethane for 4 hours (Kirkpatrick 2001). The MRL is based on a LOAEL of 58 ppm which was converted to a human equivalent concentration (LOAEL_HEC_) of 7.5 ppm and divided by a total uncertainty factor of 90 (3 for use of a minimal LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability) and a modifying factor of 3 for an incomplete database.

Selection of the Critical Effect: In the only acute-duration study that subjected tissues to histopathological examinations (Kirkpatrick 2001), rats exposed to 1,1,2-trichloroethane for 4 hours showed evidence of respiratory tract damage (necrosis of the olfactory epithelium at nasal levels III, IV, and V) at ≥58 ppm. This effect was seen at a lower concentration than hepatocellular necrosis in the same study (≥181 ppm). Several other acute-duration inhalation toxicity studies of 1,1,2-trichloroethane identified liver damage and/or neurological effects (Bonnet et al. 1980; Carlson 1973; de Ceaurriz et al. 1981; Gehring 1968; Lazarew 1929; Takahara 1986a). The majority of the studies identified changes in serum blood chemistry related to liver function (at ≥800 ppm) or clinical signs of neurotoxicity (at ≥418 ppm); gross or microscopic pathology examinations were not performed.

The LOAEL for respiratory effects is lower than the LOAELs for other target systems identified in acute-duration studies (hepatic and neurological effects). NOAEL and LOAEL values for acute-duration inhalation exposure are summarized in Table A-1.

Table A-1 Summary of Relevant NOAEL and LOAEL Values Following Acute-Duration Inhalation Exposure to 1,1,2-Trichloroethane

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Respiratory effects
F344 rat | 4 hours | ND | 58 | Necrosis of the olfactory epithelium | Kirkpatrick 2001
F344 rat | 4 hours | 170 (females); 205 (males) | 840 (females); 1,474 (males) | Increased protein content of BALF (females) | Kirkpatrick 2001
Liver effects
F344 rat | 4 hours | 58 | 181 | Hepatocellular necrosis | Kirkpatrick 2001
Mouse (NS) | 3 hours | ND | 800 | Increased ALT and liver triglycerides; decreased plasma triglycerides and ATP | Takahara 1986a
Albino rat | 2 hours | 890 | 2,080 | Increased ALT | Carlson 1973
Swiss-Webster mouse | 15 hours | ND | 3,750 | Increased ALT | Gehring 1968
Neurological effects
Swiss OF_1_ mouse | 4 hours | ND | 418 | CNS depression | de Ceaurriz et al. 1981
F344 rat | 4 hours | ND | 840 (females); 1,474 (males) | Sleepiness; decreased respiration | Kirkpatrick 2001
F344 rat | 4 hours | ND | 1,527 | Sleepiness; decreased respiration | Kirkpatrick 2001
Sprague-Dawley rat | 6 hours | ND | 1,654 | Somnolent | Bonnet et al. 1980
Mouse (NS) | 2 hours | 1,833 | 2,749 | Lie down on side; loss of reflex control | Lazarew 1929
Swiss-Webster mouse | 15 hours | ND | 3,750 | Anesthesia Gehring | 1968

ALT = alanine aminotransferase; BALF = bronchoalveolar lavage fluid; CNS = central nervous system; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified

Selection of the Principal Study: The study of Kirkpatrick (2001) was selected as the principal study for deriving an acute-duration inhalation MRL for 1,1,2-trichloroethane because it identified the lowest reliable LOAEL for respiratory effects in the only study that performed histopathological examinations.

Summary of the Principal Study:

Kirkpatrick DT. 2001. Acute inhalation toxicity (with histopathology) study of 1,1,2-trichloroethane (1,1,2-TCE) in rats. WIL Research Laboratories, Inc. HAP Task Force. EPA-HQ-OPPT-2002-0056-0039. WIL-417001. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0056-0039. March 07, 2018 .

F344 rats (5/sex/group) were exposed whole-body to 1,1,2-trichloroethane (purity 99.56%) as a vapor at nominal concentrations of 0, 50, 200, and 1,500 ppm for 4 hours and sacrificed 24 hours after cessation of exposure. Actual (measured) concentrations were 0, 58, 181, and 1,527 ppm. Animals were monitored for mortality and clinical signs of toxicity. The response to a noise stimulus was assessed at the midpoint of exposure. One day following exposure, detailed physical examinations were performed and body weights were measured. At necropsy, organ weights of the adrenals, brain, kidneys, liver, lungs, ovaries, and testes were recorded. Respiratory tract tissues were examined microscopically in all control and exposed animals; the liver, kidneys, and stomach were additionally examined in animals in the control and high-exposure groups.

Three females exposed at 1,527 ppm died on the day following exposure; although the cause of death was not specified, necrosis of the liver, kidneys, and/or respiratory tract tissues was observed. No mortality occurred in males or in other groups of exposed females. All animals exposed at 1,527 ppm showed sleepiness, decreased respiration, and clear discharge of the eyes immediately following exposure; these signs, in addition to lethargy, hypothermia, and reddish-brown urine, were noted on the day following exposure. The incidence of the absence of a response to a noise stimulus was increased in rats exposed at 1,527 ppm but was not strictly exposure-related. Rats exposed to 181 and 1,527 ppm lost weight from study days 0 to 1; within 1 day of exposure, the body weights of rats exposed to 1,527 ppm were significantly lower by 13% compared to controls. At scheduled necropsy, pale liver, dark areas in the stomach, liver, intestines, and urinary bladder were observed at 1,527 ppm. Relative kidney and adrenal gland weights were significantly increased by 19 and 40%, respectively, in 1,527 ppm males; no significant effects were observed in females, possibly due to the low number of surviving animals. Histopathological changes were noted primarily in the liver and respiratory tract tissues. Hepatocellular centrilobular necrosis was observed in 0/5 males and 4/5 females (minimal to mild) exposed at 181 ppm and 5/5 males and 2/2 females (moderate to severe) exposed at 1,527 ppm, compared to 0/10 controls. The incidence and severity of necrosis of the olfactory epithelium (nasal levels III, IV, and V) increased in an exposure-related manner. Based on statistical analyses (Fisher’s exact test) performed for this analysis, the male and female combined incidence of necrosis was significantly increased at all exposure concentrations at nasal level IV (affecting a small number of cells), and at 181 and 1,527 ppm at nasal levels III and V. The severity of the lesions were graded as minimal (2/5 males and 3/5 females) or mild (2/5 females) at 58 ppm, mild (5/5 males and 5/5 females) at 181 ppm, and mild (3/5 males) or moderate (1/5 males and 2/2 females) at 1,527 ppm. There was no evidence of necrosis in these tissues in control animals.

Selection of the Point of Departure for the MRL: The LOAEL of 58 ppm was selected as the point of departure (POD) for deriving an acute-duration inhalation MRL for 1,1,2-trichloroethane. Incidence data for necrosis of the olfactory epithelium in rats (level IV; any severity) are shown in Table A-2.

Table A-2 Incidence of Necrosis of the Olfactory Epithelium in F344 Rats Exposed to 1,1,2-Trichloroethane for 4 Hours

Target | Exposure concentration (ppm)
Target | 0 | 50 | 200 | 1,500
Measured | 0 | 58 | 181 | 1,527
Necrosis; level IV | 0/10 (0%) | 7/10 (70%) | 10/10 (100%) | 7/7 (100%)^a^

a Data for three females that died on the day following exposure were excluded from analyses.

Source: Kirkpatrick 2001

These data were not considered amenable to benchmark dose (BMD) modeling because the lowest tested concentration shows a response that is substantially higher than the benchmark response (BMR) of 10% (i.e., 70% of animals were affected at 58 ppm). Thus, the data provide limited information on the dose-response relationship at lower concentrations. In addition, since the response was 100% at the two highest tested exposure concentrations, higher exposure concentrations did not reduce the uncertainty associated with the shape of the dose-response curve.

Human Equivalent Concentration: The LOAEL of 58 ppm was converted to a human equivalent concentration (HEC) of 7.5 ppm using the following equation:

LOAEL_HEC_ = LOAEL × RGDR_ET_

where RGDR_ET_ is the extrathoracic regional gas dose ratio (animal:human) for the extrathoracic region. Extrathoracic regional gas doses were calculated for each species as follows: V_E_ (minute volume) ÷ SA_ET_ (surface area of the extrathoracic region); where V_E_ = 137 mL/minute (based on reference body weight for male and female rats, 0.180 kg) and SA_ET_ = 15 cm^2^ in rats and V_E_ = 13,800 mL/minute and SA_ET_ = 200 cm^2^ in humans (EPA 1994).

LOAEL_[ HEC ]_ = LOAEL × RGDR_ET_ LOAEL_[ H E C ]_ = 58 ppm × (137 mL / minute ÷ 15 cm^2^) / (13.800 mL / minute ÷ 200 cm^2^) LOAEL_[ HEC ]_ = 58 ppm × 0.13 LOAEL_[ HEC ]_ = 7.5 ppm

Uncertainty Factor and Modifying Factor: The LOAEL_HEC_ was divided by a total uncertainty factor of 90 and a modifying factor of 3:

- 3 for extrapolation from a minimal LOAEL; the study authors classified the severity of necrosis as minimal to mild because necrosis affected a small number of cells.
- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability
- 3 as a modifying factor for database deficiency because the only acute exposure data are from a single 4-hour exposure study.

MRL = LOAEL_HEC_ ÷ ( UFS × MF ) 7.5 ppm ÷ ( 3 × 3 × 10 × 3 ) = 0.03 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Histopathological changes to the olfactory epithelium (vacuolization/microcyst formation) were observed following intermediate-duration oral exposure to 1,1,2-trichloroethane (Kirkpatrick 2002).

Agency Contacts (Chemical Manager): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,2-Trichloroethane
CAS Numbers: | 79-00-5
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.002 ppm
Critical Effect: | Lesions of the olfactory epithelium (vacuolization/microcyst formation)
Reference: | Kirkpatrick 2002
Point of Departure: | BMCL_10_ of 3.15 ppm (BMCL_HEC_ of 0.07 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 13
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.002 ppm was derived for 1,1,2-trichloroethane based on an increase in the incidence of vacuolization/microcyst formation in the olfactory epithelium of male and female rats exposed to 40 ppm 1,1,2-trichloroethane 6 hours/day, 5 days/week for 13 weeks (Kirkpatrick 2002). The MRL is based on a BMCL_10_ of 3.15 ppm, which was adjusted to continuous duration exposure, converted to a human equivalent concentration (BMCL_HEC_) of 0.07 ppm, and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability).

Selection of the Critical Effect: Only one study evaluated intermediate-duration inhalation toxicity of 1,1,2-trichloroethane (Kirkpatrick 2002). This study identified two targets of toxicity: the respiratory tract and the liver.

Based on a comparison of the lowest LOAEL for these endpoints, the respiratory tract appears to be the most sensitive target of toxicity. At concentrations of 40 and 100 ppm, significantly increased incidences of atrophy and vacuolization/microcyst formation of the olfactory epithelium were observed in male and female rats; the incidence of respiratory epithelial metaplasia of the olfactory epithelium was also significantly increased at 100 ppm (Kirkpatrick 2002). The incidence of these respiratory effects was not significantly increased at 15 ppm relative to controls. A significantly increased incidence of liver effects (namely hepatocellular vacuolization) was seen in the same study at 100 ppm only. Although increased cholesterol was noted in female rats exposed at concentrations as low as 40 ppm, the toxicological significance of this effect is unclear in the absence of effects on other serum chemistry parameters (AST, ALT) and liver weight, and the small magnitude of change in this parameter (within 20% of control values at all concentrations).

Selection of the Principal Study: Kirkpatrick (2002) was selected as the principal study because it was the only study that evaluated the toxicity of 1,1,2-trichloroethane following intermediate-duration exposure.

Summary of the Principal Study:

Kirkpatrick DT. 2002. A 90-day inhalation toxicity study of 1,1,2-trichloroethane (1,1,2-TCE) in rats (with satellite groups for pharmacokinetic evaluations in rats and mice) WIL Research Laboratories, Inc. HAP Task Force. EPA-HQ-OPPT-2002-0046-0003. WIL-417002. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2002-0046-0003 .

Fischer 344 CDF Crl:BR rats (10/sex/group) were exposed whole-body to 1,1,2-trichloroethane (purity 99.5%) as a vapor at 0, 15, 40, and 100 ppm 6 hours/day, 5 days/week for 13 weeks. Rats were monitored for mortality and clinical signs of toxicity. Food consumption and body weights were measured weekly. Hematology and clinical chemistry parameters were evaluated at study termination. Ophthalmological examinations were performed. All animals were subjected to necropsy; organ weights of kidneys, liver, lungs, heart, brain, spleen, adrenals, thymus, thyroid, parathyroid, ovaries, testes, and epididymides were recorded. Comprehensive histopathological examinations were performed on all animals in the high-exposure and control groups; select tissues (liver, kidneys, and respiratory tissues) were examined in all dose groups. Cross-sections of nasal tissues from six nasal levels were prepared using methods described by Morgan (1991).

No significant, exposure-related effects on mortality, clinical signs of toxicity, food consumption, or body weights were reported. There were no significant effects on hematology parameters or on serum chemistry measurements indicative of liver function. Male rats exposed to 100 ppm and female rats exposed to 40 and 100 ppm showed significantly increased levels of serum cholesterol; however, this effect was not strictly dose related. Serum glucose was significantly decreased in 100 ppm females (but not males). Ophthalmological examinations did not reveal differences between exposed rats and controls. No significant, exposure-related macroscopic changes were reported. Rats of both sexes exposed to 40 and 100 ppm showed lesions of the olfactory epithelium of the nasal turbinates, including atrophy and vacuolization/microcyst formation; respiratory epithelial metaplasia was observed at 100 ppm. Hepatocellular vacuolization of minimal in severity occurred in rats of both sexes. Incidences of vacuolization/microcyst formation and atrophy are presented in Table A-3.

Table A-3 Incidence of Nasal Olfactory Epithelial Lesions in F344 Rats Exposed to 1,1,2-Trichloroethane 6 Hours/Day, 5 Days/Week for 13 Weeks

| Exposure concentration (ppm)
| 0 | 15 | 40 | 100
Vacuolization/microcyst formation | 2/20 (10%) | 6/20 (30%) | 10/20 (50%) | 18/20 (90%)
Atrophy | 0/20 (0%) | 0/20 (0%) | 13/20 (65%) | 17/20 (85%)

Source: Kirkpatrick 2002

Selection of the Point of Departure for the MRL: The BMCL_10_ of 3.15 ppm for increased incidence vacuolization/microcyst formation of the olfactory epithelium was selected as the POD for the MRL.

BMD modeling was conducted to identify a POD using exposure concentrations of 0, 15, 40, and 100 ppm. The data were fit to all available dichotomous models in EPA’s Benchmark Software (BMDS version 3.1.2). A BMR of 10% was selected in the absence of data that would support a lower BMR. Adequate model fit was judged by four criteria: (1) goodness-of-fit statistics (p-value >0.1); (2) scaled residual at the data point (except the control) closest to the predefined BMR; (3) BMCL that is not 10 times lower than the lowest non-zero dose; and (4) visual inspection of the dose-response curve. None of the BMD models provided adequate fit to the atrophy data. For vacuolization/microcyst formation of the olfactory epithelium, all models provided adequate fit to the data. The Dichotomous Hill model was not run because the model requires a minimum of five dose levels. The range of BMCL_10_ values was >3-fold; therefore, the model with the lowest BMCL_10_ (Log-Logistic) was selected. Details of the modeling results for vacuolization/microcyst formation are in Table A-4. The fit of the Log-Logistic model is presented in Figure A-1.

Table A-4 Results from BMD Analysis of Vacuolization/Microcyst Formation of the Olfactory Epithelium in Male and Female Fischer 344 Rats Administered 1,1,2-Trichloroethane for 13 Weeks (Kirkpatrick 2002)

Model | BMC_10_ (ppm) | BMCL_10_ (ppm) | p-value^a^ | AIC | Scaled residuals^b^
Model | BMC_10_ (ppm) | BMCL_10_ (ppm) | p-value^a^ | AIC | Dose near BMC | Control group
Dichotomous Hill | 11.45 | 3.15 | 0.336 | 85.10 | 0.52 | −0.19
Gamma^c^ | 9.18 | 4.15 | 0.546 | 84.53 | 0.33 | −0.08
Log-Logistic ^d^ ^,^ ^e^ | 11.45 | 3.15 | 0.336 | 85.10 | 0.52 | −0.19
Multistage Degree 3^f^ | 7.38 | 4.23 | 0.785 | 84.24 | −0.07 | −0.07
Multistage Degree 2^f^ | 8.02 | 4.20 | 0.694 | 84.32 | 0.28 | −0.08
Multistage Degree 1^f^ | 5.72 | 4.06 | 0.709 | 82.88 | 0.14 | 0.14
Weibull^c^ | 9.05 | 4.17 | 0.591 | 84.45 | 0.34 | −0.09
Logistic | 13.34 | 9.85 | 0.675 | 82.99 | 0.51 | −0.66
Log-Probit | 11.42 | 3.49 | 0.339 | 85.08 | 0.48 | −0.14
Probit | 12.97 | 9.90 | 0.677 | 82.98 | 0.49 | −0.65

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals for dose group near the BMC and for the control group

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Recommended model. All models provided adequate fit to the data. The BMCLs for models providing adequate fit were not sufficiently close (differed by >3 fold). Therefore, the model with the lowest BMCL was selected (log-logistic model)

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk)

Figure A-1 Fit of Log-Logistic Model to Data on 1,1,2-Trichloroethane, Incidence of Vacuolization/Microcyst Formation in Male and Female Rats

Two PODs were considered for the MRL:

- BMC_10_ of 11.45 ppm based on increased incidence vacuolization/microcyst formation of the olfactory epithelium
- LOAEL of 40 ppm based on increased incidence atrophy of the olfactory epithelium.

The BMC_10_of 11.45 ppm for increased incidence vacuolization/microcyst formation of the olfactory epithelium was selected as the basis of the MRL since it provided the lowest POD. The corresponding BMCL_10_ was 3.15 ppm.

Intermittent Exposure: The BMCL_10_ of 3.15 was adjusted for intermittent exposure to a continuous exposure scenario according to the following equitation:

BMCL_ADJ_ = BMCL_10_ of 3.15 ppm × ( 6 hours / 24 hours ) × ( 5 days / 7 days ) = 0.056 ppm

Human Equivalent Concentration: The BMCL_ADJ_ of 0.56 ppm was converted to a human equivalent concentration (HEC) of 0.07 ppm using the following equation:

BMCL_HEC_ = BMCL_ADJ_ × RGDR_ET_

where RGDR_ET_ is the extrathoracic regional gas dose ratio (animal:human) for the extrathoracic region. Extrathoracic regional gas doses were calculated for each species as follows: V_E_ (minute volume) ÷ SA_ET_ (surface area of the extrathoracic region); where V_E_ = 137 mL/minute (based on reference body weight for males and females, 0.180 kg) and SA_ET_ = 15 cm^2^ in rats and V_E_ = 13,800 mL/minute and SA_ET_ = 200 cm^2^ in humans (EPA 1994).

BMCL_HEC_ = BMCL_ADJ_ × RGDR_ET_ BMCL_HEC_ = 0.56 ppm × (137 mL / minute ÷ 15 cm^2^) / (13,800 mL / minute ÷ 200 cm^2^) BMCL_HEC_ = 0.56 ppm × 0.13 BMCL_HEC_ = 0.073 ppm

Uncertainty Factor: The BMCL_HEC_ was divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

MRL = BMCL_HEC_ ÷ UFS 0.073 ppm ÷ ( 3 × 10 ) = 0.0024 ≈ 0.002 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Histopathological changes to the olfactory epithelium (necrosis) were observed following acute-duration oral exposure to 1,1,2-trichloroethane (Kirkpatrick 2001).

Agency Contacts (Chemical Manager): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,2-Trichloroethane
CAS Numbers: | 79-00-5
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for 1,1,2-trichloroethane.

Agency Contacts (Chemical Manager): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,2-Trichloroethane
CAS Numbers: | 79-00-5
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.5 mg/kg/day
Critical Effect: | Increased liver enzymes (AST and ALT)
Reference: | Tyson et al. 1983
Point of Departure: | NOAEL of 46 mg/kg
Uncertainty Factor: | 100
LSE Graph Key: | 3
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.5 mg/kg/day was derived for 1,1,2-trichloroethane based on increased liver enzymes (AST and ALT) in male rats administered 1,1,2-trichloroethane via gavage (Tyson et al. 1983). The MRL is based on a NOAEL of 46 mg/kg and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: In an acute toxicity study of male Sprague-Dawley rats administered a single gavage dose of 1,1,2-trichloroethane, a substantial elevation in liver enzymes (AST and ALT) was observed 48 hours after administration of approximately 92 mg/kg; no increases in these liver enzymes were observed at 46 mg/kg compared to controls (Tyson et al. 1983). The increase in liver enzymes was observed at a lower dose than effects on liver histopathology (congestion, fatty degeneration, and edema) in dogs administered 433 mg/kg/day (Wright and Schaffer 1932), or increased enzymatic activity of ALT, sorbital dehydrogenase [SDH], or glutamate dehydrogenase in Wistar rats administered 667 mg/kg/day (Xia and Yu 1992).

NOAEL and LOAEL values for acute-duration oral exposure are summarized in Table A-5. The LOAEL for increased liver enzymes is lower than LOAELs identified for other acute effects. Gait impairment and decreased body weight gain (males) were observed at 200 mg/kg in a well-conducted acute neurotoxicity study (Beck 2004). Although motor activity was reported to be significantly decreased in males at 55 mg/kg in this study (Beck 2004), this effect was transient (observed during only a small window of time, without significant effects on mean total or ambulatory counts), showed high variability, and was not consistent across sexes (nonsignificant increases in motor activity counts were observed in females during the same time period). Several other acute toxicity studies of mice and dogs with 1,1,2-trichloroethane also reported neurological effects at doses higher than that eliciting liver effects in the Tyson et al. (1983) study. Results included sedation in male mice at ≥450 mg/kg/day (White et al. 1985), taste aversion in male mice at ≥100 mg/kg/day (toxicological significance uncertain; Kallman et al. 1983), motor impairment in mice at 128 mg/kg/day (Borzelleca 1983), and drowsiness in dogs at ≥289 mg/kg/day (Wright and Schaffer 1932). LOAELs for effects on other target systems identified in acute-duration toxicity studies (effects on body weight and the gastrointestinal and renal systems) were higher than the LOAEL for increased liver enzymes in male rats.

Selection of the Principal Study: The Tyson et al. (1983) study was selected as the principal study for deriving an acute-duration oral MRL for 1,1,2-trichloroethane because it identified the lowest reliable LOAEL for acute effects.

Table A-5 Summary of Relevant NOAEL and LOAEL Values Following Acute-Duration Oral Exposure to 1,1,2-Trichloroethane

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
Crl:CD(SD) IGS rat | Once | 95 | 200 | Gait impairment on study day 0 (4/14 males; 5/12 females; 0/12 controls) | Beck 2004
CD-1 mouse | Once | 30 | 100 | Taste aversion | Kallman et al. 1983
CD-1 mouse | Once | ND | 128 | Motor impairment | Borzelleca 1983
Dog (NS) | Once | 144 | 289 | Drowsiness | Wright and Schaffer 1932
CD-1 mouse | Once | ND | 450 | Sedation | White et al. 1985
Liver effects
Sprague-Dawley rat | Once | 46 | 92 | Increased AST and ALT | Tyson et al. 1983
Dog (NS) | Once | 144 | 433 | Mild congestion, fatty degeneration and edema | Wright and Schaffer 1932
Wistar rat | Once | ND | 667 | Increased ALT, SDH, glutamate dehydrogenase | Xia and Yu 1992
Other effects
Dog (NS) | Once | ND | 144 | Mild congestion and cloudy swelling of the kidneys | Wright and Schaffer 1932
Wistar-derived Alderley Park rat | 7 days | ND | 180 | Decreased body weight gain | Platt and Cockrill 1969
Crl:CD(SD) IGS rat | Once | 95 | 200 | Decreased body weight gain in males | Beck 2004
Dog (NS) | Once | 144 | 433 | Mild congestion and inflammation of the gastrointestinal tract | Wright and Schaffer 1932

ALT = alanine aminotransferase; AST = aspartate aminotransferase; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified; SDH = sorbitol dehydrogenase

Tyson CA, Hawk-Prather K, Story DL, . 1983. Correlations of in vitro and in vivo hepatotoxicity for five haloalkanes. Toxicol Appl Pharmacol 70:289–302 6623471 .

In an acute toxicity study, male Sprague-Dawley rats (number per group not specified) were administered 1,1,2-trichloroethane as a single dose via gavage. Data were presented graphically in Figure 9 of the study report. Doses were estimated using GrabIt! Software; doses were approximately 0, 0.34, 0.69, and 1.71 mmol/kg, or 0, 46, 92, and 228 mg/kg (based on molecular weight of 133.4 g/mol for 1,1,2-trichloroethane). The enzymatic activities of ALT and AST were evaluated 6, 24, and/or 48 hours after dosing. No other evaluations of hepatic toxicity were reported.

Enzyme levels (mean±standard deviation) for the control group were reported in the text of the study. ALT and AST in untreated controls were 45±10 and 83±21 U/L, respectively at 6, 24, and 48 hours post-exposure; the number of animals evaluated at each of these time points was 3, 5 and 5, respectively. Based on data from Figure 9 of the study report (obtained via GrabIt! Software or embedded in the figure), 48 hours after treatment at 92 and 228 mg/kg, ALT and AST activities were increased by approximately 7.2- and 15-fold, respectively, compared to controls (statistical analyses were not performed); values are summarized in Table A-6. In the 46 mg/kg group, there was no significant change in liver enzymes.

Table A-6 Effects on Liver Enzymes in Male Sprague-Dawley Rats Exposed to 1,1,2-Trichloroethane as a Single Gavage Dose^a^

Effect | Dose (mg/kg)
Effect | 0 | 46 | 92 | 228
ALT (U/L); 24 hours | 45±10^b^ | 29 | 60 | 1,811^c^
ALT (U/L); 48 hours | | 38 | 323 | 3,975^c^
AST (U/L); 24 hours | 83±21^b^ | 72 | 163 | 4,428^c^
AST (U/L); 48 hours | | 77 | 1,248^c^ | 8,781^c^

a Data for administered doses and enzyme levels were obtained from Figure 9 of the study using GrabIt! Software.

b Mean±standard deviation at 6, 24, and 48 hours (as reported in the text of the study).

c Measured values as reported in Figure 9 of the study.

ALT = alanine aminotransferase; AST = aspartate aminotransferase

Source: Tyson et al. 1983

Selection of the Point of Departure for the MRL: The NOAEL of 46 mg/kg was selected as the POD for deriving an acute-duration oral MRL for 1,1,2-trichloroethane. BMD modeling could not be conducted because information required to perform modeling (e.g., animal numbers, measures of variance) was not reported.

Uncertainty Factor: The NOAEL of 46 mg/kg was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

MRL = NOAEL ÷ UFS 46 mg / kg ÷ ( 10 × 10 ) = 0.46 mg / kg / day ≈ 0.5 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: In male mice administered 1,1,2-trichloroethane via a single intraperitoneal injection, the reported ED_50_ values for increased serum ALT were approximately 144 mg/kg (based on the ED_50_ reported in mL/kg) and 240 mg/kg (based on the ED_50_ reported in mmol/kg) (Klaassen and Plaa 1966). No non-neoplastic liver lesions (based on histopathological examinations) were observed in rats treated at up to 92 mg/kg/day or mice treated at up to 390 mg/kg/day via gavage for 78 weeks (NCI 1978).

Agency Contacts (Chemical Manager): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,2-Trichloroethane
CAS Numbers: | 79-00-5
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.04 mg/kg/day
Critical Effect: | Immunotoxicity (decreased hemagglutination titers) and mild hepatotoxicity
Reference: | Sanders et al. 1985
Point of Departure: | NOAEL of 3.9 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 18
Species: | Mouse

MRL Summary: An intermediate-duration oral MRL of 0.04 mg/kg/day was derived for 1,1,2-trichloroethane based on immunological effects observed in male and female mice exposed to 44 mg/kg/day 1,1,2-trichloroethane in drinking water for 90 days (Sanders et al. 1985). The MRL is based on a NOAEL of 3.9 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effects: In an intermediate-duration oral toxicity study, male and female mice administered 1,1,2-trichloroethane in the drinking water for 90 days showed dose-related effects on the humoral immune system (a reduction in hemagglutination titers) at ≥44 mg/kg/day (Sanders et al. 1985). NOAEL and LOAEL values for reduced hemagglutination titers were identified as 3.9 and 44 mg/kg/day, respectively, in females and 4.4 and 46 mg/kg/day, respectively, in males. In addition, the ability of thioglycolate-recruited peritoneal exudate cells (PECs) to phagocytize sRBCs was significantly reduced in males at 305 mg/kg/day. Cell-mediated immunity was unaffected in both sexes. Immune effects were observed at lower doses than effects on body weight (≥69 mg/kg/day; Mylchreest 2006; Story et al. 1986; White et al. 1985; Wilson 2005), developmental effects (82.2 mg/kg/day; Mylchreest 2006), and increased liver weight (384 mg/kg/day; White et al.1985). No other intermediate-duration oral toxicity studies evaluated immune function. NOAEL and LOAEL values for intermediate-duration oral exposure are summarized in Table A-7.

Table A-7 Summary of Relevant NOAEL and LOAEL Values Following Intermediate-Duration Oral Exposure to 1,1,2-Trichloroethane

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
CD-1 mouse | 90 days | 3.9 F; 4.4 M | 44 F; 46 M | Decreased hemagglutination titers | Sanders et al. 1985
Osborne-Mendel rat | 5 days/week, 7 weeks | ND | 69 | Decreased body weight | Story et al. 1986
Crl:CD(SD) IGS rat | Two generations | 40.6 | 82.2 | Decreased body weight gain during gestation (P1 and F1 females) | Mylchreest 2006
Crl:CD(SD) IGS rat | Two generations | 40.6 | 82.2 | Decreased F1 and F2 pup weights (PNDs 4–21) | Mylchreest 2006
Crl:CD(SD) IGS rat | GDs 6–20 | 48 | 111 | Decreased body weight gain | Wilson 2005
CD-1 mouse | 90 days | 46 M | 305 M | Decreased body weight in males | White et al. 1985
CD-1 mouse | 90 days | 44 F | 384 F | Increased relative and absolute liver weight | White et al. 1985

F = female; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; M = male; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day

Selection of the Principal Study: The intermediate-duration database identifies the immune system as the most sensitive target of 1,1,2-trichloroethane. The Sanders et al. (1985) study was selected as the principal study for deriving an intermediate-duration oral MRL for 1,1,2-trichloroethane because it identified the lowest LOAEL of 44 mg/kg/day (NOAEL of 3.9 mg/kg/day).

Summary of the Principal Study:

Sanders VM, White KL, Shopp Jr GM, . 1985. Humoral and cell-mediated immune status of mice exposed to 1,1,2-trichloroethane. Drug Chem Toxicol 8(5):357–372 4064948 .

Sanders et al. (1985) administered 1,1,2-trichloroethane (purity 95%) at 0, 20, 200, and 2,000 ppm in the drinking water to male and female CD-1 mice (time-weighted average doses of 0, 4.4, 46, and 305 mg/kg/day for males and 0, 3.9, 44, and 384 mg/kg/day for females based on measured water intake and body weight data were calculated by study authors) for 90 days. Immunological endpoints were examined in 8–25 mice/sex/group. Humoral immune status was assessed by measuring the numbers of splenic AFCs to sRBCs (on peak day 4 and on day 5), hemagglutination titers, and the response of splenic lymphocytes to lipopolysaccharide (LPS; a B-cell mitogen) and concanavalin A (con A; a T-cell mitogen). Cell-mediated immune function parameters included delayed-type hypersensitivity (DTH) and popliteal lymph node responses to sRBCs. Additional immunological endpoints evaluated were the ability of macrophages of the reticuloendothelial system (RES) to clear sRBC from the vascular system and distribute them to the liver, spleen, thymus, lungs, and kidneys; numbers of PECs (recruitable, adherent, chemotaxis) and their ability to phagocytize sRBCs, and DNA synthesis in the bone marrow.

Sanders et al. (1985) found that hemagglutination titers (expressed as log_2_ titers) were significantly decreased in male and female mice at ≥44 mg/kg/day relative to controls. Based on the transformation of log_2_ titers to antibody dilutions, hemagglutination levels were decreased 47 and 59% in males treated at 46 and 305 mg/kg/day, respectively, and 40 and 45% in females treated at 44 and 384 mg/kg/day, respectively. Changes in the activity of fixed macrophages of the RES to clear and distribute sRBCs (observed in females only) were not considered treatment-related due to variations in the direction and magnitude of effects. In male mice treated at 305 mg/kg/day, PECs showed a reduced ability to phagocytize sRBCs (55–56% lower than controls over a 20–45-minute period). No effects on the humoral immune response based on AFC counts or the response of splenic lymphocytes to B-cell and T-cell mitogens were observed, and cell-mediated immune responses were unaffected by treatment. No significant time- or dose-related effects on bone marrow DNA synthesis were observed.

Selection of the Point of Departure for the MRL: The NOAEL of 3.9 mg/kg/day was selected as the POD for deriving an intermediate-duration oral MRL for 1,1,2-trichloroethane. These data were not amenable to BMD modeling because information required to perform modeling (e.g., animal numbers) was not reported.

Uncertainty Factor: The NOAEL of 3.9 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

MRL = NOAEL ÷ UFs 3.9 mg / kg / day ÷ 100 = 0.039 mg / kg / day ≈ 0.04 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: An acute-duration study in mice exposed to 1,1,2-trichloroethane in drinking water at up to 38 mg/kg/day for 14 days did not identify any significant treatment-related effects on humoral or cell-mediated immunity; this study used lower doses than those used in the intermediate-duration study and did not evaluate a comprehensive set of immunological parameters (Sanders et al. 1985). A 90-day drinking water study in mice reported an 18% increase in relative spleen weight in females (but not males); no increase in thymus weight was observed in males or females (White et al. 1985). However, immune function was not examined in this study. The available chronic-duration studies did not identify histopathological changes to the spleen, lymph nodes, bone marrow, or thymus of rats (treated at up to 92 mg/kg/day for 78 weeks) or mice (treated at up to 390 mg/kg/day for 78 weeks); however, immune system function was not evaluated (NCI 1978).

Agency Contacts (Chemical Managers): Jennifer Przybyla

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,2-Trichloroethane
CAS Numbers: | 79-00-5
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No chronic-duration oral MRL was derived for 1,1,2-trichloroethane because the available data are insufficient for identifying a critical effect. No adverse effects were identified in rats administered 1,1,2-trichloroethane via gavage at doses up to 92 mg/kg/day 5 days/week for 78 weeks (NCI 1978). The only adverse effects found in mice administered 1,1,2-trichloroethane via gavage at up to 390 mg/kg/day 5 days/week for 78 weeks were increased mortality at 195 mg/kg/day, an increased incidence of hepatocellular carcinomas at ≥195 mg/kg/day, and adrenal pheochromocytomas at 390 mg/kg/day (NCI 1978).

Agency Contacts (Chemical Manager): Jennifer Przybyla