# 9 REFERENCES

* Not cited in text

ACGIH. 2001. 1,2,4-Trichlorobenzene. In: Documentation of the threshold limit values. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2009. 1,2,4-Trichlorobenzene. In: 2009 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adebusoye SA, Picardal FW, Ilori MO, . 2007. Aerobic degradation of di- and trichlorobenzenes by two bacteria isolated from polluted tropical soils. Chemosphere 66(10):1939–1946.16962633
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 2005. Toxicological profile for hexachlorocyclohexanes (update). Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp43.pdf. October 21, 2010.
AIHA. 2010. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. http://www.aiha.org/foundations/GuidelineDevelopment/ERPG/Documents/ERPG_Values2010.pdf. June 17, 2010.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Ariyoshi T, Ideguchi K, Iwasaki K, . 1975a. Relationship between chemical structure and activity. II. Influences of isomers in dichlorobenzene, trichlorobenzene, and tetrachlorobenzene on the activities of drug-metabolizing enzymes. Chem Pharm Bull (Tokyo) 23(4):824–830.1182864
Ariyoshi T, Ideguchi K, Iwasaki K, . 1975b. Relationship between chemical structure and activity. III. Dose-response or time-course of induction in microsomal enzymes following treatment with 1,2,4-trichlorobenzene. Chem Pharm Bull (Tokyo) 23(4):831–836.1182865
Arnot JA, Gobas FAPC. 2006. A review of bioconcentration factor (BCF) and bioaccumulation factor (BAF) assessments for organic chemicals in aquatic organisms. Environ Rev 14:257–297.
Bakke JE, Huwe JK, Mulford DJ, . 1992. Metabolism of 1,2,4-trichlorobenzene in rats: Examination of thiol formation. Xenobiotica 22(2):199–210.1632109
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Beck AJ, Alcock RE, Wilson SC, . 1995. Long-term persistence of organic chemicals in sewage sludge-amended agricultural land a soil quality perspective. In: Sparks DL, ed. Advances in agronomy. Vol. 55. San Diego, CA: Academic Press, Inc., 345–391.
Beer F, Gugel A, Martin KR, . 1997. High-yield reactive extraction of giant fullerenes from soot. J Mater Chem 7(8):1327–1330.
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Bharati K, Padhy S, Adhya TK. 1998. Accelerated biodegradation of gamma-hexachlorocyclohexane (γ-HCH) in a flooded alluvial soil retreated with γ-HCH or its metabolite 1,2,4-trichlorobenzene (TCB). Bull Environ Contam Toxicol 60(6):858–863.9606261
*Black WD, Valli VE, Ruddick JA, . 1988. Assessment of teratogenic potential of 1,2,3- 1,2,4- and 1,3,5-trichlorobenzenes in rats. Bull Environ Contam Toxicol 41(5):719–726.3233372
Bogaards JJ, van Ommen B, Wolf CR, . 1995. Human cytochrome P450 enzyme selectivities in the oxidation of chlorinated benzenes. Toxicol Appl Pharmacol 132(1):44–52.7747284
Bosma TN, Ballemans EM, Hoekstra NK, . 1996. Biotransformation of organics in soil columns and an infiltration area. Ground Water 34(1):49–56.
Bristol DW, Crist HL, Lewis RG, . 1982. Chemical analysis of human blood for assessment of environmental exposure to semivolatile organochlorine chemical contaminants. J Anal Toxicol 6(6):269–275.6819409
Brown SK, Sim MR, Abramson MJ, . 1994. Concentrations of volatile organic compounds in indoor air-A review. Indoor Air 4:123–134.
*Brown VK, Muir C, Thorpe E. 1969. The acute toxicity and skin irritant properties of 1,2,4-trichlorobenzene. Ann Occup Hyg 12(4):209–212.5361142
Brunsbach FR, Reineke W. 1994. Degradation of chlorobenzenes in soil slurry by a specialized organism. Appl Microbiol Biotechnol 42(2–3):415–420.7765781
Burkhard LP, Sheedy BR, McCauley DJ, . 1997. Bioaccumulation factors for chlorinated benzenes, chlorinated butadienes and hexachloroethane. Environ Toxicol Chem 16(8):1677–1686.
*Carlson GP, Tardiff RG. 1976. Effect of chlorinated benzenes on the metabolism of foreign organic compounds. Toxicol Appl Pharmacol 36:383–394.1273854
Carmichael LM, Smith TG, Pardieck DL. 1999. Organic compounds in the environment. J Environ Qual 28:888–897.
*Chernoff N, Kavlock RJ. 1983. A teratology test system which utilizes postnatal growth and viability in the mouse. Environ Sci Res 27:417–427.
Choudhry GG, Webster RB, Hutzinger O. 1986. Environmental significant photochemistry of chlorinated benzenes and their derivatives in aquatic systems. Toxicol Environ Chem 13:27–83.
Chu I, Murdoch DJ, Villeneuve DC, . 1987. Tissue distribution and elimination of trichlorobenzenes in the rat. J Environ Sci Health B 22(4):439–454.3655190
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*CMA. 1989. A three month dietary range-finding study of 1,2,4-trichlorobenzene in rats final report with letter dated 2/2/89 from Chemical Manufacturers Association. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. EPA Document No. 40-98201006. OTS0523023.
*Coate WB, Lewis R, Busey WM, . 1977. Chronic, inhalation exposure of rats, rabbits, and monkeys to 1,2,4-trichlorobenzene. Arch Environ Health 32(6):249–255.412471
*Côté M, Chu I, Villeneuve DC, . 1988. Trichlorobenzenes results of a thirteen week feeding study in the rat. Drug Chem Toxicol 11(1):11–28.3378508
Davies K. 1988. Concentrations and dietary intake of selected organochlorines, including PBCs, PCDDs and PCDFs in fresh food composites grown in Ontario, Canada. Chemosphere 17(2)263–276.
den Besten C, Smink MC, de Vries EJ, . 1991. Metabolic activation of 1,2,4-trichlorobenzene and pentachlorobenzene by rat liver microsomes: A major role for quinone metabolites. Toxicol Appl Pharmacol 108(2):223–233.2017752
Ding W, Aldous KM, Briggs RG, . 1992. Application of multivariate statistical analysis to evaluate local sources of chlorobenzene congeners in soil samples. Chemosphere 25(5):675–690.
DOE. 2010a. 1,2,3-Trichlorobenzene. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 25 for Chemicals of Concern (08/2009). U.S. Department of Energy. http://www.atlintl.com/DOE/teels/teel/complete.asp. June 21, 2010.
DOE. 2010b. 1,2,4-Trichlorobenzene. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 25 for Chemicals of Concern (08/2009). U.S. Department of Energy. http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. June 16, 2010.
*Dow Chemical. 1956. Results of range finding toxicological tests on 1,2,3-trichlorobenzene. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA Document No. 878214849. OTS0206686.
Dow Chemical. 1981. Comprehensive industrial hygiene survey for the Michigan division organic chemicals production department distribution center and warehouse, and buildings, March, 1979, to December, 19809. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA Document No. 878214804. OTS0206686.
*E.I. Dupont. 1971. Primary skin irritation and sensitization tests on guinea pigs. E.I. Dupont de Nemours & Co Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA Document No. 878220477. OTS0215045.
EPA. 1976. Follow-up study of the distribution and fate of polychlorinated biphenyls and benzenes in soil and ground water samples after an accidental spill of transformer fluid. Atlanta, GA: U.S. Environmental Protection Agency.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency. Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
EPA. 1991. Alpha _2u_-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat. Washington, DC: U.S. Environmental Protection Agency. Risk Assessment Forum. EPA625391019F.
EPA. 1994. Method 8121: Chlorinated hydrocarbons by gas chromatography: Capillary column technique. Test methods for evaluating solid waste. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/waste/hazard/testmethods/sw846/pdfs/8121.pdf. June 18, 2010.
EPA. 1996a. Index I. Master testing list. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/chemtest/pubs/index1.pdf. June 18, 2010.
EPA. 1996b. Method 8260B: Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). In: Test methods for evaluating solid waste. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/waste/hazard/testmethods/sw846/pdfs/8260b.pdf. June 18, 2010.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency. Risk Assessment Forum.
EPA. 1998a. Announcement of the drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 63(40):10274–10287. http://www.gpoaccess.gov/fr/index.html. June 17, 2010.
EPA. 1998b. Notice of availability of draft RCRA waste minimization PBT chemical list. U.S. Environmental Protection Agency. Fed Regist 63(216):60332–60343. http://www.gpoaccess.gov/fr/index.html. June 17, 2010.
EPA. 1998c. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency. Office of Pollution Prevention and Toxics.
EPA. 1999. Compendium of methods for the determination of toxic organic compounds in ambient air. Second edition. Compendium method TO-14A. Determination of volatile organic compounds (VOCs) in ambient air using specially prepared canisters with subsequent analysis by gas chromatography. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010b.
EPA. 2000a. Benchmark dose technical guidance document. Washington, DC: Environmental Protection Agency. EPA600R000-01. http://www.epa.gov/ncea/pdfs/bmds/BMD-External_10_13_2000.pdf. October 21, 2010.
EPA. 2000b. National air pollutant emission trends, 1900-1998. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA454R00002.
EPA. 2005a. Guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA630P030.
EPA. 2005b. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006a. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water. http://www.epa.gov/waterscience/criteria/wqcriteria.html. May 11, 2009.
EPA. 2006b. Title 42-The public health and welfare. Chapter 85-Air pollution prevention and control. Sec. 7412. Hazardous air pollutants. U.S. Environmental Protection Agency. United States Code 42 USC 7412 http://www.gpoaccess.gov/uscode/index.html. June 18, 2010.
EPA. 2007. Method 8270D: Semivolatile organic compounds by gas chromatography/mass spectrometry (GC/MS). In: Test methods for evaluating solid waste. SW-846. U.S. Environmental Protection Agency. http://www.epa.gov/waste/hazard/testmethods/sw846/pdfs/8270d.pdf. July 27, 2010.
EPA. 2009e. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. Office of Ground Water and Drinking Water. EPA816F09004. http://www.epa.gov/safewater/consumer/pdf/mcl.pdf. August 7, 2009.
EPA. 2009d. 2009 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. Office of Water. EPA822R09011. http://epa.gov/waterscience/criteria/drinking/dwstandards2009.pdf. December 17, 2009.
EPA. 2009g. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009h. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009i. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.epa.gov/lawsregs/search/40cfr.html. May 11, 2009.
EPA. 2009j. Table 1 to § 68.130—List of regulated toxic substances and threshold quantities for accidental release prevention. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 68.130. http://edocket.access.gpo.gov/cfr_2009/julqtr/pdf/40cfr68.130.pdf. June 17, 2010.
EPA. 2009k. Table 2 to subpart F of part 63—Organic hazardous air pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 63, Table 2 to Subpart F. http://edocket.access.gpo.gov/cfr_2009/julqtr/pdf/40cfr63.107.pdf. June 18, 2010.
EPA. 2009l. Table 117.3 - Reportable quantities of hazardous substances designated persuant to section 311 of the clean water act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://edocket.access.gpo.gov/cfr_2009/julqtr/pdf/40cfr117.3.pdf. June 18, 2010.
EPA. 2009m. Toxic substances control act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009a. Appendix IX to part 264—Ground-water monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264, Appendix IX. http://edocket.access.gpo.gov/cfr_2009/julqtr/pdf/40cfr264AppIX.pdf. June 18, 2010.
EPA. 2009b. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30. http://edocket.access.gpo.gov/cfr_2009/julqtr/pdf/40cfr712.30.pdf. June 18, 2010.
EPA. 2009c. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://edocket.access.gpo.gov/cfr_2009/julqtr/pdf/40cfr116.4.pdf. June 18, 2010.
EPA. 2009f. Subpart VV—Standards of performance for equipment leaks of VOC in the synthetic organic chemicals manufacturing industry for which construction, reconstruction, or modification commenced after January 5, 1981, and on or before November 7, 2006. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 60 Subpart VV. http://www.gpoaccess.gov/cfr/index.html. June 18, 2010.
EPA. 2010a. Air data. Monitor values report-hazardous air pollutants. 1,2,4-Trichlorobenzene. U.S. Environmental Protection Agency. http://iaspub.epa.gov/airsdata/ADHAP.monvals?geotype=us&geocode=usa&geoinfo=us%7Eusa%7EUnited+States&pol=45810&year=2008&fld=monid&fld=address&fld=city&fld=county&fld=stabbr&fld=regn&rpp=165&page=1&sort=a9&fmt=. June 18, 2010.
EPA. 2010b. Non-confidential 2006 IUR records by chemical, including manufacturing, processing and use information. CAS: 87-61-6. U.S. Environmental Protection Agency. http://cfpub.epa.gov/iursearch/2006_iur_companyinfo.cfm?chemid=1643&outchem=both. June 18, 2010.
EPA. 2010d. Acute exposure guideline levels (AEGLs). Second AEGL chemical priority list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/pubs/priority_2.htm. June 16, 2010.
*EPA. 2010c. Compiled AEGL values. AEGL Chemicals. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_may2010.pdf. June 18, 2010.
EPA. 2010e. Non-confidential 2006 IUR records by chemical, including manufacturing, processing and use information. CAS: 120-82-1. U.S. Environmental Protection Agency. http://cfpub.epa.gov/iursearch/2006_iur_companyinfo.cfm?chemid=3659&outchem=both. June 18, 2010.
EPA. 2014. National Emissions Inventory (NEI) air pollution trends data. Technology Transfer Network Clearinghouse for Inventories and Emissions Factors. U.S. Environmental Protection Agency. http://www.epa.gov/ttnchie1/trends/. November 14, 2014.
Ethyl Corp. 1975. In vitro microbiological mutagenicity studies of ethyl compounds. Ethyl Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA Document No. 86-870001694. OTS0515770.
Euro Chlor. 2002. Euro Chlor risk assessment for the marine environment OSPARCOM region-North Sea. 1,2,4-Trichlorobenzene. Euro Clor. http://www.eurochlor.org/upload/documents/document82.pdf. June 18, 2010.
European Communities. 2003. European Union risk assessment report. 1,2,4-Trichlorobenzene. http://ecb.jrc.ec.europa.eu/documents/Existing-Chemicals/RISK_ASSESSMENT/REPORT/trichlorobenzenereport039.pdf. June 18, 2010.
Fathepure BZ, Tiedje JM, Boyd SA. 1988. Reductive dechlorination of hexachlorobenzene to tri- and dichlorobenzenes in anaerobic sewage sludge. Appl Environ Microbiol 54(2):327–330.3355129
FDA. 2010a. Bottled water. U.S. Food and Drug Administration. 21 CFR 165.110 http://edocket.access.gpo.gov/cfr_2010/aprqtr/pdf/21cfr165.110.pdf. June 18, 2010.
FDA. 2010b. Everything added to food in the United States (EAFUS). U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnNavigation.cfm?rpt=eafusListing. June 18, 2010.
FEDRIP. 2010. Trichlorobenzenes. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17(5):617–636.2337085
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Fox ME, Carey JH, Oliver BG. 1983. Compartmental distribution of organochlorine contaminants in the Niagara River and the western basin of Lake Ontario. J Great Lakes Res 9(2):287–294.
Fratello G, Marchini S, Zucco F, . 1997. Cytotoxicity of halogenated benzenes and its relationship with logP. Toxicol In Vitro 11:673–677.20654369
*Gage JC. 1970. The subacute inhalation toxicity of 109 industrial chemicals. Br J Ind Med 27:1–18.5418916
Garrett NE, Lewtas J. 1983. Cellular toxicity in Chinese hamster ovary cell cultures: 1. Analysis of cytotoxicity end points for 29 priority pollutants. Environ Res 32(2):455–465.6641673
Girard R, Tolot F, Bourret J. 1969. Serious blood disorders and exposure to chlorine derivatives of benzene (a report of 7 cases). J Med Lyon 50(1164):771–773.5788739
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Suppl 2):65–71.7902273
*Gray LE, Kavlock RJ. 1984. An extended evaluation of an in vivo teratology screen utilizing postnatal growth and viability in the mouse. Teratog Carcinog Mutagen 4:403–426.6150557
*Gray LE, Kavlock RJ, Ostby J, . 1986. An evaluation of figure-eight maze activity and general behavioral development following prenatal exposure to forty chemicals: Effects of cytosine arabinoside, dinocap, nitrofen, and vitamin A. Neurotoxicology 7:449–462.3537858
Grosjean D. 1991. Atmospheric fate of toxic aromatic compounds. Sci Total Environ 100:367–414.
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):3–142.
HazDat. 2007. Trichlorobenzenes. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Heitmuller PT, Clark JR. 1989. Bioaccumulation of 1,2,4-trichlorobenzene from food and water sources by spot (Leiostomua xanthurus). Aquat Toxicol Haz Assess 12:261–269.
*Hiles RA. 1989. 13-Week toxicity study with 1,2,4-trichlorobenzene in mice with. Final report with letter dated 4/10/89. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. EPA 4089201005. OTS0523025.
Hoekstra PF, Braune BM, O’Hara TM, . 2003. Organochlorine contaminant and stable isotope profiles in Arctic fox (Alopex lagopus) from the Alaskan and Canadian Arctic. Environ Pollut 122:423–433.12547532
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
HSDB. 2010. 1,2,3-Trichlorobenzene, 1,2,4-trichlorobenzene, and 1,3,5-trichlorobenzene. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 22, 2010.
IARC. 2009. Agents reviewed by the IARC monographs. Volumes 1-100A. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. May 16, 2010.
IPCS. 1991. Chlorobenzenes other than hexachlorobenzene. Environmental Health Criteria 128. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc128.htm. July 27, 2010.
*IRIS. 2010. 1,2,4-Trichlorobenzene. Washington, DC: Integrated Risk Information System. Environmental Protection Agency. http://cfpub.epa.gov/ncea/iris/index.cfm?fuseaction=iris.showSubstanceList. June 16, 2010.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190(1):3–16.6769537
Jondorf WF, Parke DV, Williams A. 1955. Studies in detoxification. 66. The metabolism of halogenbenzenes, 1,2,3-, 1,2,4-, and 1,3,5-trichlorobenzenes. Biochem J 61:512–521.13269390
Jonker MTO, Smedes F. 2000. Preferential sorption of planar contaminants in sediments from Lake Ketelmeer, the Netherlands. Environ Sci Technol 34:1620–1626.
*Jorgenson TA, Simmon VF, Dilley JV. 1976. Final report. Preliminary toxicological studies of TATB, TCB, and TCTNB. Occidental Chem Corp. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. EPA Document No. 88920001151. OTS0537049.
Kato Y, Kimura R. 2002. The contribution of 2,3,5-trichlorophenyl methyl sulfone, a metabolite of 1,2,4-trichlorobenzene, to the delta-aminolevulinic acid synthetase induction by 1,2,4-trichlorobenzene in rat liver. Chemosphere 47(1):1–7.11996131
Kato Y, Kogure T, Sato M, . 1988. Effects of chlorobenzenes and their methyl sulfone metabolites on microsomal enzymes associated with drug metabolism in rat liver. J Pharmacobiodyn 11(11):758–762.3148707
Kato Y, Yamada S, Sato M, . 1993. Role of 2,3,5-trichlorophenyl methyl sulfone, a metabolite of 1,2,4-trichlorobenzene, in the induction of hepatic microsomal drug-metabolizing enzymes by 1,2,4-trichlorobenzene in rats. Toxicol Appl Pharmacol 122(2):214–221.8212004
Kielb CL, Pantea CI, Gensburg LJ, . 2010. Concentrations of selected organochlorines and chlorobenzenes in the serum of former Love Canal residents, Niagara Falls, New York. Environ Res 110(3):220–225.20117765
*Kitchin KT, Ebron MT. 1983. Maternal hepatic and embryonic effects of 1,2,4-trichlorobenzene in the rat. Environ Res 31(2):362–373.6884296
*Kociba RJ, Leong BK, Hefner RE, Jr. 1981. Subchronic toxicity study of 1,2,4-trichlorobenzene in the rat, rabbit and beagle dog. Drug Chem Toxicol 4(3):229–249.7338204
Kohli J, Weisgerber I, Klein W, . 1976. Contributions to ecological chemistry CVII1. Fate of lindane-14C in lettuce, endives and soil under outdoor conditions. J Environ Sci Health B 11(1):23–32.58883
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case Studies, Mechanisms, and Novel Approaches. San Diego, CA: Academic Press, 399–437.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554.
Lawlor T, Haworth SR, Voytek P. 1979. Evaluation of the genetic activity of nine chlorinated phenols, seven chlorinated benzenes and three chlorinated hexanes [Abstract]. Environ Mutagen 1:143.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lingg RD, Kaylor WH, Pyle SM, . 1982. Comparative metabolism of 1,2,4-trichlorobenzene in the rat and rhesus monkey. Drug Metab Dispos 10(2):134–141.6124398
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lopes TJ, Furlong ET. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States, 1992-1995. Environ Toxicol Chem 20:727–737.11345447
MacLeod M, Mackay D. 1999. An assessment of the environmental fate and exposure of benzene and the chlorobenzenes in Canada. Chemosphere 38(8):1777–1796.10101848
Marinucci AC, Bartha R. 1979. Biodegradation of 1,2,3- and 1,2,4-trichlorobenzene in soil and in liquid enrichment culture. Appl Environ Microbiol 38(5):811–817.120698
Masunaga S, Susarla S, Yonezawa Y. 1996. Dechlorination of chlorobenzenes in anaerobic estuarine sediment. Water Sci Technol 33(6):173–180.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McElroy NR, Thompson ED, Jurs PC. 2003. Classification of diverse organic compounds that induce chromosomal aberrations in Chinese hamster cells. J Chem Inf Comput Sci 43(6):2111–2119.14632463
Mes J. 1992. Organochlorine residues in human blood and biopsy fat and their relationship. Bull Environ Contam Toxicol 48(6):815–820.1568057
Mes J, Davies DJ, Doucet J, . 1993. Levels of chlorinated hydrocarbon residues in Canadian human breast milk and their relationship to some characteristics of the donors. Food Addit Contam 10(4):429–441.8405582
Meylan W, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Middeldorp P, De Wolf J, Zehnder A, . 1997. Enrichment and properties of a 1,2,4-trichlorobenzene-dechlorinating methanogenic microbial consortium. Appl Environ Microbiol 63(4):1225–1229.16535564
Mohtashamipur E, Triebel R, Straeter H, . 1987. The bone marrow clastogenicity of eight halogenated benzenes in male NMRI mice. Mutagenesis 2(2):111–113.3331700
*Moore MR. 1994b. Final report, 104-week dietary carcinogenicity study with 1,2,4-trichlorobenzene in mice, with cover letter dated 6/15/94. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. EPA Document No. OPPTS-44612. OTS0558831.
*Moore MR. 1994a. Final report (6 copies), 104-week dietary carcinogenicity study with 1,2,4-trichlorobenzene in rats, with cover letter dated 6/15/94. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. EPA Document No. OPPTS-44612. OTS0558832.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Nagpal V, Paknikar KM. 2006. Integrated biological approach for the enhanced degradation of lindane. Indian J Biotechnol 5(Suppl):400–406.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences/National Research Council. National Academy Press.
Newsome WH, Davies D, Doucet J. 1995. PCB and organochlorine pesticides in Canadian human milk-1992. Chemosphere 30(11):2143–2153.7620848
NIOSH. 1990a. Benzene, 1,2,3-trichloro-. CAS #87-61-6. Estimated numbers of employees potentially exposed to specific agents by 2-digit Standard Industrial Classification (SIC). National Occupational Exposure Survey conducted from 1981-1983. Centers for Disease Control. National Institute for Occupational Safety and Health. http://www.cdc.gov/noes/noes1/x9450sic.html. June 18, 2010.
NIOSH. 1990b. Benzene, 1,2,4-trichloro-. CAS #120-82-1. Estimated numbers of employees potentially exposed to specific agents by 2-digit Standard Industrial Classification (SIC). National Occupational Exposure Survey conducted from 1981-1983. Centers for Disease Control. National Institute for Occupational Safety and Health. http://www.cdc.gov/noes/noes1/83334sic.html. June 18, 2010.
NIOSH. 1992. NIOSH recommendations for occupational safety and health: Compendium of policy documents and statements. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/pdfs/92-100.pdf. June 18, 2010.
NIOSH. 1994. Method 5517: Polychlorobenzenes. NIOSH manual of analytical methods (NMAM), fourth edition. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/5517.pdf. June 18, 2010.
NIOSH. 2005. 1,2,4-Trichlorobenzene. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. NIOSH Publication 2005-149. http://www.cdc.gov/niosh/npg/npgd0627.html. June 16, 2010.
Nishihara T, Nishikawa J, Kanayama T, . 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci 46(4):282–298.
NITE. 2002. Biodegradation and bioconcentration of existing chemical substances under the Chemical Substances Control Law. Trichlorobenzenes. National Institute of Technology and Evaluation. http://www.safe.nite.go.jp/data/hazkizon/pk_e_kizon_disp.html?k_no=0012. June 18, 2010.
Njoroge BNK, Ball WP, Cherry RS. 1998. Sorption of 1,2,4-trichlorobenzene and tetrachloroethene within an authigenic soil profile: Changes in K_oc_ with soil depth. J Contam Hydrol 29:347–377.
Nohmi T, Miyata R, Yoshikawa K, . 1985. Mutagenicity tests on organic chemical contaminants in city water and related compounds. 1. Bacterial mutagenicity tests. Eisei Shikenjo Hokoku 103:60–64.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
NTP. 2005. Report on carcinogens, eleventh edition. Research Triangle Park, NC: National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/toc11.html. June 18, 2010.
Oliver BG. 1987. Fate of some chlorobenzenes from the Niagara River in Lake Ontario. In: Hites RA, Eisenreich SJ, eds. Advances in chemistry series, 216. Sources and fates of aquatic pollutants. Washington, DC: American Chemical Society, 471–490.
Oliver BG, Nicol KD. 1982. Chlorobenzenes in sediments, water, and selected fish from Lakes Superior, Huron, Erie, and Ontario. Environ Sci Technol 16:532–536.
Oliver BG, Niimi AJ. 1983. Bioconcentration of chlorobenzenes from water by rainbow trout: Correlations with partitions coefficients and environmental residues. Environ Sci Technol 17:287–291.
O’Neil MJ, Heckelman PE, Koch CB, . 2006. 1,2,3-Trichlorobenzene, 1,2,4-trichlorobenzene, 1,3,5-trichlorobenzene. In: O’Neil MJ, ed. The Merck index. 14th ed. Whitehouse Station, NJ: Merck & Co., Inc., 1655–1656.
Ono Y, Somiya I, Kawaguchi T. 1992. Genotoxic evaluation on aromatic organochlorine compounds by using umu test. Water Sci Technol 26(1–11):61–69.
OSHA. 2009. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000. http://edocket.access.gpo.gov/cfr_2009/julqtr/pdf/29cfr1910.1000.pdf. June 18, 2010.
*Otson R, Fellin P. 1992. Volatile organics in the indoor environment: Sources and occurrence. In: Nriagu JO, ed. Gaseous pollutants: Characterization and cycling. Hoboken, NJ, John Wiley & Sons, Inc., 335–421.
Otson R, Polley G, Robertson JL. 1986. Chlorinated organics from chlorine used in water treatment. Water Res 20(6):775–779.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Parke DV, Williams RT. 1960. Studies in detoxication. 81. The metabolism of halogenobenzenes: (a) Penta and hexa-chlorobenzenes. (b) Further observations of 1:3:5-trichlorobenzene. Biochem J 74:5–9.16748811
Parrini M, Bolognesi C, Roggieri P. 1990. Induction of micronuclei within bone marrow polychromatic erythrocytes after intraperitoneal administration to mice. Boll Soc Ital Biol Sper 66(7):709–716.2083065
Peattie ME, Lindsay DG, Hoodless RA. 1984. Dietary exposure of man to chlorinated benzenes in the United Kingdom. Sci Total Environ 34(1–2):73–86.6710140
Peijnenburg WJG, Hart MJ, Den Hollander HA, . 1992. Reductive transformations of halogenated aromatic hydrocarbons in anaerobic water-sediment systems: Kinetics, mechanisms and products. Environ Toxicol Chem 11(3):289–300.
Pellizzari ED, Zweidinger RA, Sheldon LS. 1985b. Method 24. GC/MS Determination of volatile hydrocarbons in breath samples. In: Environmental carcinogens selected methods of analysis. Vol. 7. Lyon, France: International Agency for Research on Cancer, 413–431.
Pellizzari ED, Sheldon LS, Bursey JT. 1985a. Method 25. GC/MS Determination of volatile halocarbons in blood and tissue. In: Fishbein L, O’Neil IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. Lyon, France: International Agency for Research on Cancer, 435–444.
Pereira WE, Rostad CE, Chiou CT, . 1988. Contamination of estuarine water biota and sediment by halogenated organic compounds a field study. Environ Sci Technol 22(7):772–778.22195660
*Powers MB, Coate WB, Lewis TR. 1975. Repeated topical applications of 1,2,4-trichlorobenzene. Effects on rabbit ears. Arch Environ Health 30(4):165–167.123438
*Rao KS, Johnson KA, Henck JW. 1982. Subchronic dermal toxicity study of trichlorobenzene in the rabbit. Drug Chem Toxicol 5(3):249–263.7151719
RePORTER. 2014. Trichlorobenzenes. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. April 24, 2014
*Rimington C, Ziegler G. 1963. Experimental porphyria in rats induced by chlorinated benzenes. Biochem Pharmacol 12:1387–1397.14096426
*Robinson KS, Kavlock RJ, Chernoff N, . 1981. Multigeneration study of 1,2,4-trichlorobenzene in rats. J Toxicol Environ Health 8(3):489–500.7345170
Rossberg M, Lendle W, Pfleiderer G, . 2006. Chlorinated hydrocarbons. In: Ullman’s encyclopedia. http://mrw.interscience.wiley.com/emrw/9783527306732/ueic/article/a06_233/current/pdf. June 24, 2010.
*Sasmore DP, Mitoma C, Tyson CA, . 1983. Subchronic inhalation toxicity of 1,3,5-trichlorobenzene. Drug Chem Toxicol 6(3):241–258.6628258
Schoeny RS, Smith CC, Loper JC. 1979. Non-mutagenicity for Salmonella of the chlorinated hydrocarbons aroclor 1254, 1,2,4-trichlorobenzene, mirex and kepone. Mutat Res 68(2):125–132.92763
Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air. Environ Sci Technol 22(12):1381–1388.22200458
Shimada T, McQueen CA, Williams GM. 1983. Study of effects on cultured liver cells of three chlorinated benzenes/liver-cell mutagenicity studies with chlorobenzene with cover letter dated 05/09/94. Monsanto Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA Document No. 86940000659. OTS0557069.
Smith EN, Carlson GP. 1980. Various pharmacokinetic parameters in relation to enzyme-inducing abilities of 1,2,4-trichlorobenzene and 1,2,4-tribromobenzene. J Toxicol Environ Health 6(4):737–749.7420477
Tanaka A, Sato M, Tsuchiya T, . 1986. Excretion, distribution and metabolism of 1,2,4-trichlorobenzene in rats. Arch Toxicol 59(2):82–88.3753195
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Toxline. 2013. Trichlorobenzenes. RePORTER Database National Institutes of Health. Toxicology Literature Online. National Library of Medicine. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?TOXLINE. October 15, 2013.
Townsend BA, Carlson GP. 1981. Effect of halogenated benzenes on the toxicity and metabolism of malathion, malaoxon, parathion, and paraoxon in mice. Toxicol Appl Pharmacol 60(1):52–61.7281175
TRI12 2013. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. October 9, 2013.
USGS. 1998. Transport, behavior, and fate of volatile organic compounds in streams. Washington, DC: U.S. Geological Survey. Professional paper 1589. http://pubs.er.usgs.gov/usgspubs/pp/pp1589. June 24, 2010.
USGS. 2006. Volatile organic compounds in the nation’s ground water and drinking-water supply wells. Reston, VA: U.S. Geological Survey. Circular 1292. http://pubs.usgs.gov/circ/circ1292/pdf/circular1292.pdf. June 21, 2010.
Veningerova M, Prachar V, Kovacicova J, . 1997. Analytical methods for the determination of organochlorine compounds: Application to environmental samples in the Slovak Republic. J Chromatogr A 774(1–2):333–347.9253193
Verschueren K. 2001. 1,2,3-Trichlorobenzene, 1,2,4-trichlorobenzene, 1,3,5-trichlorobenzene. In: Handbook of environmental data on organic chemicals. 4th ed. New York, NY: John Wiley & Sons, Inc., 2044–2053.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Wakeham SG, Davis AC, Karas JL. 1983a. Mesocosm experiments to determine the fate and persistence of volatile organic compounds in coastal seawater. Environ Sci Technol 17:611–617.22288706
Wakeham SG, Goodwin JT, Davis AC. 1983b. Distribution and fate of volatile organic compounds in Narragansett Bay, Rhode Island. Can J Fish Aquat Sci 40(Suppl 2):304–321.
Wang M, Jones KC. 1994. Occurrence of chlorobenzenes in nine United Kingdom retail vegetables. J Agric Food Chem 42(10):2322–2328.
Webber MD, Pietz RI, Granato TC, . 1994. Plant uptake of PCBs and other organic contaminants from sludge-treated coal refuse. J Environ Qual 23(5):1019–1026.34872209
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2000. Summary of the guidelines. In: WHO air quality guidelines for Europe. 2nd ed. Geneva, Switzerland: World Health Organization, 32–40. http://www.euro.who.int/__data/assets/pdf_file/0005/74732/E71922.pdf. June 17, 2010.
WHO. 2006. Annex 4-Chemical summary tables. In: Guidelines for drinking-water quality, 3rd ed., incorporating first and second addenda. Geneva, Switzerland: World Health Organization, 488–492. http://www.who.int/water_sanitation_health/dwq/GDWAN4rev1and2.pdf. May 19, 2009.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
*Yamamoto H, Ohno Y, Nakamori K, . 1982. Chronic toxicity and carcinogenicity testing of 1,2,4-trichlorobenzene on mice by dermal painting. Nara Igaku Zasshi 33(2):132–145.
*Yamamoto H, Taniguchi Y, Imai S, . 1978. Acute toxicity and local irritation tests of trichlorobenzene (TCB) on DDY mice. Nara Igaku Zasshi 29(4–5):569–573.
Younglai EV, Foster WG, Hughes EG, . 2002. Levels of environmental contaminants in human follicular fluid, serum, and seminal plasma of couples undergoing in vitro fertilization. Arch Environ Contam Toxicol 43(1):121–126.12045882
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zimmering S, Mason JM, Valencia R, . 1985. Chemical mutagenesis testing in drosophila. II. Results of 20 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:87–100.3917911