# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an intermediate-duration oral MRL of 0.1 mg/kg/day for 1,2,4-trichlorobenzene based on an increased incidence of centrilobular hepatocyte hypertrophy in male rats administered 1,2,4-trichlorobenzene in the diet for 13 weeks (CMA 1989). The MRL was derived using BMD modeling of incidence data for hepatocyte hypertrophy in male rats. The predicted dose associated with a 10% extra risk (BMD_10_) for hepatocyte hypertrophy was 33.09 mg/kg/day; the lower 95% confidence limit on this dose (BMDL_10_) was 14.35 mg/kg/day. An uncertainty factor of 100 was used (10 for animal to human extrapolation and 10 for human variability).

ATSDR has derived a chronic-duration oral MRL of 0.1 mg/kg/day for 1,2,4-trichlorobenzene based on an increased incidence of hepatocellular hypertrophy in male rats administered 1,2,4-trichlorobenzene in the diet for 104 weeks (Moore 1994a). The MRL was derived using BMD modeling of incidence data for hepatocellular hypertrophy in male rats. The predicted dose associated with a 10% extra risk (BMD_10_) for hepatocellular hypertrophy was 23.25 mg/kg/day; the lower 95% confidence limit on this dose (BMDL_10_) was 13.33 mg/kg/day. An uncertainty factor of 100 was used (10 for animal to human extrapolation and 10 for human variability).

EPA (IRIS 2010) has established an oral reference dose (RfD) for 1,2,4-trichlorobenzene of 0.01 mg/kg/day based on a NOAEL of 14.8 mg/kg/day for increased adrenal weights in rats exposed to 1,2,4-trichlorobenzene in drinking water (Robinson et al. 1981). The uncertainty factor used in this assessment was 1,000 (10 for extrapolation from laboratory studies, 10 for the protection of sensitive human subpopulations, and 10 to account for a lack of chronic studies). EPA’s assessment was conducted in 1991.

EPA has not derived an inhalation reference concentration (RfC) for trichlorobenzenes.

The international and national regulations, advisories, and guidelines regarding trichlorobenzenes in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Trichlorobenzenes

Agency | | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
| IARC | Carcinogenicity classification | No | IARC 2009
| WHO | Air quality guidelines | No | WHO 2000
| WHO | Drinking water quality guidelines | No^a^ | WHO 2006
[underlined: NATIONAL]
Regulations and Guidelines:
a. | Air
a. | ACGIH | TLV (8-hour TWA) | No | ACGIH 2009
a. | ACGIH | STEL (15-minute TWA)
a. | ACGIH | 1,2,4-Trichlorobenzene | 5 ppm^b^
a. | ACGIH | TLV-basis (critical effect) | Eye and upper respiratory tract irritation
a. | AIHA | ERPGs | No | AIHA 2010
a. | EPA | AEGLs | No | EPA 2010c
a. | EPA | Hazardous air pollutant | | EPA 2006b; 42 USC 7412
a. | EPA | 1,2,4-Trichlorobenzene | Yes
a. | EPA | Regulated toxic substances and threshold quantities for accidental release prevention | No | EPA 2009j; 40 CFR 68.130
a. | EPA | Second AEGL chemical priority list | | EPA 2010d
a. | EPA | 1,2,4-Trichlorobenzene | Yes^c^
a. | NIOSH | REL (10-hour TWA) | | NIOSH 2005
a. | NIOSH | 1,2,4-Trichlorobenzene | 5 ppm (40 mg/m^3^)^b^
a. | NIOSH | Target organs | Eyes, skin, respiratory system, liver, reproductive system
a. | NIOSH | Category of pesticide | Group III^d^ | NIOSH 1992
a. | OSHA | PEL (8-hour TWA) for general industry | No | OSHA 2009; 29 CFR 1910.1000, Table Z-1
a. | DOE | TEELs
a. | DOE | TEEL-0^e^
a. | DOE | 1,2,3-Trichlorobenzene | 5 mg/m^3^ | DOE 2010a
a. | DOE | 1,2,4-Trichlorobenzene | 0.25 ppm (1.5 mg/m^3^) | DOE 2010b
a. | DOE | PAC-1^f^
a. | DOE | 1,2,3-Trichlorobenzene | 15 mg/m^3^
a. | DOE | 1,2,4-Trichlorobenzene | 0.75 ppm (5 mg/m^3^)
a. | DOE | PAC-2^g^
a. | DOE | 1,2,3-Trichlorobenzene | 25 mg/m^3^
a. | DOE | 1,2,4-Trichlorobenzene | 5 ppm (35 mg/m^3^)
a. | DOE | PAC-3^h^
a. | DOE | 1,2,3-Trichlorobenzene | 500 mg/m^3^
a. | DOE | 1,2,4-Trichlorobenzene | 40 ppm (300 mg/m^3^)
b. | Water
b. | EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | No | EPA 2009c; 40 CFR 116.4
b. | EPA | Drinking water contaminant candidate list | No | EPA 1998a; 63 FR 10274
b. | EPA | Drinking water standards and health advisories | | EPA 2009d
b. | EPA | 1-Day health advisory for a 10-kg child
b. | EPA | 1,2,4-Trichlorobenzene | 0.1 mg/L
b. | EPA | 1,3,5-Trichlorobenzene | 0.6 mg/L
b. | EPA | 10-Day health advisory for a 10-kg child
b. | EPA | 1,2,4-Trichlorobenzene | 0.1 mg/L
b. | EPA | 1,3,5-Trichlorobenzene | 0.6 mg/L
b. | EPA | DWEL
b. | EPA | 1,2,4-Trichlorobenzene | 0.35 mg/L
b. | EPA | 1,3,5-Trichlorobenzene | 0.2 mg/L
b. | EPA | Lifetime
b. | EPA | 1,2,4-Trichlorobenzene | 0.07 mg/L
b. | EPA | 1,3,5-Trichlorobenzene | 0.04 mg/L
b. | EPA | 10^−4^ Cancer risk | No
b. | EPA | Master Testing List | Yes^i^ | EPA 1996a
b. | EPA | National primary drinking water standards (1,2,4-trichlorobenzene) | | EPA 2009e
b. | EPA | MCL | 0.07 mg/L
b. | EPA | Potential health effects from long-term exposure above the MCL | Changes in adrenal glands
b. | EPA | Common sources of 1,2,4-Trichlorobenzene in drinking water | Discharge from textile finishing factories
b. | EPA | Public health goal | 0.07 mg/L
b. | EPA | National recommended water quality criteria (1,2,4-trichlorobenzene) | Yes | EPA 2006a
b. | EPA | Human health for the consumption of
b. | EPA | Water + organism | 35 μg/L
b. | EPA | Organism only | 70 μg/L
b. | EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No | EPA 2009l; 40 CFR 117.3
b. | EPA | Groundwater monitoring list | Yes | EPA 2009a; 40 CFR 264, Appendix IX
c. | Food
c. | FDA | Bottled drinking water | | FDA 2010a; 21 CFR 165.110
c. | FDA | 1,2,4-Trichlorobenzene | 0.07 mg/L
c. | FDA | EAFUS | No | FDA 2010b
d. | Other
d. | ACGIH | Carcinogenicity classification | No | ACGIH 2009
d. | EPA | Carcinogenicity classification | | IRIS 2010
d. | EPA | 1,2,4-trichlorobenzene | D^j^
d. | EPA | RfC | No
d. | EPA | RfD
d. | EPA | 1,2,4-Trichlorobenzene | 0.01 mg/kg/day
d. | EPA | Superfund, emergency planning, and community right-to-know
d. | EPA | Designated CERCLA hazardous substance (1,2,4-trichlorobenzene) | Yes^k^ | EPA 2009g; 40 CFR 302.4
d. | EPA | Reportable quantity | 100 pounds
d. | EPA | Effective date of toxic chemical release reporting | | EPA 2009i; 40 CFR 372.65
d. | EPA | 1,2,4-Trichlorobenzene | 1/1/1987
d. | EPA | Extremely hazardous substances and its threshold planning quantity | No | EPA 2009h; 40 CFR 355, Appendix A
d. | EPA | TSCA chemical lists and reporting periods | No | EPA 2009b; 40 CFR 712.30
d. | EPA | TSCA health and safety data reporting | | EPA 2009m; 40 CFR 716.120
d. | EPA | Effective date | | EPA 2009m; 40 CFR 716.120
d. | EPA | 1,2,3-Trichlorobenzene | 10/04/1982 | EPA 2009m; 40 CFR 716.120
d. | EPA | 1,2,4-Trichlorobenzene | 10/04/1982 | EPA 2009m; 40 CFR 716.120
d. | EPA | 1,3,5-Trichlorobenzene | 10/04/1982 | EPA 2009m; 40 CFR 716.120
d. | EPA | Sunset date | | EPA 2009m; 40 CFR 716.120
d. | EPA | 1,2,3-Trichlorobenzene | 10/04/1992 | EPA 2009m; 40 CFR 716.120
d. | EPA | 1,2,4-Trichlorobenzene | 10/04/1992 | EPA 2009m; 40 CFR 716.120
d. | EPA | 1,3,5-Trichlorobenzene | 10/04/1992 | EPA 2009m; 40 CFR 716.120
d. | EPA | RCRA waste minimization PBT priority chemical list (1,2,4-trichlorobenzene) | Yes | EPA 1998b; 63 FR 60332
d. | EPA | Standards of performance for equipment leaks of VOC in the synthetic organic chemicals manufacturing industry | | EPA 2009f; 40 CFR 60 Subpart VV
d. | EPA | Trichlorobenzenes | Yes
d. | EPA | Organic hazardous air pollutant | | EPA 2009k; 40 CFR 63, Table 2 to Subpart F
d. | EPA | 1,2,4-Trichlorobenzene | Yes
d. | NTP | Carcinogenicity classification | No | NTP 2005

a Guideline value not established because total trichlorobenzenes occur in drinking water at concentrations below those at which toxic effects may occur, and health-based value would exceed lowest reported odor threshold (WHO 2006).

b Ceiling: the concentration should not be exceeded during any part of the working exposure.

c Trichlorobenzenes are included on the list of 371 priority chemicals that are acutely toxic and represent the selection of chemicals for AEGL development by the NAC/AEGL committee during the next several years.

d Group III pesticides pose minimal risk of adverse acute effects even at relatively high doses.

e TEEL-0 is the threshold concentration below which most people will experience no adverse health effects.

f PAC-1 is the airborne concentration (expressed as ppm or mg/m^3^) of a substance above which it is predicted that the general population, including susceptible individuals, could experience discomfort, irritation, or certain asymptomatic, nonsensory effects. However, these effects are not disabling and are transient and reversible upon cessation of exposure.

g PAC-2 is the airborne concentration (expressed as ppm or mg/m^3^) of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting, adverse health effects or an impaired ability to escape.

h PAC-3 is the airborne concentration (expressed as ppm or mg/m^3^) of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death.

i 1,2,4-Trichlorobenzene was originally recommended to the MTL by the TSCA Interagency Testing Committee in 1990 and was removed in 1994 because the TSCA Section 4 Final Rule-Making testing program was completed. 1,2,4-Trichlorobenzene was again recommended to the MTL in 1995 by the Organization for Economic Cooperation and Development (OECD) and by the U.S. EPA Office of Air and Radiation (OAR). The OECD chemical testing program is currently underway by a voluntary testing agreement and the testing needs include SIDS screening data for health effects, environmental effects, and environmental fate and exposure. The OAR chemical testing action development is currently underway and the testing needs for health effects include acute toxicity, neurotoxicity, developmental toxicity and immunotoxicity.

j D: not classifiable as to human carcinogenicity based on a dermal exposure study in mice that was found inadequate for drawing conclusions as to carcinogenicity in humans.

k Designated CERCLA hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act and Section 112 of the Clean Air Act.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; MTL = Master Testing List; NAC = National Advisory Committee; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; SIDS = Screening Information Data Sets; STEL = short-term expsoure limit; TEEL = temporary emergency exposure limits; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TWA = time-weighted average; USC = United States Code; VOC = volatile organic compound; VTA = Voluntary Testing Agreement; WHO = World Health Organization

EPA has designated 1,2,4-trichlorobenzene as a hazardous air pollutant (HAP) under the Clean Air Act (CAA) (EPA 2006b). 1,2,4-Trichlorobenzene is on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986” and has been assigned a reportable quantity (RQ) limit of 100 pounds (EPA 2009g). The RQ represents the amount of a designated hazardous substance which, when released to the environment, must be reported to the appropriate authority.