# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

There are three possible isomers for trichlorobenzene: 1,2,3-trichlorobenzene; 1,2,4-trichlorobenzene; and 1,3,5-trichlorobenzene. The chemical identity of each isomer is shown in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Trichlorobenzenes are relatively volatile, hydrophobic substances. The physical and chemical properties of each isomer are shown in Table 4-2.

Table 4-1 Chemical Identity of Trichlorobenzenes^a^

Characteristic | 1,2,3-Trichlorobenzene | 1,2,4-Trichlorobenzene | 1,3,5-Trichlorobenzene
Synonym(s) | Benzene, 1,2,3-trichloro-; vic-trichlorobenzene; AI3-15516 | Benzene, 1,2,4-trichloro-; unsym-Trichlorobenzene; AI3-07775; 1,2,4-Triclorobenceno (Spanish) | Benzene, 1,3,5-trichloro-; s-Trichlorobenzene; sym-Trichlorobenzene
Chemical formula | C_6_H_3_Cl_3_ | C_6_H_3_Cl_3_ | C_6_H_3_Cl_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 87-61-6 | 120-82-1 | 108-70-3
RTECS | No data | DC2100000^b^ | No data
EPA hazardous waste | No data | No data | No data
EPA/OPP pesticide Code | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data
HSDB | 1502 | 1105 | 132
EINECS | No data | 204-428-0^c^ | No data
NCI | No data | No data | No data

a All information from HSDB 2010, unless otherwise noted.

b NIOSH 1994.

c European Communities 2003.

Table 4-2 Physical and Chemical Properties of Trichlorobenzenes^a^

Property | 1,2,3-Trichlorobenzene | 1,2,4-Trichlorobenzene | 1,3,5-Trichlorobenzene
Molecular weight | 181.45 | 181.45 | 181.45
Physical description | Platelets from alcohol | Colorless liquid | White crystals
Melting point | 51.3°C | 16.92°C | 62.8°C
Boiling point | 218.5°C | 213.5°C | 208°C
Density | 1.4533 g/cm^3^ at 25°C | 1.459 g/cm^3^ at 20°C | 1.456 g/cm^3^ at 20°C
Odor | No data | Aromatic odor | No data
Solubility:
Water | 18 mg/L at 25°C | 49 mg/L at 25°C | 6.01 mg/L at 25°C
Organic solvent(s) | Slightly soluble in ethanol; very soluble in ether and benzene. Freely soluble in carbon disulfide | Sparingly soluble in alcohol; miscible with ether, benzene, petroleum ether, carbon disulfide | Sparingly soluble in alcohol; freely soluble in ether, benzene, petroleum ether, carbon disulfide, glacial acetic acid
Partition coefficients:
Log K_ow_ | 4.05 | 4.02 | 4.19
Log K_oc_ | 3.21–3.90 | 3.10–4.03 | 2.80–3.82
Henry’s Law constant | 1.25×10^−3^ atm-m^3^/mol | 1.42×10^−3^ atm-m^3^/mol | 1.89×10^−3^ atm-m^3^/mol
Vapor pressure | 0.21 mm Hg at 25°C | 0.46 mm Hg at 25°C | 0.24 mm Hg at 25°C
Autoignition temperature | No data | 571°C | No data
Flashpoint | 112.7°C | 105°C | 107°C
Flammability limits in air | No data | Lower flammable limit: 2.5% by volume at 302°F (150°C). Upper flammable limit: 6.6% by volume at 302°F (150°C) | No data
Conversion factors^b^ | 1 mg/m^3^=0.13 ppm | 1 mg/m^3^=0.13 ppm | 1 mg/m^3^=0.13 ppm
Explosive limits | No data | 2.5–6.6 % volume (at 150°C) | No data

a All information from HSDB 2010, unless otherwise noted.

b Verschueren 2001.